# Literature Search Strategies and Yields

## Published Literature

Table A1 PubMed original search, 3/26/15

[Limited to date range of 1/1/1990 – present.]

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “total worker health” | 22
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Occupational Health”[Mesh] OR “Occupational Health Services”[Mesh] OR “Occupational Injuries”[Mesh] OR “Workplace”[Mesh] OR “worksite health” | 45888
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Health Promotion”[Mesh]) OR “Accident Prevention”[Mesh]) OR “Wounds and Injuries/prevention and control”[Mesh] | 160904
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 AND #3) | 7667
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #4) | 7676
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #4) Filters: Humans | 7116
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #4) Filters: Humans; English | 6473
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #4) Filters: Publication date from 1990/01/01; Humans; English | 6074
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Clinical Trial” [Publication Type] OR “Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type]) OR “Evaluation Studies” [Publication Type] OR (“Cohort Studies”[Mesh]) OR “Longitudinal Studies”[Mesh] | 2127524
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 AND #9) | 830
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Occupational Diseases/prevention & control OR Accidents, Occupational/prevention & control) | 22822
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Workplace”[Mesh] OR Work[Mesh] OR worksite OR workplace OR protection OR “integrated intervention” | 309706
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((occupational health [mesh] OR occupational exposure [mesh])) | 73332
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND #12 AND #13) | 1562
#15 | Search study OR intervention OR program | 7088040
#16 | Search (#14 AND #15) | 702
#17 | Search (#14 AND #15) Filters: English | 573
#18 | Search (#14 AND #15) Filters: Humans; English | 571
#19 | Search (#14 AND #15) Filters: Publication date from 1990/01/01; Humans; English | 563
#20 | Search (#10 OR #19) | 1359

Table A2 PubMed update search, 9/21/15

[Limited to date range of 8/1/2014 – present.]

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “total worker health” | 26 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Occupational Health”[Mesh] OR “Occupational Health Services”[Mesh] OR “Occupational Injuries”[Mesh] OR “Workplace”[Mesh] OR “worksite health” | 47216 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Health Promotion”[Mesh]) OR “Accident Prevention”[Mesh]) OR “Wounds and Injuries/prevention and control”[Mesh] | 166271 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 AND #3) | 7971 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #4) | 7981 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #4) Filters: Publication date from 1990/01/01; Humans; English | 253 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Clinical Trial” [Publication Type] OR “Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type]) OR “Evaluation Studies” [Publication Type] OR (“Cohort Studies”[Mesh]) OR “Longitudinal Studies”[Mesh] | 2199173 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 AND #10) | 29 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Occupational Diseases/prevention & control OR Accidents, Occupational/prevention & control) | 23088 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Workplace”[Mesh] OR Work[Mesh] OR worksite OR workplace OR protection OR “integrated intervention” | 321211 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((occupational health [mesh] OR occupational exposure [mesh])) | 75045 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 AND #13 AND #14) | 1610 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search study OR intervention OR program | 7337802 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 AND #16) | 720 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 AND #16) Filters: Publication date from 2014/08/01; Humans; English | 13 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#20 OR #11) Filters: Publication date from 2014/08/01; Humans; English | 41 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)

Table A3 Cochrane Library original search for reviews, 3/26/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 16
#2 | (occupational OR work) AND (health promotion OR prevention) AND (integrated OR “health education”) | 8

Table A4 Cochrane Library update search for reviews, 9/21/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 5
#2 | (occupational OR work) AND (health promotion OR prevention) AND (integrated OR “health education”) | 1

Table A5 Cochrane Library original search for clinical trials, 3/26/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 21
#2 | (occupational OR work) AND (health promotion OR prevention) AND (integrated OR “health education”) | 20

Table A6 Cochrane Library update search for clinical trials, 9/21/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 7
#2 | (occupational OR work) AND (health promotion OR prevention) AND (integrated OR “health education”) | 0

Table A7 PsycINFO original search, 3/26/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 3
#2 | (occupational OR work) AND (health promotion OR prevention) AND (integrated OR “health education”) | 23

Table A8 PsycINFO update search, 3/26/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 1
#2 | (occupational OR work) AND (health promotion OR prevention) AND (integrated OR “health education”) | 8

## Gray Literature

Table A9 Academic Search Premier, original search, 3/26/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 12

Table A10 Academic Search Premier, update search, 9/21/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 9

Table A11 ClinicalTrials.gov, original search, 3/26/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 12
#2 | (occupational OR worksite) AND (health promotion OR prevention) AND (integrated) | 8

Table A12 ClinicalTrials.gov, update search, 9/21/15

[No limits based on publication date.]

ID | Search | Hits
#1 | “Total Worker Health” | 0
#2 | (occupational OR worksite) AND (health promotion OR prevention) AND (integrated) | 0