# Results

## Results of Literature Searches

We depict the literature selection process in Figure 2. Searches identified 2,880 citations, of which we excluded 2,637. The most common reasons for exclusion were studies of other conditions (e.g., non-small-cell lung cancer), case reports, studies of treatments, and other studies not addressing staging. We retrieved the other 243 articles, of which we excluded 236. The most common reasons were studies with fewer than 10 patients with SCLC and studies of other conditions. See Appendix B for a list of the publications excluded at the full article level. We included the remaining seven publications. Our search of Clinicaltrials.gov identified no additional relevant studies.

Figure 2 Literature flow diagram

SCLC = small cell lung cancer

Figure 2 shows the counts of articles at various stages of searching. The box at the top stated that searches identified 2,880 articles that were potentially relevant. Screening of abstracts excluded 2,637 of these, for many different reasons, which are listed in the upper right box. The most common reason was that the article did not involve SCLC patients (953 articles). Other reasons included treatment studies (269 studies), non-staging studies (232), narrative reviews (254), screening studies (170), case reports (322), opinions (129), none of the modalities of interest (118), duplicate articles (47), studies of prognosis (40), animal/in vitro/phantom studies (27), systematic reviews (18), fewer than 10 patients with SCLC (18), guidelines (17), and other reasons (23). We then reviewed 243 full articles, and 236 of these were excluded for various reasons, listed in the box on the lower right. The most common reason for exclusion at the full article level was fewer than 10 patients with SCLC (64 articles), non-SCLC studies (42), studies of a single test of interest but not data on staging accuracy (31), no separate data on patients with SCLC (26), reviews (22), unclear whether any patients had SCLC (10), none of the modalities of interest (10), not staging before treatment (9), no outcomes of interest (9), duplicate articles (2), and other reasons (11).

All seven studies were included for KQ1, and none were included for KQs 2 or 3. Two studies were conducted in South Korea, and one each in Japan, Taiwan, Spain, Germany, and Denmark. The only study not published in English was one from Spain.21 The studies enrolled a total of 408 patients with SCLC, with average ages ranging from 56 to 68, and the percentage of patients who were female ranged from 15 percent to 62 percent. Start dates ranged from 1999 to 2008, and the median duration of patient enrollment was about 5 years. Four studies were retrospective, and three were prospective. Only one study22 reported its funding source (the German Cancer Foundation, which likely would not have a vested interest in some imaging technologies over others), and two other studies23,24 reported that there were no financial conflicts of interest to disclose.

All evidence tables appear in Appendix C, including general study information (Table C-1), patient characteristics (Table C-2), general test details (Table C-3), readers and reference standards (Table C-4), concordance data (Table C-5), accuracy data (Table C-6), and our analyses of accuracy data (Table C-7). Of the seven studies, three23-25 reported the comparative accuracy of two or more tests, and four21,22,26,27 reported single-test accuracy. One25 of the comparative accuracy studies also reported concordance data.

Regarding the imaging tests performed:

- Three studies24,25,27 reported data on “standard staging” or “conventional staging.” This involved multiple tests, typically history, clinical exam, chest x-ray, bone marrow biopsy, and possibly MRI or CT of the brain.
- Three studies22,23,25 reported data on whole-body bone scintigraphy with Tc99m-MDP, using a dose of 500-900 MBq 2 to 3 hours before the scan, and a dual-head camera
- Two studies22,25 reported data on MDCT, but authors provided few details.
- Four studies21,23-25 reported data on PET/CT using FDG (dose range 400–550 MBq). One was specifically of the brain,21 and the others three were presumably whole body. All were dedicated PET/CT scanners: two were the GE Discovery system, one was the Phillips Gemini scanner, and one was the Siemens Biograph Sensation.
- One study26 reported data on EBUS, using a convex probe integrated with convex transducer; a 22-gauge needle was used for needle aspiration.
- No studies reported data on MRI, PET/MRI, or EUS.

For three studies of comparative accuracy of imaging tests, the elapsed time between the tests was a median of 5 days in one study,23 a maximum of 7 days in another study,25 and not reported by the third study.24 Test readers were generally experienced, but authors mentioned little about resolving difference among different readers. Reference standards were based on multiple considerations such as histology if available, clinical followup, progression on subsequent scans, and other imaging results such as MRI.

Our risk-of-bias assessments appear in Appendix D in Figure D-1 and Figure D-2. Of the three studies reporting comparative accuracy, we rated two as moderate risk of bias and one as high risk-of-bias. The moderate ratings were due to unknown spectrum bias, lack of reporting of whether test readers had the same clinical information available when interpreting different tests, and the use of test results in determining the reference standard. The one high-risk-of-bias rating was due to the above problems as well as the probability of spectrum bias, not reporting the elapsed time between imaging tests, and non-complementary knowledge available to different test readers.

The four single-test accuracy studies were all rated as moderate risk of bias. Reasons for the moderate rating varied across studies, but common problems were not accounting for inter-reader differences and not blinding the reference standard assessment to test results or other clinical information.

## Key Question 1 Concordance and Comparative Accuracy

In this section, we address the following KQ:

KQ1: What are the test concordance and comparative accuracy of imaging tests (MDCT, PET/CT, MRI, PET/MRI, EBUS, EUS, bone scintigraphy) for the pretreatment staging of SCLC?

We first briefly summarize test concordance data, and then the rest of the section concerns comparative accuracy.

### Test Concordance

One study25 reported test-test concordance data for three imaging tests (MDCT, FDG PET/CT, and bone scintigraphy). The data appear in Table C-5 of Appendix C. For various staging determinations (T stage, N stage, pleural effusion, metastases to ipsilateral lung, metastases to contralateral lung, metastases to the liver, metastases to the adrenal glands, and metastases to extra-thoracic lymph nodes), authors reported high agreement between MDCT and FDG PET/CT, ranging from 86 to 97 percent. For the assessment of osseous involvement, however, agreement was lower (83 percent between MDCT and FDG PET/CT; 46 percent between MDCT and bone scintigraphy; 57 percent between FDG PET/CT and bone scintigraphy). The same study also reported the accuracy of these modalities for assessing osseous metastases, and these data are discussed (along with all other accuracy data) in the next section.

### Comparative Accuracy

An overview of the included accuracy data appears in Table 2. Studies reported numerous staging determinations (e.g., whether the patient has limited or extensive disease), but the evidence for any given determination and modality comparison was limited. The largest evidence base involved the comparison of FDG PET/CT to bone scintigraphy in the determination of osseous (bone or bone marrow) metastases; this evidence base comprised two studies making direct comparisons (combined n=123) and a single study reporting only bone scintigraphy accuracy data (n=76).

Table 2 Overview of included accuracy data

Staging Determination | Studies Making Direct Comparisons in Accuracy Between Imaging Modalities | Studies Reporting Accuracy Data on a Single Imaging Modality (i.e., for indirect comparisons)
Limited or extensive disease | Standard staging^*^ vs. FDG PET/CT; 1 study, n=28 | Standard staging only^*^; 1 study, n=25
Presence of metastases to osseous structures (bone or bone marrow) | MDCT vs. Bone scintigraphy; 1 study, n=28 MDCT vs. FDG PET/CT; 1 study, n=29 Bone scintigraphy vs. FDG PET/CT; 2 studies, n=123 | Bone scintigraphy only; 1 study, n=76
Presence of lymph node involvement | None | MDCT only; 1 study, n=118 EBUS only; 1 study, n=36
Presence of metastases to adrenal glands | None | MDCT only; 1 study, n=120
Presence of metastases to the liver | None | MDCT only; 1 study, n=120
Presence of metastases to the spleen | None | MDCT only; 1 study, N=120
Presence of any distant metastases | Standard staging^*^ vs. standard staging^*^ plus FDG PET/CT; 1 study, N=73 | None
Presence of metastases to the brain | None | FDG PET/CT only; 1 study, N=21

FDG PET/CT = [^18^F]-fluorodeoxyglucose positron emission tomography/computed tomography; MDCT = multidetector computed tomography

* Standard” staging of SCLC is not a precisely defined term, but may involve numerous investigations including history, physical exam, chest x-ray, chest CT, bone scan, bone marrow aspiration, and/or MRI or CT of the brain.

Below, we discuss the results separately for each of eight staging determinations (LD/ED, metastases to osseous structures (bone or bone marrow), lymph node involvement, metastases to adrenal glands, metastases to the liver, metastases to the spleen, any distant metastases, and metastases to the brain).

A detailed description of reference standards for each study is provided in Appendix C, Table C-4. As a reminder, studies utilizing an imaging test alone as a reference standard were considered to provide information regarding test concordance, but not comparative accuracy. Reference standards for comparative accuracy studies varied widely, from clinical follow up to composite measures consisting of several possible elements (i.e., positive biopsy or confirmation by CT or MRI or progression on subsequent imaging).

#### Limited or Extensive Disease

Two studies25,27 with moderate risk of bias reported data on the ability of imaging tests to determine whether patients with SCLC had LD or ED. Both reported the use of “standard staging,” which is a combination of multiple testing procedures such as chest x-ray, bone marrow biopsy and possibly MRI or CT of the brain. In addition, Fischer et al. (2007)25 reported data on the performance of FDG PET/CT in staging disease as LD or ED. The data suggest that both standard staging and FDG PET/CT performed well (e.g., 86 percent or 95 percent for the sensitivity at detecting ED, or specificity of 90 percent or more at ruling out ED). However, both studies were small (n=28 and n=25, respectively), and the overall data were too imprecise to permit any conclusions about relative accuracy.

#### Metastases to Osseous Structures (Bone or Bone Marrow)

Three studies with moderate risk of bias reported data on the ability of imaging tests to determine whether patients had metastases to osseous structures (bone or bone marrow). One study compared FDG PET/CT to bone scintigraphy;23 another study compared CT to FDG PET/CT to bone scintigraphy;25 the third study provided data only on bone scintigraphy.22 The sensitivity and specificity data are shown in Figure 3. For bone scintigraphy, the data from Fischer et al. (2007)25 are shown twice: once if equivocal bone scans are treated as positive tests and another if equivocal bone scans are treated as negative tests.

Figure 3 ROC plots of accuracy data for osseous metastases

Note: The three plots show the data on osseous metastases in ROC space. The left plot is for bone scintigraphy, the middle plot is for MDCT, and the right plot is for FDG PET/CT. They each show two accuracy measures; sensitivity and specificity. Sensitivity is the percentage of patients who are deemed by the test to have osseous metastases, among those who truly do have osseous metastases. Specificity, by contrast, is the percentage of patients who are deemed by the test to not have osseous metastases, among those who truly do not have osseous metastases. The best possible score for both measures is 100 percent. In each plot, the horizontal axis is specificity (with higher specificity as one moves to the left in the plot), and the vertical axis is sensitivity (with higher sensitivity as one moves up in the plot). The 45-degree line represents chance. Thus, an optimal modality would have data in the upper left corner of the plot. Each point is a study (with different studies represented by different shapes). The error bars represent 95% confidence intervals. The study by Brink provided data only on bone scintigraphy, which explains why it does not appear in the other two plots. The study by Lee compared bone scintigraphy and FDG- PET/CT, and the study by Fischer compared all three modalities. The Fischer data are further complicated by the fact that some bone scintigraphy results were considered equivocal by the authors (i.e., neither clearly positive nor clearly negative). Treating equivocal results as positive (as shown with the point labeled “Fischer Equiv. POS”) results in higher sensitivity than treating equivocal bone scan results as negative (as shown with the point labeled “Fischer Equiv. NEG”), but lower specificity. For PET/CT, both studies had point estimates for specificity of 100 percent, but the confidence intervals around those estimates were too wide to permit conclusions about relative specificity.

Figure 3 depicts three plots showing the data on osseous metastases in ROC space. The left plot is for bone scintigraphy, the middle plot is for MDCT, and the right plot is for FDG PET/CT. They each show two accuracy measures; sensitivity and specificity. Sensitivity is the percentage of patients who are deemed by the test to have osseous metastases, among those who truly do have osseous metastases. Specificity, by contrast, is the percentage of patients who are deemed by the test to not have osseous metastases, among those who truly do not have osseous metastases. The best possible score for both measures is 100%. In each plot, the horizontal axis is specificity (with higher specificity as one moves to the left in the plot), and the vertical axis is sensitivity (with higher sensitivity as one moves up in the plot). The 45-degree line represents chance. Thus, an optimal modality would have data in the upper left corner of the plot. Each point is a study (with different studies represented by different shapes). The error bars represent 95% confidence intervals. The study by Brink provided data only on bone scintigraphy, which explains why it does not appear in the other two plots. The study by Lee compared bone scintigraphy and FDG- PET/CT, and the study by Fischer compared all three modalities. The Fischer data are further complicated by the fact that some bone scintigraphy results were considered equivocal by the authors (i.e., neither clearly positive nor clearly negative). Treating equivocal results as positive (as shown with the point labeled “Fischer Equiv. POS”) results in higher sensitivity than treating equivocal bone scan results as negative (as shown with the point labeled “Fischer Equiv. NEG”), but lower specificity. For PET/CT, both studies had point estimates for specificity of 100%, but the confidence intervals around those estimates were too wide to permit conclusions about relative specificity.

Our statistical tests of these data indicated FDG PET/CT was more sensitive than bone scintigraphy in the Lee study; the Fischer study replicated this finding if equivocal bone scans were treated as negative tests. If they were considered positive tests, then for the Fischer study FDG PET/CT was more specific than bone scintigraphy. These are direct comparisons. Considered together with the bone scintigraphy results in the Brink study, we concluded that FDG PET/CT is more sensitive than bone scintigraphy for detecting osseous metastases. There was not sufficient data to allow us to assess comparative sensitivity by metastasis site.

Comparing FDG PET/CT to MDCT, only the Fischer study made a direct comparison, and FDG PET/CT was more sensitive, but not more specific. Thus, we concluded that FDG PET/CT is more sensitive than MDCT for detecting osseous metastases. Too little data exist to permit a conclusion on specificity, so we cannot rule out FDG PET/CT being less specific than MDCT.

Finally, with regard to comparing MDCT with bone scintigraphy, treating equivocal bone scans as positive resulted in a statistical advantage in sensitivity for bone scintigraphy but a statistical advantage in specificity for MDCT. By contrast, if equivocal bone scans were treated as negatives in Fischer, we found no statistical differences in sensitivity or specificity. Other data on bone scintigraphy from Brink and Lee do not suggest marked differences from MDCT. However, the data were too imprecise to permit any conclusions about the comparison of MDCT and bone scintigraphy with respect to osseous metastases.

#### Lymph Node Involvement

Two moderate-risk-of-bias studies reported data on the ability of imaging tests to determine whether patients had lymph node involvement. One study used EBUS for this purpose;26 the other used MDCT.22 The EBUS study reported better results (96 percent sensitivity, 100 percent specificity) than the CT study (70 percent sensitivity, 94 percent specificity). However, patients in the CT study (which defined a positive lymph node as >1cm) may have had cancers that were more difficult to assess for lymph node involvement, which would bias the comparison against CT. The indirect nature of the comparison precludes conclusions.

#### Metastases to Adrenal Glands, Liver, or Spleen

A single study22 with moderate risk of bias reported the single-test performance of MDCT for detecting metastases to the adrenal glands, liver, or spleen (separate results for each of these three types). Because such data were not reported for other imaging modalities by this or other studies, we drew no conclusions about how different modalities compare.

#### Any Distant Metastases

A single study24 with high risk of bias reported the comparative performance of standard staging versus standard staging plus FDG PET/CT for detecting any distant metastases. The study reported a large difference in sensitivity (92 percent for standard staging plus FDG PET/CT vs. only 46 percent for standard staging), and this difference was statistically significant. The specificities were similar (96 percent for standard staging plus FDG PET/CT vs. 100 percent for standard staging), but the precision was too high to permit a conclusion of equivalence on specificity. We deemed the evidence sufficient to permit the conclusion that standard staging plus FDG PET/CT is more sensitive than standard staging alone for detecting any distant metastases. Given that it was only a single study that had a high risk of bias, we rated the strength of evidence as low.

#### Metastases to the Brain

A single study with moderate risk of bias reported the single-test performance of FDG PET/CT of the brain for detecting brain metastases. Because such data were not reported for other modalities by this or other studies, we drew no conclusions about how different modalities compare in the assessment of brain metastases.

## Key Question 2 Comparative Effectiveness

In this section, we address the following KQ:

KQ2: When used for the pretreatment staging of SCLC, what is the comparative effectiveness of imaging tests (MDCT, PET/CT, MRI, PET/MRI, EBUS, EUS, bone scintigraphy) on later outcomes?

No studies were included for this question.

## Key Question 3 Factors Associated with Comparative Outcomes

In this section, we address the following KQ:

KQ3. To what extent are the following factors associated with the comparative accuracy or effectiveness of imaging tests (MDCT, PET/CT, MRI, PET/MRI, EBUS, EUS, bone scintigraphy) when used for the pretreatment staging of SCLC?

No studies were included for this question. No studies had been excluded due to the fact that we required such comparisons to be planned in advance.