# References

1 American Cancer Society (ACS). Cancer facts & figures 2015. Atlanta, GA. American Cancer Society (ACS). 2015. 56 p.
2 SEER Cancer Statistics Review, 1975-2011. Bethesda, MD. National Cancer Institute. 31 p.
3 American Cancer Society. Cancer prevention & early detection facts & figures 2013. Atlanta (GA). American Cancer Society. 2013. 65 p.
4 National Cancer Institute (NCI). Small cell lung cancer treatment (PDQ) health professional version. Bethesda, MD. National Cancer Institute (NCI), National Institutes of Health (NIH). 2014. Feb. 21. http://www.cancer.gov/cancertopics/pdq/treatment/small-cell-lung/healthprofessional/page1. 2014 Jun 11.
5 Shepherd FA, Crowley J, Van Houtte P, et al. The International Association for the Study of Lung Cancer Lung Cancer Staging Project: proposals regarding the clinical staging of small cell lung cancer in the forthcoming (seventh) edition of the tumor, node, metastasis classification for lung cancer. J Thorac Oncol. Dec. 2007;2(12):1067-77. [pmid: 18090577].
6 Kalemkerian GP, Akerley W, Bogner P, et al. Small cell lung cancer. JNCCN J Natl Compr Canc Netw. Jan. 1. 2013;11(1):78-98. [pmid: 23307984].
7 Micke P, Faldum A, Metz T, et al. Staging small cell lung cancer: Veterans Administration Lung Study Group versus International Association for the Study of Lung Cancer--what limits limited disease?. Lung Cancer. Sep. 2002;37(3):271-6. [pmid: 12234695].
8 Trends in lung cancer morbidity and mortality. Chicago, IL. American Lung Association. 2012. Apr. 34 p.
9 Glisson BS, Byers LA. Pathobiology and staging of small cell carcinoma of the lung. Lilenbaum RC, Nicholson A, Jett JR, editors. UptoDate. Waltham, MA. UptoDate. 2013. May. 07. http://www.uptodate.com/contents/pathobiology-and-staging-of-small-cell-carcinoma-of-the-lung?source=search_result&search=sclc&selectedTitle=2%7E150#H7. 2014 Jun 12.
10 Jett JR, Schild SE, Kesler KA, et al. Treatment of small cell lung cancer: diagnosis and management of lung cancer, 3rd ed: American College of Chest Physicians evidence-based clinical practice guidelines. Chest. May. 2013;143(5 Suppl):e400S-19S. [pmid: 23649448].
11 Hillner BE, Tosteson AN, Song Y, et al. Growth in the use of PET for six cancer types after coverage by medicare: additive or replacement?. J Am Coll Radiol. Jan. 2012;9(1):33-41. [pmid: 22221634].
12 2014 PET market summary report. Greenbelt, MD. IMV Info. 2014. http://www.imvinfo.com/index.aspx?sec=pet&sub=dis&itemid=200083. 2015 May 15.
13 New IMV survey shows slowing growth in PET medical imaging scans. Des Plaines (IL). PRWeb. 2012. Aug. 12. http://www.prweb.com/releases/2012/8/prweb9820176.htm. 2015 May 18.
14 Lang K, Huang H, Lee DW, et al. National trends in advanced outpatient diagnostic imaging utilization: an analysis of the medical expenditure panel survey, 2000-2009. BMC Med Imag. 2013;13:40. [pmid: 24279724].
15 Ravenel JG, Rosenzweig KE, Kirsch J, et al. ACR appropriateness criteria non-invasive clinical staging of bronchogenic carcinoma. J Am Coll Radiol. Sep. 2014;11(9):849-56. [pmid: 25086958].
16 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(1):25. [pmid: 14606960].
17 Harbord RM, Deeks JJ, Egger M, et al. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. Apr. 2007;8(2):239-51. [pmid: 16698768].
18 STATA statistics/data analysis. MP parallel edition. Ver 10.0. College Station (TX). StataCorp. 1984-2007. Single user Stata for Windows. http://www.stata.com.
19 Trikalinos TA, Hoaglin DC, Small KM, et al. Evaluating practices and developing tools for comparative effectiveness reviews of diagnostic test accuracy: methods for the joint meta-analysis of multiple tests. Methods research report. (Prepared by the Tufts Evidence-based Practice Center, under Contract No. 290-2007-10055-I.) AHRQ publication no. 12(13)-EHC151-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2013. Jan. 49 p. http://effectivehealthcare.ahrq.gov/ehc/products/291/1380/Methods%20Report_Evaluating-Practices-Developing-Tools_Final_01-14-2013.pdf.
20 Singh S, Chang S, Matchar DB, et al. Grading a body of evidence on diagnostic tests. (AHRQ publication no. 12-EHC079-EF). Chapter 7 of Methods guide for medical test reviews (AHRQ publication no. 12-EHC017). Rockville, MD. Agency for Healthcare Research and Quality. 2012. Jun. 1. http://effectivehealthcare.ahrq.gov/ehc/products/246/558/Methods-Guide-for-Medical-Test-Reviews_Full-Guide_20120530.pdf.
21 Palomar Munoz A, Garcia Vicente AM, Bellon Guardia ME, et al. Is a selective brain (18)F-FDG PET/CT study profitable in patients with small cell lung cancer?. Rev Esp Med Nucl Imagen Mol. May. 2012;31(3):124-9. [pmid: 21722995].
22 Brink I, Schumacher T, Mix M, et al. Impact of [(18)F]FDG-PET on the primary staging of small-cell lung cancer. Eur J Nucl Med Mol Imaging. Dec. 2004;31(12):1614-20. [pmid: 15258700].
23 Lee JW, Lee SM, Lee HS, et al. Comparison of diagnostic ability between (99m)Tc-MDP bone scan and 18F-FDG PET/CT for bone metastasis in patients with small cell lung cancer. Ann Nucl Med. Oct. 2012;26(8):627-33. [pmid: 22729551].
24 Sohn BS, Lee DH, Kim EK, et al. The role of integrated 18F-FDG PET-CT as a staging tool for limited-stage small cell lung cancer: a retrospective study. Onkologie. Aug. 2012;35(7):432-8. [pmid: 22846975].
25 Fischer BM, Mortensen J, Langer SW, et al. A prospective study of PET/CT in initial staging of small-cell lung cancer: comparison with CT, bone scintigraphy and bone marrow analysis. Ann Oncol. Feb. 2007;18(2):338-45. [pmid: 17060487].
26 Wada H, Nakajima T, Yasufuku K, et al. Lymph node staging by endobronchial ultrasound-guided transbronchial needle aspiration in patients with small cell lung cancer. Ann Thorac Surg. Jul. 2010;90(1):229-34. [pmid: 20609781].
27 Shen YY, Shiau YC, Wang JJ, et al. Whole-body 18F-2-deoxyglucose positron emission tomography in primary staging small cell lung cancer. Anticancer Res. 2002;22(2):1257-64. [pmid: 12168935].
28 Samson DJ, Seidenfeld J, Simon GR, et al. Evidence for management of small cell lung cancer: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. Sep. 2007;132(3 Suppl):314S-23S. [pmid: 17873177].
29 Lu YY, Chen JH, Liang JA, et al. 18F-FDG PET or PET/CT for detecting extensive disease in small-cell lung cancer: a systematic review and meta-analysis. Nucl Med Commun. Jul. 2014;35(7):697-703. [pmid: 24694775].
30 Ruben JD, Ball DL. The efficacy of PET staging for small-cell lung cancer: a systematic review and cost analysis in the Australian setting. J Thorac Oncol. Jun. 2012;7(6):1015-20. [pmid: 22534816].
31 Ravenel JG. Evidence-based imaging in lung cancer: a systematic review. J Thorac Imaging. Sep. 2012;27(5):315-24. [pmid: 22914125].
32 Hellwig D, Baum RP, Kirsch C. FDG-PET, PET/CT and conventional nuclear medicine procedures in the evaluation of lung cancer: a systematic review. Nuklearmedizin. 2009;48(2):59-69. [pmid: 19333516].
33 Ung YC, Maziak DE, Vanderveen JA, et al. 18Fluorodeoxyglucose positron emission tomography in the diagnosis and staging of lung cancer: a systematic review. J Natl Cancer Inst. Dec. 5. 2007;99(23):1753-67. [pmid: 18042932].
34 Facey F, Bradbury I, Laking G, et al. Overview of the clinical effectiveness of positron emission tomography imaging in selected cancers. Health Technol Assess. Oct. 2007;11(44):iii-85. [pmid: 17999839].
35 Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review (CSR) 1975-2011. Bethesda, MD. National Cancer Institute (NCI). 2014. Dec. 17. http://seer.cancer.gov/csr/1975_2011/. 2015 Feb 2.
36 American College of Radiology (ACR), Society for Pediatric Radiology (SPR). ACR-SPR practice parameter for performing FDG-PET in oncology. Reston, VA. American College of Radiology (ACR). 2014. 14 p. http://www.acr.org/∼/media/71B746780F934F6D8A1BA5CCA5167EDB.pdf.
37 American College of Radiology (ACR), Society for Pediatric Radiology (SPR). ACR-SPR practice parameter for the performance of skeletal scintigraphy (bone scan). Reston, VA. American College of Radiology (ACR). 2014. 9 p. http://www.acr.org/∼/media/839771405B9A43F7AF2D2A9982D81083.pdf.
38 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Methods Future Research Needs Report No. 2 (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. http://www.effectivehealthcare.ahrq.gov/ehc/products/201/735/FRN2_Frameworks_20110726.pdf.