# Methods

## Topic Development and Refinement

Initially a panel of key informants gave input on the Key Questions (KQs) to be examined; these KQs were posted on AHRQ's Web site for public comment between September 4, 2014, and September 24, 2014, and revised as needed. We then drafted a protocol for the Comparative Effectiveness Review and recruited a panel of technical experts to provide high-level content and methodologic expertise throughout the development of the review. The protocol is registered with PROSPERO (http://www.crd.york.ac.uk/PROSPERO/) as review # CRD42014015429.

## Literature Search Strategy

Literature searches were performed by medical librarians within the Evidence-Based Practice Center (EPC) Information Center; searches followed established systematic review methods. We searched the following databases using controlled vocabulary and text words: EMBASE, MEDLINE, PubMed, and the Cochrane Library. The following grey literature sources were searched using text words: ClinicalTrials.gov, Centers for Medicare & Medicaid Medicare Coverage Database, ECRI Institute Health Devices, Healthcare Standards, Internet, Medscape, National Guideline Clearinghouse™, and the U.S. Food and Drug Administration. The search strategy appears in Appendix A. The last search date was June 15, 2015.

Literature screening was performed by experienced research analysts using the database Distiller SR (Evidence Partners, Ottawa, Canada). Literature search results were initially screened for relevancy. Relevant abstracts were screened against the study inclusion criteria in duplicate. Studies that appeared to meet the study inclusion criteria were retrieved in full and screened in duplicate against the study inclusion criteria. All disagreements were resolved by consensus discussion among the two original screeners or a third screener.

## Study Selection

Our inclusion criteria are listed below in five categories: Publication criteria, study design criteria, patient criteria, test criteria, and data criteria.

### Publication Criteria

a. Full-length articles: The article must have been published as a full-length, peer-reviewed study.
b. Redundancy: To avoid double-counting patients, in instances in which several reports of the same or overlapping groups of patients were available, only outcome data based on the larger number of patients were included. However, we included data from publications with lower numbers of patients when either (a) a publication with lower patient enrollment reported an included outcome that was not reported by other publications of that study, or (b) a publication with lower patient enrollment reported longer followup data for an outcome.
c. Publication date: We included studies published since January 1, 2000. Technical progress in all the imaging modalities under consideration means that older studies are likely to underestimate the diagnostic performance of these modalities.
d. We initially had excluded studies not published in English, but after identifying a relatively low number of qualifying studies, we removed that requirement.

### Study Design Criteria

a. The study must have provided data on at least one test of interest. Ideally, studies would directly compare two or more tests (or test strategies). The comparison may also be addressed indirectly by comparing one set of studies of one imaging test and another set of studies of another imaging test (e.g., a set of studies reporting the accuracy of MRI at mediastinal node staging of SCLC compared with a separate set of studies reporting the accuracy of CT at mediastinal node staging of SCLC). This is an indirect comparison of modalities, so conclusions based on it are weaker.
b. For comparisons of variants of a given modality, and studies of patient factors or tumor characteristics for KQ3, the comparison must have been planned in advance.
c. For comparative accuracy (KQ1), the study must have compared both tests to a common reference standard. The reference standard must not have been defined by either imaging test being assessed. We set no requirements on what the reference standard must be (e.g., biopsy, clinical followup).
d. For comparative effectiveness (KQ2), some patients must have received one of the imaging tests (or test strategies), and a separate group of patients must have received a different imaging test (or test strategy). This design permits a comparison of how the choice of test (or test strategy) may influence choice of treatment, timeliness of treatment, harms due to over-/undertreatment, survival, and/or quality of life.
e. For the influence of patient factors or tumor characteristics (KQ3), the study must have reported comparative accuracy data stratified by patient/tumor factor or comparative- effectiveness data stratified by patient/tumor factor.

### Patient Criteria

a. The study reported data specifically on patients undergoing staging for SCLC, or if the data were combined with other types of patients, at least 85 percent of the patients in the reported data were undergoing staging for SCLC.
b. Adults. At least 85 percent of patients must have been aged 18 years or older, or data must have been reported separately for those aged 18 years or older.
c. Studies of staging for primary SCLC were included. Studies of staging for recurrent SCLC were excluded.
d. Data on imaging tests performed after any form of treatment (e.g., chemotherapy) were excluded, but pretreatment imaging data were considered.

### Test Criteria

a. Type of test. Only studies of the imaging tests of interest were included (listed in the key questions above). Studies of CT that did not explicitly state (or we could not determine) whether they used CT or MDCT were assumed to be MDCT. Given our publication date of 2000 and later, we believe it is safe to assume that CT performed in such studies was MDCT.
b. PET/CT must have been based on a dedicated PET/CT machine. We excluded studies in which PET and CT were acquired separately and later fused for the following reasons. First, methods for image fusion can vary widely. Since accurate staging relies on precise localization of the margin of tumor or metastasis, inclusion of less precise means of combining PET and CT images would underestimate the performance of PET/CT. Second, image fusion is no longer the state of the art in PET/CT, and since this report is intended to guide use of imaging technologies in the future, it should reflect the technology presently in use.

### Data Criteria

a. The study must have reported data pertaining to one of the outcomes of interest (see the KQs).
  ○ For test concordance (part of KQ1), this means reporting the number of patients for whom the two tests provided the same or different results.
  ○ For comparative accuracy (part of KQ1), this means reporting enough information to calculate both sensitivity and specificity, along with their corresponding confidence intervals (CIs).
  ○ For comparative choice of treatment (part of KQ2), this means reporting the percentage of patients who received a specific treatment choice for one test or test strategy compared with another test or test strategy.
  ○ For comparative timeliness of treatment (part of KQ2), this means reporting the duration of time elapsed before the initiation of treatment for one test or test strategy compared with another test or test strategy.
  ○ For comparative tumor response (part of KQ2), this means reporting the percentage of patients whose tumor responded to treatment for one test or test strategy compared with another test or test strategy.
  ○ For comparative harms of overtreatment or undertreatment (part of KQ2), this means reporting the percentage of patients who were overtreated or undertreated (based on authors' judgment), for one test/test strategy compared with another test/test strategy.
  ○ For comparative survival (part of KQ2), this means either reporting median survival after each imaging test or test strategy, or mortality rates at a given time point, or other patient survival such as a hazard ratio.
  ○ For quality of life (part of KQ2), this means reporting data on a previously tested quality-of-life instrument (such as the Short-Form 36) separately for each imaging test or test strategy.
  ○ For patient factors or tumor characteristics (KQ3), this means reporting data on whether such factors are associated with either comparative accuracy and/or comparative effectiveness.
b. Regarding the minimum patient enrollment, we required data on at least 10 patients per imaging test or test strategy.
c. For all KQs, the reported data must have included at least 50 percent of the patients who had initially enrolled in the study.

## Data Extraction and Management

Abstraction forms were constructed in Microsoft Excel, and the data were abstracted into these forms. Elements abstracted included general study characteristics (e.g., country, setting, study design, enrolled N, funding source), patient characteristics (e.g., enrollment criteria, age, sex, final diagnoses including tumor characteristics), details of the imaging methodology (e.g., radiotracer, timing of test, readers, elapsed time between imaging tests, what reference standard was used), risk-of-bias items, and outcome data. Outcome data were dual abstracted to ensure accuracy, with discrepancies resolved by consensus. Multiple publications of the same study were grouped as a single study. We identified these by examining author names, study centers, patient enrollment dates, and imaging technologies.

## Risk-of-Bias Evaluation

For studies directly comparing two or more imaging tests, we applied a set of nine items involving risk of bias (listed in Appendix D). We devised these items after considering the QUADAS-2 instrument,16 as well as additional issues that specifically address bias in the comparison of imaging tests. For studies of only a single imaging test of interest, the critical issue was whether the study's quantitative estimates could be biased, and we used 14 items, which are listed in Appendix D (also based on considering the QUADAS-2 instrument.)16 Two analysts independently assessed each study, with disagreements resolved by consensus. Once all individual items were resolved, two analysts assigned each study to a risk-of-bias category (low, moderate, or high), with disagreements resolved by consensus.

## Data Synthesis

Decisions about whether meta-analysis is appropriate depended on the judged clinical homogeneity of the different study populations, imaging and treatment protocols, and outcomes. When meta-analysis was not appropriate (due to limitations of reported data), the data were synthesized using a descriptive narrative review approach.

For KQ1 on comparative accuracy, we had planned to synthesize sensitivity and specificity of each test on its own using a bivariate mixed-effects binomial regression model as described by Harbord et al.17 If appropriate, all such analyses were performed using the STATA 13 statistical software package (StataCorp, College Station, Texas) using the “midas” command.18 To compare two tests, we used the EPC methods described in equation 39 of Trikalinos et al. (2013).19

For KQ2 on comparative effectiveness, if meta-analysis had been appropriate, we planned to compute effect sizes and measures of variance using standard methods and to perform Knapp-Hartung random-effects meta-analysis. If heterogeneity was encountered, we planned to use meta-regression to explore possible causes.

For KQ3 on patient factors and tumor characteristics, we planned to calculate for each study the association between a patient factor (e.g., age) and comparative accuracy or effectiveness (e.g., the difference in sensitivity between two tests). If appropriate, we would have meta-analyzed the correlations using standard techniques and Knapp-Hartung standard errors.

We refrained from specifying a numerical threshold for clinical significance of results in either sensitivity or specificity in this report, for two reasons. First, there is no agreement in the field on what threshold is appropriate. Second, clinical importance is a clinical judgment that is sensitive to numerous clinicians and patient factors.

## Grading the Body of Evidence for Each Outcome

We determined the strength-of-evidence grade for the following outcomes:

- Comparative sensitivity (KQ1)
- Comparative specificity (KQ1)
- Comparative timeliness of treatment (KQ2)
- Comparative choice of treatment (KQ2)
- Comparative tumor response (KQ2)
- Comparative survival (KQ2)
- Comparative quality of life (KQ2)
- Comparative harms due to overtreatment (KQ2)
- Comparative harms due to undertreatment (KQ2)
- Association between age and comparative accuracy (KQ3)
- Association between body habitus and comparative accuracy (KQ3)
- Association between tumor characteristics and comparative accuracy (KQ3)
- Association between age and comparative effectiveness (KQ3)
- Association between body habitus and comparative effectiveness (KQ3)
- Association between tumor characteristics and comparative effectiveness (KQ3)

We determined each grade separately for each modality comparison (e.g., CT vs. PET/CT). For accuracy, we examined both sensitivity and specificity. We did not separately grade other accuracy-related outcomes (i.e., predictive values or likelihood ratios) because these grades would be redundant with the grades for accuracy since our estimates would be based on the same studies and the same quantitative syntheses.

We used the EPC system for grading evidence on diagnostic tests as described in the EPC guidance chapter by Singh et al. (2012).20 This system uses up to eight domains as inputs (study limitations, directness, consistency, precision, publication bias, dose-response association, all plausible confounders would reduce the effect, and strength of association). The output is a grade for the strength of evidence: high, moderate, low, or insufficient (see Table 1). This grade is provided separately for each outcome of each comparison of each KQ. The grade refers to our confidence in the direction of effect when comparing two imaging technologies, not to the magnitude of the difference between technologies.

Table 1 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, that is, another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Source: Singh et al. (2012).20

A grade of Insufficient was given when the evidence did not permit a conclusion for the outcome of interest and the two modalities being compared. For example, if the outcome is test accuracy and the comparison is CT to PET/CT, the evidence may permit a conclusion that either 1) CT is more accurate, 2) PET/CT is more accurate, or 3) the tests are similarly accurate. If none of these three conclusions could be drawn (as judged by three independent analysts), then evidence was graded Insufficient for that comparison. In order to conclude that two modalities differ for an outcome, we used a p value less than 0.05 two-tailed (i.e., the standard value for alpha). In order to conclude that two modalities are approximately equivalent for an outcome, we used the independent judgment of three analysts (with disagreements resolved by discussion).

If the evidence was sufficient to permit a conclusion, then the grade was deemed high, moderate, or low. The grade was provided by three independent raters, with discrepancies resolved by consensus. Specifically, each of three analysts considered all strength of evidence domains listed earlier, and decided on a rating for each evidence base, without knowledge of the ratings of the other two analysts. If any of the three ratings differed, a single rating was reached based on consensus discussion.

Below, we discuss the eight domains and how they were considered as inputs to the grade:

Study Limitations (see the section Assessment of Methodological Risk of Bias of Individual Studies above). If the evidence permits a conclusion, and all else being equal, a set of studies with low limitations yield a higher strength of evidence grade than a set of studies with moderate or high limitations.

Directness. Our initial inclusion criteria required direct comparisons between modalities, but we subsequently included studies of single modalities. Indirect comparisons meant downgrades to the strength of the evidence. This is because different sets of studies may have enrolled slightly different types of patients or used slightly different reference standards for determining patients' true SCLC stages.

Consistency. Consistency among study results was judged based on whether the studies' findings suggest the same direction of effect (e.g., that one test is better than another).

Precision. Precision of the combined study results was judged by an assessment of the meta-analytic CI, or if meta-analysis was not performed, by an assessment of the precision of the individual studies (based on CIs or numbers of patients).

Reporting bias. This was addressed by noting the presence of abstracts or ClinicalTrials.gov entries describing studies that did not subsequently appear as full published articles. If many such studies exist, this tends to decrease the strength of the evidence. We also considered the funding sources of the studies in determining the risk of reporting bias.

Dose-response association. This factor is used for studies of treatments and is not relevant for this topic.

All plausible confounders would reduce the effect. This domain acknowledged that a set of studies may be biased against finding a difference between two modalities, and yet the studies still found an important difference. Thus, if the studies had controlled for the confounders, the effect would have been even larger. This domain will generally increase the strength-of-evidence grade.

Strength of association. While the Cochrane Collaboration and other reviewers have objective criteria for defining this domain in the context of treatments, no such criteria exist for diagnostic test accuracy. Therefore, this domain was judged by EPC team members based on whether the strength of the effect (e.g., the extent of difference in accuracy between two tests) is so large that the potential study biases could not explain it. If true, this domain will generally increase the strength-of-evidence grade.

## Peer Review and Public Commentary

Peer reviewers were invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer-review comments on the preliminary draft have been be considered by the EPC in preparation of the final version of the report. Dispositions of the peer- review comments are documented and will be published 3 months after publication of the evidence report.