# Introduction

## Background

### Epidemiology

Lung cancer is the leading cause of cancer-related mortality, accounting for about 27 percent of cancer deaths in the United States in 2015.^1^ In 2011 (the most recent year for which U.S. prevalence data are available), an estimated 402,236 people in the United States were living with lung cancer.2 In 2015, an estimated 221,200 new cases of lung cancer will be diagnosed.1 Small cell lung cancer (SCLC) is an aggressive subset of lung cancer that is characterized by rapid doubling time, high growth fraction, and early development of metastatic disease. This histologic subset of lung cancer is primarily seen in smokers3 and composes approximately 15 percent of all lung cancers.4 Despite advances in diagnosis, treatment, and management of lung cancer, the 5-year survival rate for SCLC remains dismal at about 6 percent.1

The majority of the patients with SCLC (approximately 70 percent) present with metastatic disease, and about 20 to 30 percent have brain metastases at presentation.5,6 Patients with metastatic SCLC have a poor prognosis, with a median survival of only 9–11 months despite aggressive initial treatment. The high rate of distant failure after completion of treatment suggests that systemic micrometastatic spread is common at the time of initial diagnosis but poorly captured by available imaging and surveillance. Platinum-based chemotherapy in combination with etoposide has been the standard of care for over 25 years, with virtually no headway in research. As we pursue novel therapies for this disease, it is imperative that we concurrently pursue strategies that enable us to diagnose and stage these patients' disease in a timely fashion, to guide selection of suitable patients for specific therapy, and to predict clinical outcome.

### Diagnosis

SCLC remains a pathologic diagnosis requiring tissue obtained via biopsy. Most cases are diagnosed after patients become symptomatic with cough, shortness of breath, weight loss, or hemoptysis. Imaging, often performed as a first diagnostic step usually reveals a suspicious nodule or mass. Thus, while imaging plays a key role in the diagnostic workup, these tests cannot be used to definitively distinguish SCLC from other types of lung cancer or from other noncancerous conditions (i.e., differential diagnosis). Multidetector computed tomography (MDCT) is widely used as the initial imaging test to determine whether, where, and how to perform a biopsy. Biopsy may be performed via one of several methods (e.g., bronchoscopy, CT-guided percutaneous biopsy, endobronchial ultrasound [EBUS], endoscopic ultrasound [EUS]), depending on the location and size of the mass and patient factors like body mass index and presence of other comorbidities. In a minority of patients, SCLC can also be detected incidentally. In these asymptomatic patients, a chest x-ray or chest CT ordered for other reasons may reveal a nodule or suspicious mass requiring further investigation.

### Staging

Staging involves determining the extent of disease and to direct the choice and goals of therapy. SCLC is typically staged using one of two systems, with the Veterans Administration Lung Study Group (VALSG) system or the less commonly used American Joint Committee on Cancer (AJCC) TNM (T stands for primary tumor, N stands for regional lymph nodes, and M stands for distant metastasis system):

- The VALSG system7 classifies SCLC as either “limited stage” or “extensive stage” disease with the following definitions:
  ○ Limited stage disease (LD): Cancer is confined to one hemithorax and may be present in the regional lymph nodes or in ipsilateral supraclavicular nodes, all of which can be encompassed in a safe radiotherapy field.
  ○ Extensive stage disease (ED): Cancer that cannot be classified as LD, such as when contralateral hilar or supraclavicular nodes, malignant pericardial or pleural effusions, or distant metastatic disease are present.
- The AJCC TNM system is used less commonly for SCLC but often used for other types of cancer. Lung cancers are classified based on the size of the main tumor, whether it has locally invaded other organs/tissues, spread to lymph nodes, and metastasized to other parts of the body. This information is used to assign a stage between I and IV. A higher stage represents a more extensive spread.

The National Cancer Institute reported that from 1975–2008, about 70 percent of SCLC cases presented with ED, another 21 percent had regional spread such as mediastinal nodal involvement, and only 5 percent were localized (the other 4 percent were unstaged).8 The most common sites of metastases for SCLC are liver, adrenal glands, bone, bone marrow, and brain.9

Some debate exists about which system should be used. The International Association for the Study of Lung Cancer recommended in 2007 that clinicians use the AJCC system.5 This recommendation was based on an analysis of more than 8,000 patients with SCLC, which found that both tumor stage and lymph node status were associated with survival. By contrast, others have noted that since approximately two-thirds of patients with SCLC present with advanced disease,9 the simpler VALSG system is sufficient to guide treatment. A 2013 guideline from the American College of Chest Physicians recommended that SCLC be staged using both systems.10 Staging involves evaluating disease in the abdomen, pelvis, bones, and brain.

More than two-thirds of patients with SCLC present with extensive stage and have a poor prognosis with a median survival of only 9–11 months. Despite initial response to chemotherapy, most patients become refractory to therapy or relapse shortly thereafter. Platinum-based chemotherapy in combination with etoposide has been the standard of care for over 25 years, with virtually no headway in research. Patients with LD are treated more aggressively with concurrent chemotherapy and radiation with curative intent. After completion of first-line therapy, prophylactic cranial irradiation (i.e., without evidence of metastases in) has been demonstrated to prolong survival in both LD and ED.

“Standard” staging of SCLC is not a precisely defined term, but may involve numerous investigations including history, physical exam, chest x-ray, chest CT, bone scan, bone marrow aspiration, and/or MRI or CT of the brain. Accurate staging of patients is essential to select the optimal treatment plan that will maximize a patient's chances of survival. On the one hand, overstaging risks denying the patient potentially life-saving treatment, while understaging risks subjecting the patient to unnecessary risk of complications from more aggressive treatment. Given the rapid progression of SCLC, timely diagnosis and staging is important; performing potentially unnecessary tests during the diagnostic and staging process could delay treatment initiation, compromising treatment efficacy.

### Imaging Tests

This section discusses several types of imaging tests used to stage SCLC.

#### Multidetector Computed Tomography

CT scanners acquire cross-sectional images (slices) of the body using x-rays. While early CT scanners could acquire only one slice at a time, current state of the art MDCT scanners can acquire as many as 640 slices at a time. These images can be reconstructed for viewing in any desired plane (multiplanar reconstruction). Since single-detector CT scanners are now obsolete, our report excluded clinical studies using single-detector CT.

Intravenous injection of a radiopaque contrast agent should be performed whenever not contraindicated in CT examinations for lung cancer staging. Contrast-enhanced CT can provide additional information about the characteristics of a mass seen in the unenhanced scan, which may facilitate characterization of the mass as probably malignant or probably benign.

MDCT has general strengths of widespread availability, high spatial resolution, and high speed and is particularly useful for evaluating the lungs, airways, bowel, and cortical bone. However, because it is a structural imaging modality, it may not detect early metastatic disease involving sites such as the bone marrow or lymph nodes and is not always able to characterize lesions as benign or malignant based on their morphologic properties. In addition, some patients cannot receive iodinated contrast material due to renal insufficiency, limiting evaluation for presence of hilar lymphadenopathy, vascular abnormalities, and lesion characterization. The major risks of iodinated contrast material include contrast allergic-like reactions (most often mild and self-limited in nature, less commonly moderate or severe requiring therapeutic intervention), contrast-induced nephropathy (most commonly in patients with pre-existing renal insufficiency), and extravasation injury (occurring in up to approximately 1 percent of scans, most often in the superficial soft tissues and typically self-limited, rarely leading to compartment syndrome). One potential concern about MDCT is patient exposure to ionizing radiation. However, given the poor prognosis for SCLC when it is typically diagnosed, this concern is relatively unimportant.

MDCT of the chest is often one of the first tests performed to diagnose possible lung cancer. For staging SCLC, additional MDCT images are taken of the abdomen, pelvis, or head to detect distant metastases.

#### Positron Emission Tomography/Computed Tomography

Positron emission tomography (PET) is an imaging modality that localizes the uptake of a positron-emitting radioisotope in the body. [^18^F]-fluorodeoxyglucose (FDG) is the most commonly used PET radiotracer. Because FDG-PET identifies anatomic sites that harbor metabolically active malignant areas, FDG-PET helps distinguish malignant tumors from benign nodules or masses. FDG-PET can also detect metabolically active metastases that may not be detected by structural imaging modalities (e.g., MDCT, magnetic resonance imaging [MRI]).

Because PET images lack anatomic detail, combined PET/CT scanners have been developed so the molecular information from PET can be anatomically localized with CT. As of 2015, PET without a concurrent CT is rarely performed. Therefore, our analysis of PET data included only studies in which patients were imaged using a combined PET/CT scanner.

FDG-PET/CT is sometimes available (but less often than CT) and has high contrast resolution. Because it is quantitative, measurements of the specific uptake in individual lesions or global disease burden may be performed. However, FDG uptake within a lesion does not always indicate malignancy. Infectious and no-infectious inflammatory lesions may also demonstrate FDG uptake, potentially leading to false-positive results. Furthermore, some small or indolent malignant lesions (such as lung adenocarcinoma in situ or carcinoid tumor) may have little to no radiotracer uptake, potentially leading to false-negative results. Lastly, patients with elevated serum glucose levels (greater than 200 mg/dl) do not generally undergo FDG-PET/CT, given the potential for false-negative results. Again, one potential concern about FDG-PET/CT is patient exposure to ionizing radiation. However, given the poor prognosis for SCLC when it is typically diagnosed, this concern is relatively unimportant.

#### Magnetic Resonance Imaging

MRI uses magnetic fields and radio waves to generate three-dimensional images of the body. Unlike PET and CT, MRI does not use ionizing radiation and thus poses no radiation-related risks to the patient. Paramagnetic contrast agents can be administered during the MRI examination to give additional information about the nature of a mass in the same way that iodinated contrast agents can enhance a CT scan.

MRI is a structural and functional imaging technique with widespread availability, high spatial resolution, and high soft-tissue contrast resolution; this imaging modality is particularly useful for detecting and characterizing lesions within tissues even when subcentimeter in size, as well as for evaluating the internal architecture of organs/tissues such as the brain, spinal cord, breasts, bone marrow, muscles, tendons, ligaments, cartilage, and other solid organs. Also, functional imaging capabilities such as diffusion-weighted imaging and magnetic resonance spectroscopy may be used to improve diagnostic accuracy. MRI examinations take longer to perform and generally cost more than MDCT, and some patients with implanted electronic or metallic devices or with claustrophobia cannot undergo MRI.

#### Positron Emission Tomography/Magnetic Resonance Imaging

Combined PET and MRI scanners are a recent technical development: they promise the sensitivity of PET combined with the anatomic detail of MRI. PET/MRI is a hybrid molecular/structural imaging technique that possesses the general strengths provided by PET and MRI listed above, along with a lower radiation dose compared with PET/CT, and potentially improved PET quantification and motion compensation. However, in addition to the weaknesses of PET and MRI listed above, it is not widely available; not currently reimbursed for by insurance companies; more expensive in terms of instrumentation than PET/CT, MDCT, and MRI; involves longer examination times; and requires additional training of personnel in terms of safety, protocol optimization, and study interpretation.

#### Endobronchial Ultrasound and Endoscopic Ultrasound

EBUS is a bronchoscopic technique utilizing ultrasonography to visualize structures within and adjacent to the airway wall, whereas EUS is an endoscopic technique that uses ultrasonography to visualize structures within and adjacent to the esophageal wall. These techniques are minimally invasive and can be performed on an outpatient basis. Patients with suspected spread of lung cancer to mediastinal lymph nodes may undergo preoperative (or intraoperative) EBUS-guided biopsy and/or EUS-guided biopsy for real-time, minimally invasive pathologic mediastinal N staging, even for lymph nodes that are subcentimeter in size or located near blood vessels. EBUS is used to sample hilar and mediastinal lymph nodes that surround the tracheal bronchial tree, whereas EUS can be used to sample other lymph nodes in proximity to the esophagus. These techniques are used during the staging workup of patients with lung cancer, as accurate N staging is important to determine optimal therapy.

EBUS-guided transbronchial needle aspiration (EBUS-TBNA) is generally performed if suspected lymph nodes are in the anterior or superior mediastinum and appear to be accessible based on prior cross-sectional imaging. EUS-guided fine-needle aspiration (EUS-FNA) may initially be used for nodes that are paraesophageal or subaortic in location or located in the posterior or inferior mediastinum. EBUS-TBNA can also be used to sample hilar lymph nodes or biopsy the left adrenal gland, left hepatic lobe and celiac axis lymph nodes.

EBUS can also be used to inform T staging of lung cancer and may potentially improve the determination of the distance between the tumor and the carina, which is a determinant of T stage. Furthermore, it may help distinguish between airway invasion by tumor compared with airway compression by tumor. EBUS is also used for diagnostic evaluation of endobronchial lesions, peripherally located pulmonary nodules, and mediastinal lesions, as well as for guiding endobronchial therapy.

#### Bone Scintigraphy

Bone scintigraphy uses a gamma camera or SPECT (Single Photon Emission Computed Tomography) scanner to create two-dimensional images of the distribution of a radiotracer, typically technetium-99m methylene diphosphonate (Tc99m-MDP). Scintigraphy of radiotracers that localize to the bones is useful in cancer staging because areas of high radiotracer uptake could represent metastases; however, uptake occurs with other common conditions as well, meaning that false-positive findings are not unusual.

Bone scintigraphy is a two-dimensional molecular imaging technique with widespread availability, high contrast resolution, and relatively low cost compared with FDG-PET/CT. However, false-negative results can occur, particularly when lytic osseous lesions are present, as bone scintigraphy indirectly reveals sites of metabolic bone turnover in reaction to bone marrow metastatic disease rather than the metastatic lesions directly. False-positive results can also occur due to other nonmalignant conditions that lead to increased bone turnover, such as fractures and osteomyelitis. Also, this technique has only planar capability (compared with tomographic capability of the other imaging techniques described above), further limiting its diagnostic capability. Lastly, bone scintigraphy is less quantitative than PET/CT and does not allow evaluation of non-osseous structures of the body (in contrast to MDCT, MRI, and PET).

#### Test Utilization and Costs

Based on an evaluation of a 20 percent sample of Medicare fee-for-service claims from 2008, Hillner and colleagues calculated the combined annual imaging days per person-year (i.e., the average number of days imaging was performed each year per patient) in beneficiaries with cancer as 2.3 for CT, 0.49 for MRI, 0.70 for PET, and 0.13 for bone scintigraphy.11 The annual rates of imaging from 2004 to 2008 increased 0.5 percent for CT, 3.2 percent for MRI, and 18.0 percent for PET, and decreased 12.7 percent for bone scintigraphy. PET continues to grow rapidly with evidence that it is replacing bone scintigraphy without a decline in CT.11 Regarding PET or PET/CT, an estimated 1.62 million clinical PET and PET/CT scans were performed in 2014, representing a net decrease of about 13 percent compared with 2011.^12^ About 94 percent of all PET studies in 2012 were for cancer (19 percent for diagnosis, 38 percent for staging, 13 percent for treatment planning, and 30 percent for follow up).13 Regarding combined MRI/CT, utilization rates have increased from 64.3 to 109.1 per 1,000 person years from 2000 to 2009.^14^ However, growth has slowed in recent years, with an average annual decline in the imaging growth rate of 4.7 percent between 2000 and 2009.^14^

Regarding costs, we searched the CMS Web site (http://www.cms.gov/apps/physician-fee-schedule/search/search-criteria.aspx) for Medicare rates (national payment amounts, based on 2015 CPT codes and CMS.gov physician fee schedule) for specific procedures and found the following:

- CT chest with contrast: $229.55
- CT abdomen and pelvis with contrast: $312.50
- CT head/ brain wo contrast: $116.20
- FDG-PET/CT (skull base to thigh): $1523.19
- MRI chest w/wo contrast: $581.37
- MRI abdomen w/wo contrast: $508.43
- MRI pelvis w/wo contrast: $507.36
- MRI head (or brain) w/wo contrast: $378.28
- Bone scintigraphy: $261.37
- Bronchoscopy with EBUS/TBNA: $281.39

### Patient Subgroups of Particular Interest

We are unaware of patient factors that might differentially affect the accuracy of imaging modalities specifically for SCLC. As previously noted, performance of various imaging modalities may be affected by comorbidities such renal insufficiency, which potentially limits the use of contrast for MDCT. Generally speaking, body habitus may limit the diagnostic quality and accuracy for any imaging modality. Many scanners are unable to safely accommodate patients above a particular weight or girth. However, these are general patient considerations, not specific to the use of imaging for SCLC.

### Recent Guidance From Professional Societies and Need for Future Work

In 2014, the American College of Radiology (ACR) appropriateness criteria review gave the highest rating of “usually appropriate” (with regard to staging SCLC) to the following specific modalities: CT of the chest and abdomen with contrast, MRI of the head with and without contrast, and FDG-PET/CT from skull base to mid-thigh.15 Bone scintigraphy was rated as “may be appropriate” and considered unnecessary if PET/CT had been performed. ACR noted that PET/CT is often helpful in staging SCLC and may result in a change in staging in up to 17 percent of cases, mostly cases in which PET/CT detects extensive disease that was not detected by other modalities. It may also detect additional involved lymph nodes, leading to revisions in treatment plans for patients scheduled to receive radiotherapy. As PET/CT has already become frequently adopted as part of the SCLC staging process, it is important to establish whether evidence exists to support this practice.

Similarly, a 2013 guideline from the American College of Chest Physicians recommended that patients with either proven or suspected SCLC undergo CT of the chest and abdomen or CT of the chest extending through the liver and adrenal glands, as well as MRI of the brain and bone scintigraphy.10 Furthermore, in patients thought to have limited disease, the guideline suggested FDG-PET/CT imaging to improve detection of metastases (with the potential to increase the stage and change the treatment choice). However, the evidence underlying this recommendation of PET for potential upstaging is limited and considered weak. The last search date of the guideline was 2011; therefore, approximately 3.5 years of additional literature were available for our report (2012 through June 15, 2015 when searches were performed). A primary objective of this report is to update the evidence base by including more recent studies.

## Scope and Key Questions

### Key Questions

Key Question 1: What are the test concordance and comparative accuracy of imaging tests (MDCT, PET/CT, MRI, PET/MRI, EBUS, EUS, bone scintigraphy) for the pretreatment staging of SCLC?

a. Test concordance
b. Sensitivity
c. Specificity
d. Positive predictive value
e. Negative predictive value
f. Positive likelihood ratio
g. Negative likelihood ratio

Key Question 2: When used for the pretreatment staging of SCLC, what is the comparative effectiveness of imaging tests (MDCT, PET/CT, MRI, PET/MRI, EBUS, EUS, bone scintigraphy) on later outcomes?

a. Choice of treatment (e.g., surgery, chemotherapy, radiation)
b. Timeliness of treatment
c. Tumor response
d. Harms due to overtreatment or undertreatment
e. Survival
f. Quality of life

Key Question 3. To what extent are the following factors associated with the comparative accuracy or effectiveness of imaging tests (MDCT, PET/CT, MRI, PET/MRI, EBUS, EUS, bone scintigraphy) when used for the pretreatment staging of SCLC?

a. Comorbidities
b. Body habitus
c. Tumor characteristics

Note that two terms above, “accuracy” and “effectiveness”, are used as overarching labels for different sets of outcomes. The “accuracy” outcomes (which are part of Key Question 1), involve an accurate determination of the patient's stage, whereas the “effectiveness” outcomes (which are listed for Key Question 2), involve the post-staging outcomes such as clinical management and response to treatment. For comparing the effectiveness of two imaging modalities, we required that studies make direct comparisons between two or more modalities, whereas for accuracy, we included studies that only used one imaging modality. Our full list of inclusion criteria appear in the section below called “Study Selection”.

### Populations, Interventions, Comparators, and Outcomes

#### Populations

- Adult patients with known SCLC or combined SCLC who are undergoing imaging test(s) for staging and who have not yet received treatment.

#### Interventions

Imaging using one or more of the following tests:

- Multidetector computed tomography (MDCT)
- PET/CT
- MRI
- PET/MRI
- EBUS
- EUS-FNA
- Bone scintigraphy

#### Comparators

- Any direct comparisons of the imaging tests of interest
- Any combination of the imaging test of interest

#### Outcomes

- Test concordance
- Sensitivity
- Specificity
- Positive predictive value
- Negative predictive value
- Positive likelihood ratio
- Negative likelihood ratio
- Choice of treatment (e.g., surgery, chemotherapy, radiation)
- Timeliness of treatment
- Tumor response
- Harms due to overtreatment or undertreatment
- Survival
- Quality of life

### Conceptual Framework

The conceptual framework for this review appears in Figure 1. This figure depicts the key questions within the context of the PICOTS listed in the previous section. The figure shows that the populations of interest (patients with either SCLC or Combined SCLC) are staged using various imaging modalities, which leads to choices in patient management, leading (hopefully) to tumor response, and finally to patient-oriented outcomes of survival and quality of life. Key harms of interest are the harms due to overtreatment or undertreatment.

Figure 1 Conceptual framework

Chemo = chemotherapy; EBUS = endobronchial ultrasound; EUS = endoscopic ultrasound; KQ = Key Question; MDCT = multidetector computed tomography; MRI = magnetic resonance imaging; PET-CT = positron emission tomography/computed tomography; PET-MRI = positron emission tomography/magnetic resonance imaging; SCLC = small cell lung cancer; XRT = radiotherapy

Figure 1 depicts the conceptual framework for this review. This figure depicts the key questions within the context of the PICOTS. The figure show that the populations of interest (patients with either SCLC or Combined SCLC) are staged using various imaging modalities, which leads to choices in patient management, leading (hopefully) to tumor response and finally to patient-oriented outcomes of survival and quality of life. Key harms of interest are the harms due to overtreatment or undertreatment.

## Organization of This Report

In the remaining three chapters of this report, we present the methods for this systematic review, the results for each key question, and a discussion of the findings. Within the Results chapter, we provide the results of the literature searches and selection procedures, then the results for Key Question 1. The Discussion section provides an overview of our findings and how they relate to what is already known. In that section, we also discuss clinical and policy decisionmaking, the applicability of the evidence, limitations of our review as well as limitations of the evidence we reviewed, and any major gaps in existing research.