# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Frank C. Detterbeck, M.D., FACS, FCCP^*^
  * This member of the Technical Expert Panel also reviewed and commented on the draft report.
  Professor of Surgery and Chief, Thoracic Surgery
  Yale University
  New Haven, CT
- Gregory P. Kalemkerian, M.D.^*^
  Professor of Medicine
  Co-Director, Thoracic Oncology Program
  University of Michigan
  Ann Arbor, MI
- Julian R. Molina, M.D., Ph.D.
  Associate Professor of Oncology
  Mayo Clinic
  Rochester, MN
- Mark S. Parker, M.D., FACR^*^
  Professor of Diagnostic Radiology and Internal Medicine
  Director, Thoracic Imaging
  Virginia Commonwealth University Medical Center
  Richmond, VA
- James G. Ravenel, M.D.
  Professor of Radiology Vice Chair of Radiology Education
  Director of Thoracic Imaging
  Medical University of South Carolina
  Charleston, SC
- Yee Ung, M.D.^*^
  Radiation Oncologist
  Sunnybrook Health Sciences Centre
  Toronto, Canada
- Kazuhiro Yasufuku, M.D.
  Associate Professor of Surgery
  University of Toronto
  Staff Thoracic Surgeon
  Division of Thoracic Surgery, Toronto General Hospital
  Toronto, Canada