# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Frank C. Detterbeck, M.D., FACS, FCCP
  Professor of Surgery, Section of Thoracic Surgery
  Chief, Thoracic Surgery
  Yale University
  New Haven, CT
- Rebecca Diekemper, M.P.H.
  Manager, Guideline Methodology
  American College of Chest Physicians
  Chicago, IL
- John A. Fallon, M.D.
  Senior Vice President and Chief Physician Executive
  Blue Cross Blue Shield of Massachusetts
  Boston, MA
- Gregory P. Kalemkerian, M.D.
  Professor of Medicine
  Co-Director, Thoracic Oncology Program
  University of Michigan
  Ann Arbor, MI
- Feng-Ming (Spring) Kong, M.D., Ph.D.
  Professor and Chair, Department of Radiation Oncology
  Co-Director of Lung and Esophageal Programs
  Georgia Regents University Cancer Center
  Augusta, GA
- Mark S. Parker, M.D., FACR
  Professor of Diagnostic Radiology and Internal Medicine
  Director, Thoracic Imaging
  Virginia Commonwealth University Medical Center
  Richmond, VA
- Maureen Rigney, LCSW
  Director of Community and Support Services
  Lung Cancer Alliance
  Washington, D.C.