# Acknowledgments

The authors gratefully acknowledge Eric B. Bass, M.D., M.P.H., of the Johns Hopkins Evidence-based Practice Center, who served as AHRQ Associate Editor; Dr. Craig A. Umscheid, M.D, M.S.C.E., Senior Associate Director of ECRI–Penn Medicine AHRQ Evidence-based Practice Center for recruiting clinical investigators, and the following individuals at ECRI Institute for their contributions to this project: Lydia Dharia, Katherine Donahue, Helen Dunn, Gina Giradi, Allison Gross, Janice Kaczmarek, and Michael Phillips. We also thank AHRQ Task Order Officer Lionel Bañez, M.D., and Nahed El-Kassar, M.D., Ph.D.