# Discussion

## Key Findings and Strength of Evidence

Based on the evidence we reviewed, we concluded the following:

- FDG PET/CT is more sensitive than bone scintigraphy at detecting osseous metastases (Strength of Evidence: low)
- FDG PET/CT is more sensitive than CT at detecting osseous metastases (Strength of Evidence: low)
- Standard staging plus FDG PET/CT is more sensitive than standard staging alone at detecting any distant metastases (Strength of Evidence: low)

Our strength-of-evidence judgments for these conclusions, along with the other evidence that was insufficient to permit conclusions, are listed in Table 3 below. Note that all three of our conclusions involve the superior sensitivity of FDG PET/CT. We discuss this commonality below in the sections “Finds in Relationship to What Is Already Known” and “Implications for Clinical and Policy Decisionmaking.”

Table 3 Strength of evidence grades

Staging Determination | Test Comparison | Number of Studies and Number of Patients | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Magnitude of Effect | SOE Grade^*^ | Conclusion
LD vs. ED | Standard staging^†^ vs. FDG PET/CT | Direct comparison: 1 study25 of 28 patients Indirect comparison: 1 study27 of standard staging of 25 patients | Moderate | Mixed | Unknown | Imprecise | None suspected | Not large | Insufficient | NA
Osseous metastases | FDG PET/CT vs. bone scintigraphy | Direct comparison: 2 studies23,25 of 123 patients Indirect comparison: 1 study22 of bone scintigraphy of 76 patients | Moderate | Mixed | Consistent | Imprecise | None suspected | Large | Low | FDG PET/CT more sensitive
Osseous metastases | CT vs. FDG PET/CT | Direct comparison: 1 study25 of 29 patients | Moderate | Direct | Unknown | Imprecise | None suspected | Large | Low | FDG PET/CT more sensitive
Osseous metastases | CT vs. bone scintigraphy | Direct comparison: 1 study25 of 28 patients Indirect comparison: 1 study22 of bone scintigraphy of 76 patients | Moderate | Mixed | Unknown | Imprecise | None suspected | Not large | Insufficient | NA
Lymph node involvement | CT vs. EBUS | Indirect comparison: 1 study22 of CT of 118 patients, and 1 study26 of EBUS of 36 patients | Moderate | Indirect | Unknown | Imprecise | None suspected | Not large | Insufficient | NA
Metastases to adrenal glands | CT vs. anything else | Indirect comparison: 1 study22 of CT of 120 patients | Moderate | Indirect | Unknown | Unknown | None suspected | Unknown | Insufficient | NA
Metastases to liver | CT vs. .anything else | Indirect comparison: 1 study22 of CT of 120 patients | Moderate | Indirect | Unknown | Unknown | None suspected | Unknown | Insufficient | NA
Metastases to spleen | CT vs. anything else | Indirect comparison: 1 study22 of CT of 120 patients | Moderate | Indirect | Unknown | Unknown | None suspected | Unknown | Insufficient | NA
Any distant metastasis | Standard staging^†^ vs. Standard staging^†^ plus FDG PET/CT | Direct comparison: 1 study24 of 73 patients | High | Direct | Unknown | Imprecise | None suspected | Large | Low | Standard staging^†^ plus FDG PET/CT more sensitive
Metastases to brain | FDG PET/CT of the brain vs. anything else | Indirect comparison: 1 study21 of FDG PET/CT of 21 patients | Moderate | Indirect | Unknown | Imprecise | None suspected | Unknown | Insufficient | NA

EBUS = endobronchial ultrasound; ED = extensive stage disease; FDG PET/CT = [^18^F]-fluorodeoxyglucose positron emission tomography/computed tomography; LD = limited stage disease; NA = not applicable since evidence was insufficient to permit a conclusion for this staging determination for this test-test comparison; SOE = strength of evidence

* The SOE grade indicates our confidence in the conclusion about the direction of the effect, not about the magnitude of the difference.

† Standard” staging of SCLC is not a precisely defined term, but may involve numerous investigations including history, physical exam, chest x-ray, chest CT, bone scan, bone marrow aspiration, and/or MRI or CT of the brain.

## Findings in Relationship to What Is Already Known

Our searches found eight previous systematic reviews that evaluated imaging modalities for pretreatment staging of SCLC. We found no previous systematic reviews of evidence on CT, MRI, or bone scintigraphy for SCLC staging. Thus, our conclusions for these modalities (and documentation of lack of evidence in many instances) represent new knowledge that can guide future investigations.

All prior systematic reviews on imaging modalities for SCLC staging focused on PET. Some reviews included studies using combined PET/CT scanners, but most had data only from standalone PET scanning, which is no longer the current standard of practice. Our review focuses on PET/CT, which will more accurately reflect choices available today.

The most relevant previous reviews were undertaken in the development of American College of Chest Physicians (ACCP) guidelines for management of SCLC. Two editions of these guidelines included reviews meeting our inclusion criteria. In the review by Samson et al. (2007),28 for the second edition of the guidelines, only one KQ addressed the role of imaging tests in SCLC staging. This question asked whether the addition of PET scanning improved staging of SCLC. The authors identified six studies of PET for various staging indications, deemed the evidence to be poor quality, and drew no conclusions from it. This and the previous reviews could not use a consistent reference standard for comparison to PET; they had to use the reference standards reported by the investigators of each study.

Since the publication of that review, combined PET/CT systems have replaced standalone PET scanners at most U.S. hospitals, so our review excluded standalone PET, which resulted in exclusion of all the studies Samson et al. cited.28 Like Samson et al, we also found the evidence on PET/CT to be weak, but nevertheless concluded that PET/CT has superior sensitivity compared with either CT alone or bone scintigraphy for detecting osseous metastases; we also concluded that PET/CT has superior sensitivity to standard staging for detecting any distant metastases overall at the patient level. Samson et al. saw a similar trend in the standalone PET studies they reviewed.28 We are more willing to state conclusions from the weak evidence because the AHRQ evidence grading system expresses the degree of weakness and makes clear that additional evidence could overturn our conclusions.

The third edition of the ACCP guidelines included the KQ “what is the ability of PET imaging to determine the stage of cancer?” The review concluded that PET was superior to standard staging modalities for detecting metastases, with the exception of brain metastases, where PET was inferior to CT and MR. The resulting guideline recommended PET for patients with SCLC clinically diagnosed as limited-stage.

While the review for ACCP by Jett et al. (2013)10 was published relatively recently, it included studies dating back as far as 2001; nearly all the studies used standalone PET. Direct integration of anatomic data from CT in combined PET/CT may mitigate some inaccuracy of PET in diagnosing brain metastases. Indeed, when looking only at PET/CT compared with standard staging, we could not conclude that PET/CT was inferior.

The Jett review also analyzed how often PET resulted in a change of management plans for patients with SCLC.10 All but one study used standalone PET, but a substantial number of patients remained whose management was changed as the result of PET findings. Like we did, Jett et al. recognized that the absence of a reliable reference diagnosis in most of these studies precludes determination that PET is the superior imaging modality. Jett et al. also commented on the lack of uniformity in study methods and data analysis; these issues persist in the evidence base for PET/CT and hindered our ability to draw any conclusions.

Neither of the ACCP guideline reviews offered a granular categorization and analysis of data such as we have provided. Therefore, although we were unable to draw many conclusions about the comparative effectiveness of PET/CT, we have provided a thorough and detailed description of the current available evidence that future investigators can use to address these important evidence gaps.

The two other systematic reviews of SCLC staging—Lu et al. (2014)29 and Ruben et al (2012)30 –were similar in that the majority of studies in both were small and included standalone PET. However, the focus of the two reviews differed. Lu et al. sought to determine a summary sensitivity and specificity of PET for distinguishing between patients with LD and ED, concluding that the sensitivity of PET was 98.1 percent (95% CI 94.7%–99.6%) and the specificity was 97.5 percent (95% CI 93.0%–99.5%). We did not find sufficient data to permit similar summary estimates for PET/CT. Ruben et al. studied the effect of PET on patient management, concluding that changes to treatment plans occurred in nearly one-third of patients having PET scans. Jett et al. arrived at a similar conclusion.10 In the absence of a gold standard reference, it is not possible to ascertain whether those changes resulted in better or worse outcomes for the patient due to denial of potentially valuable treatment (false-positive PET) or avoidance of unnecessary treatment and its side effects (true-positive PET).

Three previous reviews—Ravanal (2012),31 Helwig et al. (2009),32 and Ung et al. (2007)33—covered lung cancer staging in general, making little reference to SCLC in particular. As the clinical course of SCLC is considerably different from that of other forms of lung cancer, decisions on staging and treatment should be based on evidence specific to SCLC. The effects of differences between cancer types could outweigh the differences in effectiveness between one modality and another as seen in a study of mixed types of lung cancer. The systematic review published by the U.K. National Health Service on PET for various cancer indications34 reported that as of the time of their searches (August 2005) no published studies existed on combined PET/CT for diagnosis, staging, or restaging of SCLC.

## Implications for Clinical and Policy Decisionmaking

Based on our review of the current evidence, our results suggest two overall conclusions. First, compared with CT and bone scintigraphy (imaging modalities commonly used for staging) FDG PET/CT is more sensitive for detecting osseous metastases in patients with SCLC. Our findings suggest that clinicians evaluating patients for the presence of osseous metastases may consider forgoing bone scintigraphy and routinely use FDG PET/CT instead. Second, for patients with SCLC who have undergone standard staging, the addition of FDG PET/CT increases sensitivity for detecting any distant metastases overall at the patient level.

The evidence base did not allow us to draw conclusions about the comparative specificity of FDG PET/CT compared with these other modalities; thus, we acknowledge that any of the modalities could yield false positives. If a false positive led to inaccurate “upstaging” to extensive disease, a patient might only receive a palliative regimen instead of aggressive chemotherapy aimed at cure. Unfortunately, as we found only 1 study addressing EBUS and no studies evaluating EUS, MRI, or PET/MRI for inclusion we were unable to assess their comparative accuracy for FDG PET/CT.

SCLC is an aggressive cancer, and timely staging is important to determine treatment decisions based on whether patients have limited or extensive disease. Currently, as part of the standard staging process, patients may undergo bone scintigraphy, CT of the abdomen and pelvis, brain MRI, and FDG-PET/CT. Reducing the total number of tests may improve the timeliness of staging and permit faster initiation of treatment.

Higher sensitivity also has other potential important implications for patient care. First, better detection of metastases can improve patient selection for optimal therapy. The higher sensitivity of FDG PET/CT would provide clinicians the confidence to offer a comprehensive stage-based treatment plan. Second, earlier detection of extensive disease would spare patients from more aggressive chemotherapy and radiation protocols used for patients with LD. Earlier initiation of palliative measures may result in improved quality of life, an important consideration given the current poor prognosis of this disease. Third, improved sensitivity and timeliness of staging may potentially improve the ability of ongoing research trials to prognosticate and detect therapeutic efficacy.

Finally, our results suggest potential resource implications. Although FDG PET/CT may be more expensive than CT and bone scintigraphy, some patients may undergo all three tests when evaluated for osseous and other distant metastases outside the brain. Eliminating routine use of bone scintigraphy from SCLC staging protocols in favor FDG-PET/CT could potentially result in some cost savings.

## Applicability

We judged the applicability of the evidence based on comparison of the patients, interventions, and settings found in the research studies to those typically used in clinical practice. The typical mean age of patients in our included studies was in the seventh decade of life. Based on the National Cancer Institute's (NCI) Surveillance Epidemiology and End Results (SEER) database, in 2011, 82 percent of those living with lung cancer were 60 years of age or older.35 Six of seven studies included mostly males (72 percent to 86 percent), and one included more females (62 percent). Based on the NCI SEER database, in 2011, men develop lung cancer more often than women (1.3:1 male/female ratio).35 Overall, the applicability of evidence in the included studies to typical patients appears reasonable.

With regard to imaging tests, the studies of FDG-PET/CT employed patient preparation and acquisition parameters typical of those used in clinical practice,36 despite minor variations in image-acquisition parameters used in these included studies. Similarly, bone scintigraphy performed in these studies was obtained with techniques typical of those used in clinical practice.37 EBUS-FNA is also frequently used as a diagnostic test for staging SCLC, and the one study addressing this technique described it similarly to that used in clinical practice.

Studies were conducted in university-based academic or teaching hospitals outside the United States, which may limit the applicability of the results to community hospitals and hospitals in the United States. Community hospitals may differ from the settings in the included studies with respect to the experience of the technicians administering the imaging test or the interpretation skills of those reading the imaging results. U.S. hospitals may differ from those outside the United States in terms of their specified protocols for the diagnostic workup and management of patients with SCLC.

## Limitations of the Comparative-Effectiveness Review Process

In this section, we discuss three challenges we faced in developing this review: (1) whether to include the concept of diagnosis, (2) whether to include non-English studies, and (3) how to assess the risk of bias of comparative accuracy studies.

The first challenge arose from the fact that imaging tests often serve the dual purpose of diagnosing and staging lung cancer. By definition, when imaging is used for diagnosis, it remains unknown whether the patient has SCLC. Lung symptoms may be due to a variety of causes, including SCLC, but also NSCLC or metastases from another site, in addition to noncancerous causes. As all these etiologies are possibilities during the process of diagnosis, including the concept of diagnosis would have required including studies of imaging tests for diagnosing any of these possibilities. Given the defined time and budget, such a scope was untenable, and so we chose to focus on the staging of SCLC.

A second challenge involved whether to include non-English studies. We initially excluded them due to the cost of translation and the possibility that the design and results of such studies may not be applicable to the United States. However, when confronted with the small size of the resulting literature (5 studies), we reconsidered the 28 studies that we had excluded for this reason. Of those, two studies met our inclusion criteria.

A third challenge involved assessing the risk of bias of comparative accuracy studies. The basic target for this assessment is whether a study comparing the staging accuracy of test A to that of test B (measuring both against a common reference standard) was biased in favor of one of the two tests. Ideally, we could have used an existing off-the-shelf assessment instrument. However, current risk-of-bias instruments for diagnostic studies (e.g., QUADAS-2) do not sufficiently address this topic because they were designed for single-test accuracy studies (e.g., did this study provide unbiased estimates of test accuracy). We thought carefully about potential areas of bias and devised our own instrument for this purpose. The instrument has not been tested by others, and its appropriateness should be verified.

## Limitations of the Evidence Base

The seven included studies were limited in numerous ways. The most prominent ways were (1) lack of test-test comparisons, (2) small sample sizes, (3) questionable reference standards, and (4) lack of comparative-effectiveness designs.

First, only three studies directly compared the accuracy of different imaging tests. More test-test comparisons might have permitted us to draw more conclusions from the evidence. Indirect comparisons are fraught with difficulty because important inter-study differences in patient populations could confound any comparisons.

Second, the seven studies were generally small (the median sample size was 36, with a range from 21 to 120). This means large imprecision in statistical results may result, which in turn means insufficient evidence to make claims about test-test comparisons.

Third, studies' reference standards were often suboptimal. Studies generally used a combination of clinical history, cell pathology (only obtained for a portion of patients), other imaging tests, and clinical followup. These reflect the clinical reality of the process of staging SCLC, since it would be unethical to perform a biopsy on all possible sites of metastases in a patient. Thus, the test accuracy estimates reported by all studies are tentative. The direction of possible bias resulting from the lack of good reference standards in these studies is not predictable, so it simply increases the uncertainty of the results. For instance, incorporation of the study test into the reference standard (incorporation bias) would tend to increase positive predictive value, but other shortcomings such as lack of histologic verification of positives could decrease positive predictive value.

Fourth, and perhaps most important, none of the studies were designed to allow inferences about comparative effectiveness. Generally, all patients in a given study received the same battery of imaging tests; thus, subsequent outcomes (e.g., management strategies, survival time and quality of life) could not be attributed to any single test or test strategy. The clinical value of an imaging test is best measured by using it for only some of the patients and comparing their health outcomes to a carefully matched group of other patients who did not receive that imaging test. Granted, such a design is exceedingly rare in the medical literature. Without such designs, however, the true patient-oriented value of any give staging modality cannot be determined.

## Research Gaps

For characterizing gaps, we used the EPC framework proposed by Robinson et al. (2011).38 That system suggests that reviewers identify a set of important gaps and determine the most important reason for each gap. Each gap should be assigned one of the following reasons for the inability to draw conclusions:

a. Insufficient or imprecise information: no studies, limited number of studies, sample sizes too small, estimate of effect is imprecise
b. Information at risk of bias: inappropriate study design; major methodologic limitations in studies
c. Inconsistency or unknown consistency: consistency unknown (only 1 study); inconsistent results across studies
d. Not the right information: results not applicable to population of interest; inadequate duration of interventions/comparisons; inadequate duration of followup; optimal/most important outcomes not addressed; results not applicable to setting of interest

We found three primary gaps in the literature on imaging tests for the pretreatment staging of SCLC. The first concerns the dearth of evidence on several tests of interest, particularly MRI, EBUS, EUS, and PET/MRI. This gap exists due to reason a, Insufficient information. Note that we did not restrict our search to studies of particular staging purposes of these tests even though some are typically used for specific targets (e.g., brain MRI). EBUS and EUS may be used as much for diagnosis as for staging, so that may partially explain the lack of direct evidence on staging SCLC. PET/MRI is a relatively new technology, and we predicted that little would be identified, but future systematic reviews may uncover evidence as it becomes more widespread.

The second gap concerns the absence of study designs to inform the optimal imaging plan for the pretreatment staging of SCLC. Thus, the reason for this gap is reason b, Information at risk of bias. At least three underlying sources exist for the gap: (1) the general lack of direct comparisons of different imaging modalities; (2) the use of mixed reference standards (based on partial histology, other imaging tests, and clinical followup) since not all patients' true stage can be determined before treatment; and (3) the complete lack of studies of comparative effectiveness with patient-oriented outcomes such as management strategy or survival after receiving different test strategies. We recognize that some of these problems are due to the clinical reality that SCLC is fast-growing, necessitating timely initiation of treatment.

The third gap concerns KQ3, which addressed the extent to which comparative accuracy or effectiveness are associated with patient factors (comorbidities, body habitus, tumor characteristics). We identified no studies for this question, so this gap exists due to reason a, Insufficient information. Addressing this problem would be easier than addressing the problems listed in the previous paragraph. As most patient records already contain information on patient characteristics, future research could stratify their accuracy results accordingly. Armed with this more detailed data, clinicians and policymakers could possibly recommend tailoring specific strategies for different patient subgroups.

Our knowledge of the biology of SCLC has increased tremendously over the past few decades. Many molecular targets have been identified. These have been used as potential targets for diagnostic and therapeutic intervention. Despite several attempts, these advances have not translated into a meaningful survival benefit. Future advances in SCLC should focus on efforts to refine imaging strategies to identify patients with actionable mutations, and identify specific sub-populations within SCLC suitable for targeted therapy.

## Conclusions

Comparative evidence on the pretreatment staging of SCLC is sparse. We found some low-strength evidence suggesting that FDG PET/CT is more sensitive than CT and bone scintigraphy for assessing osseous metastases, and that standard staging plus FDG PET/CT is more sensitive than standard staging alone at detecting any distant metastases.