# Appendix References

1 Lee JW, Lee SM, Lee HS, et al. Comparison of diagnostic ability between (99m)Tc-MDP bone scan and 18F-FDG PET/CT for bone metastasis in patients with small cell lung cancer. Ann Nucl Med. Oct. 2012;26(8):627-33. [pmid: 22729551].
2 Palomar Munoz A, Garcia Vicente AM, Bellon Guardia ME, et al. Is a selective brain (18)F-FDG PET/CT study profitable in patients with small cell lung cancer?. Rev Esp Med Nucl Imagen Mol. May. 2012;31(3):124-9. [pmid: 21722995].
3 Sohn BS, Lee DH, Kim EK, et al. The role of integrated 18F-FDG PET-CT as a staging tool for limited-stage small cell lung cancer: a retrospective study. Onkologie. Aug. 2012;35(7):432-8. [pmid: 22846975].
4 Wada H, Nakajima T, Yasufuku K, et al. Lymph node staging by endobronchial ultrasound-guided transbronchial needle aspiration in patients with small cell lung cancer. Ann Thorac Surg. Jul. 2010;90(1):229-34. [pmid: 20609781].
5 Fischer BM, Mortensen J, Langer SW, et al. A prospective study of PET/CT in initial staging of small-cell lung cancer: comparison with CT, bone scintigraphy and bone marrow analysis. Ann Oncol. Feb. 2007;18(2):338-45. [pmid: 17060487].
6 Brink I, Schumacher T, Mix M, et al. Impact of [(18)F]FDG-PET on the primary staging of small-cell lung cancer. Eur J Nucl Med Mol Imaging. Dec. 2004;31(12):1614-20. [pmid: 15258700].
7 Shen YY, Shiau YC, Wang JJ, et al. Whole-body 18F-2-deoxyglucose positron emission tomography in primary staging small cell lung cancer. Anticancer Res. 2002;22(2):1257-64. [pmid: 12168935].