# Risk of Bias Assessments

Figure D-1 Risk of bias assessments of comparative accuracy studies

Item | Lee et al. (2012)1 | Fischer et al. (2007)5 | Sohn et al. (2012)3
1. Did the study enroll all, consecutive, or a random sample of patients? | NR | Yes | Yes
2 Was the study unaffected by spectrum bias (e.g., patients with known status before the study, or patients selected for being difficult to diagnose/stage)? | NR | NR | No
3 Was prior experience with the test (technicians, readers) similar for the two imaging tests being compared in the study? | Yes | Yes | Yes
4 Were the imaging tests performed within one month of each other (to avoid the possibility that the patient's true condition changed between tests)? | Yes | Yes | Yes
5 Was knowledge of the other test complementary (either both tests were read with knowledge of the other results, or neither test was read with knowledge of the other)? | NR | Yes | No
6 Did the interpreters have the same other information available at the time of interpretation for the two imaging tests (other clinical information, 3rd test results)? | NR | NR | No
7 Was each test's accuracy measuring using the same reference standard (or a similar proportion of patients who underwent different reference standards such as clinical follow-up and surgical findings)? | Yes | Yes | Yes
8 Were readers of both tests of interest blinded to the results of the reference standard (or the reference standard was unknowable until after the tests were read)? | Yes | Yes | Yes
9 Were the people determining the reference standard unaware of the diagnostic test results? | No | No | No
Risk of Bias Category | Moderate | Moderate | High

Figure D-2 Risk of bias assessments of single test accuracy studies

Item | Wada et al. (2010)4 | Brink et al. (2004)6 | Shen et al. (2002)7 | Palomar Munoz et al. (2012)2
1. Did the study enroll all, consecutive, or a random sample of patients? | Yes | Yes | NR | NR
2 Were more than 85 percent of the approached/eligible patients enrolled? | Yes | NR | NR | NR
3 Were the patient inclusion and exclusion criteria applied consistently to all patients? | Yes | Yes | NR | NR
4 Was the study unaffected by obvious spectrum bias? | Yes | Yes | Yes | Yes
5 Did the study account for inter-reader differences? | No | Yes | No | No
6 Were readers of the diagnostic test of interest blinded to the results of the reference standard? | NR | Yes | Yes | Yes
7 Were readers of the reference standard blinded to the results of the diagnostic test of interest? | No | No | NR | Yes
8 Were readers of the diagnostic test of interest blinded to all other clinical information? | Yes | Yes | NR | NR
9 Were readers of the reference standard blinded to all other clinical information? | NR | No | No | No
10 Were patients assessed by a reference standard regardless of the test's results? | No | Yes | Yes | Yes
11 Were all patients assessed by the same reference standard regardless of the test's results? | No | Yes | Yes | Yes
12 If the study reported data for a single diagnostic threshold, was the threshold chosen a priori? | NA | NA | NA | NA
13 Were the study results unaffected by intervening treatments or disease progression/regression? | Yes | Yes | Yes | No
14 Were at least 85 percent of the enrolled patients accounted for? | Yes | No | Yes | Yes
Risk of Bias Category | Moderate | Moderate | Moderate | Moderate