# Evidence Tables

Table C-1 General study information of included studies

Study | Country | Name of Clinic(s) | Range of Dates When Patients Received Imaging Tests | Prospective or Retrospective | Funding Source and Disclosed Potential Conflicts of Interest
Lee et al. (2012)1 | South Korea | Soonchunhyang University | Jan 2006–Oct 2011 | Retrospective | Funding NR, No conflicts to disclose
Palomar Munoz et al. (2012)2 | Spain | Ciudad Real | Jul 2008–Dec 2009 | Retrospective | NR
Sohn et al. (2012)3 | South Korea | Asan Medical Center | Jan 2002–Dec 2007 | Retrospective | NR, but no conflicts to disclose
Wada et al. (2010)4 | Japan | Chiba University | Nov 2002–Sep 2008 | Retrospective | NR
Fischer et al. (2007)5 | Denmark | Copenhagen University Hospital | Feb 2003–Dec 2004 | Prospective | NR
Brink et al. (2004)6 | Germany | Freiburg University Hospital | 1999–2003 | Prospective | Funded by German Cancer Foundation, conflicts NR
Shen et al. (2002)7 | Taiwan | China Medical College | NR | Prospective | NR

NR=Not reported

Table C-2 Patient characteristics of included studies

Study | Patient Enrollment Criteria | Number of Patients Included | % Female | Age (Mean, Range) | Consecutivity
Lee et al. (2012)1 | Diagnosed with SCLC, no treatment, no history of previous malignancy | 95 | 25% (24/95) | Mean 68, SD 9, range NR | Did not report whether enrollment was consecutive
Palomar Munoz et al. (2012)2 | Diagnosed with SCLC, had pre-treatment PET/CT, no neurologic symptoms | 21 | 14% (3/21) | Mean 66.57 (range 45–83) | Excluded patients followed up less than 6 months. Does not explicitly say consecutive.
Sohn et al. (2012)3 | Diagnosed with SCLC, no treatment, had initial CT and bone scan or neuro imaging | 73 | 18% (13/73) | Mean NR, SD NR, median 62, range 27–83 | Does not explicitly say consecutive.
Wada et al. (2010)4 | Limited disease SCLC patients who underwent EBUS-TBNA for lymph node staging because they were being considered for surgical resection | 40 | 15% (6/40) | Mean 66.0, SD NR, range 37–79 | Did not report whether enrollment was consecutive. Of note, although the demographic data describe 40 pts, only 36 were included in the denominator for sen, spec, calcs, since 4 patients who were considered “negative” by EBUS could not undergo surgery and confirmation of “negative” status. However, the demographics for these 4 are not provided separately.
Fischer et al. (2007)5 | Patients with pathologically proven SCLC | 34 | 62% (21/34) | Mean 63, range 47–77 | Consecutive enrollment
Brink et al. (2004)6 | Histologically confirmed SCLC, exclusion criteria not reported | 120 | 25% (30/120) | Mean 60.8, SD 8.9 | Consecutive enrollment
Shen et al. (2002)7 | Diagnosed with SCLC, no treatment | 25 | 28% (7/25) | Mean 56.4, SD 7.2, median 57, range 45–68 | Did not report whether enrollment was consecutive.

NR=Not reported

Table C-3 General test details of included studies

Study | Number of SCLC Patients in This Study Who Received This Test | Imaging Test | Test Details | Order of Multiple Tests Performed | Elapsed Time Between Tests
Lee et al. (2012)1 | 95 | Bone scintigraphy | Tc99m-MDP, 740-925 MBq 3 hours prior, GE Xeleris dual-head camera, continuous acquisition mode (12 cm/min), 20% symmetric window about 140 keV, whole-body and spot imaging | NR | Median 5 days, max 20 days
Lee et al. (2012)1 | 95 | FDG PET/CT | FDG, 5.18 MBq/kg 1 hour prior, Philips Gemini scanner, 128 matrix, 3D reformatting | NR | Median 5 days, max 20 days
Palomar Munoz et al. (2012)2 | 21 | FDG PET/CT of the brain | FDG, methods reported in previous article, GE Discovery DSTE 16 scanner | NA | NA
Sohn et al. (2012)3 | 73 | FDG PET/CT | FDG, 550 MBq 1 hour prior, Siemens Biograph Sensation, 2 minutes per position | Conventional first | NR
Sohn et al. (2012)3 | 73 | Standard staging | History, physical exam, chest x-ray, chest CT, bone scan, bone marrow aspiration, MRI or CT of the brain) | Conventional first | NR
Wada et al. (2010)4 | 40 | EBUS | Convex probe EBUS (BF-UC260F-OL8; Olympus, Tokyo, Japan) integrated with convex transducer (7.5 MHz); ultrasound images processed with ultrasound scanner (EU-C2000;Olympus); a dedicated 22-gauge needle was used to perform transbronchial needle aspiration (NA-201SX-4022; Olympus) | NA | NA
Fischer et al. (2007)5 | 29 | Standard staging | Any of the following: Clinical exam, blood test, chest x-ray, bronchoscopy, and bone marrow biopsy | NR | All exams performed within one week
Fischer et al. (2007)5 | 29 | FDG PET/CT | 400 MBq 18-F-FDG was given, scan performed on integrated PET/CT system (GE Discovery LS; General Electric Medical Systems, Milwaukee, WI). A standardized CT protocol (80–120 mAs, 140 kV, tube rotation time 0.5 s per rotation, pitch 6, and slice thickness of 5 mm) was applied followed by PET scan (3 or 5 min emission scan per table position) | Radiologist first read CT (blinded to PET), then nuclear medicine physician read PET (blinded to CT findings); then “fused PET/CT images were evaluated in consensus afterwards” | CT result was derived from PET/CT, thus no time lapse between PET/CT and CT. Bone scan was at most six days after PET/CT
Fischer et al. (2007)5 | 29 | Bone scintigraphy | Whole body scan with dual head gamma camera (Geor ADAC) with high resolution low energy collimator was performed 2 hr after injection with 500-700 MBq 99m Tc-oxydronate (TechneScan HDP; Malinkrodt, Hazelwood, MO, USA) | NR | All exams performed within one week
Fischer et al. (2007)5 | 29 | CT | Was performed using PET/CT scanner | Radiologist first read CT (blinded to PET), then nuclear medicine physician read PET (blinded to CT findings); then “fused PET/CT images were evaluated in consensus afterwards” | CT result was derived from PET/CT, thus no time lapse between PET/CT and CT. Bone scan was at most six days after PET/CT
Brink et al. (2004)6 | 120 | CT | NR | NA | NA
Brink et al. (2004)6 | 76 | Bone scintigraphy | Tc99m-MDP, 700 MBq 3 hours prior, dual-head camera, mfr. not reported, some SPECT as well | NR | NR
Shen et al. (2002)7 | 25 | Standard staging | Standard staging assessment, which included history and physical exam, chest x-ray, possibly chest CT, brain CT, abdominal CT, possibly hepatic sonography, Tc-99m MDP bone scan, unilateral iliac crest bone marrow exam. | NA | NA

Note: This table includes details of only the imaging tests for which data met our inclusion criteria.

NA=Not applicable; NR=not reported

Table C-4 Imaging test readers and reference standards

Study | Imaging Test | Number of Test Readers Per Scan | Prior Experience of These Readers With This Imaging Test | Other Reported Details About the Readers | Reference Standard
Lee et al. (2012)1 | Bone scintigraphy | 2 | Experienced | NM specialist, used 4-point scale. Consensus or independent reading NR, blinding NR | Positive biopsy OR CT or MRI confirmation OR progression seen on subsequent scan (any one sufficient to diagnose)
Lee et al. (2012)1 | FDG PET/CT | 2 | Experienced | NM specialist, used 4-point scale. Consensus or independent reading NR, blinding NR | Positive biopsy OR CT or MRI confirmation OR progression seen on subsequent scan (any one sufficient to diagnose)
Palomar Munoz et al. (2012)2 | FDG PET/CT of the brain | NR | Nuclear medicine experts | NR | Minimum 6 month clinical follow-up including contrast CT, brain MRI.
Sohn et al. (2012)3 | FDG PET/CT | 2 (consensus) | Experienced | Not blinded to other results | Clinical follow-up
Sohn et al. (2012)3 | Standard staging | NR | NR | Not blinded to other results | Clinical follow-up
Wada et al. (2010)4 | EBUS | 1 | NR | Blinded to patient details | Negative nodes: surgical path; positive nodes: EBUS results
Fischer et al. (2007)5 | Standard staging | NR | NR | NR | Reference standard based on four things: 1) histology if available; 2) concordance between different imaging modalities; 3) results of MRI or ultrasound; 4) clinical follow-up
Fischer et al. (2007)5 | FDG PET/CT | 2 | Experienced | NR | See above
Fischer et al. (2007)5 | Bone scintigraphy | 1 | “Experienced” nuclear medicine physician | NR | See above
Fischer et al. (2007)5 | CT | 1 | “An experienced radiologist, blinded to PET findings interpreted the CT scan” | NR | See above
Brink et al. (2004)6 | CT | NR | NR | NR | Consensus achieved by committee of 4 (2 clinicians, 2 nuclear medicine specialists)
Brink et al. (2004)6 | Bone scintigraphy | Not reported | Not reported | NR | Committee decision
Shen et al. (2002)7 | Standard staging (multiple tests) | NR | NR | NR | Based on several considerations including surgical findings, other imaging results, and one year clinical follow-up

Note: This table includes details of only the imaging tests for which data met our inclusion criteria.

NA=Not applicable; NR=not reported

Table C-5 Concordance data for tests of interest in included studies (Fischer et al. [2007])

Staging Determination | Test 1 Versus Test 2 | Number With Both Tests Positive | Number With Both Tests Negative | Number With Where Test 1 Positive But Test 2 Negative | For These Discrepancies, How Many Were Stated by the Authors to be True Positives? | Number With Where Test 2 Positive and Test 1 Negative | For These Discrepancies, How Many Were Stated by the Authors to be True Positives? | % Agreement Between Tests | Comments
Tumor stage (T) | CT vs. PET/CT | 28 | 0 | 1 | NR | 0 | NR | 97% | Out of 29 patients, CT and PET/CT agreed on T staging for 28. For 1 patient, CT found stage =3, while PET/CT found stage =2. PET/CT was assessed in consensus by two people (one who had previously viewed just the CT portion of PET/CT, and the other who previously viewed just the PET portion of PET/CT), whereas CT was assessed without reference to PET/CT.
N stage (N) Lymph nodes | CT vs. PET/CT | 25 | 0 | 2 | NR | 2 | NR | 86% | Out of 29 patients CT and PET/CT agreed for 25 patients; for 2 patients CT had higher stage (Stages 3 vs. 2, Stage 2 vs. 0); for 2 patients PET/CT had higher stages (Stage 3 vs. 2 and Stage 3 vs. 2)
Pleural effusion | CT vs. PET/CT | 9 | 20 | 0 | NA | 0 | NA | 100% | Out of 29 patients, complete agreement
Metastasis to ipsilateral lung | CT vs. PET/CT | 4 | 23 | 2 | NR | 0 | NR | 93% | Out of 29 patients, 2 patients for whom CT found ipsilateral mets, but PET/CT did not
Metastasis to contralateral lung | CT vs. PET/CT | 3 | 26 | 0 | NR | 0 | NR | 100% | Our of 29 patients there was complete agreement between these 2 tests
Metastasis to the liver | CT vs. PET/CT | 10 | 16 | 1 | NR | 2 | NR | 90%
Metastasis to adrenals | CT vs. PET/CT | 3 | 24 | 2 | NR | 0 | NR | 93%
Metastasis to extra-thoracic lymph nodes | CT vs. PET/CT | 5 | 22 | 1 | NR | 1 | NR | 93%
Metastasis to osseous structures | CT vs. PET/CT | 3 | 21 | 0 | NA | 5 | 5 | 83% | All five discrepancies were called correctly by PET/CT and incorrectly by CT
Metastasis to osseous structures | CT vs. bone scint. | 1 | 12 | 1 | 1 | 14 | 7 | 46% | Counting equivocal as + for Bone scan. The 14 includes 4 times where bone scintigraphy was positive and CT was negative. 10 times where bone scintigraphy was equivocal and CT was negative. Out of 15 total discrepancies, PET/CT was correct in 8 and bone scintigraphy was correct in 7.
Metastasis to osseous structures | FDG PET/CT vs. bone scint. | 5 | 11 | 2 | 2 | 10 | 2 | 57% | Counting equivocal as + for Bone scan. The 10 includes 4 times where bone scintigraphy was positive and PET/CT was negative, and 6 times where bone scintigraphy was equivocal and PET/CT was negative. Out of 12 total discrepancies, PET/CT was correct in 10 and bone scintigraphy was correct in 2.

All included concordance data are from Fischer et al. (2007).5

NA=Not applicable; NR=not reported; scint.=scintigraphy.

Table C-6 Accuracy data for tests of interest in included studies

Study | Staging Determination | Test(s) of Interest (Test 1 vs. Test 2) | Test 1, True Positives | Test 1, False Positives | Test 1, False Negatives | Test 1, True Negatives | Test 2, True Positives | Test 2, False Positives | Test 2, False Negatives | Test 2, True Negatives | No Internal Discrepancies in Reported Data? | Comments
Fischer et al. (2007)5 | LD/ED | Standard staging vs. FDG PET/CT | 19 | 0 | 3 | 6 | 21 | 0 | 1 | 6 | OK
Shen et al. (2002)7 | LD/ED | Standard staging only | 14 | 1 | 1 | 9 | NA | NA | NA | NA | OK | Data are from Table III in the article
Lee et al. (2012)1 | Metastasis to osseous structures | FDG PET/CT vs. Bone scintigraphy | 30 | 0 | 0 | 65 | 11 | 5 | 19 | 60 | OK | These data are on a per-patient basis
Fischer et al. (2007)5 | Metastasis to osseous structures | CT vs. Bone scintigraphy | 2 | 0 | 7 | 19 | 7 | 8 | 2 | 11 | OK | These data treat equivocal bone scintigraphy results as positives
Fischer et al. (2007)5 | Metastasis to osseous structures | CT vs. Bone scintigraphy | 2 | 0 | 7 | 19 | 2 | 3 | 7 | 16 | OK | These data treat equivocal bone scintigraphy results as negatives
Fischer et al. (2007)5 | Metastasis to osseous structures | CT vs. FDG PET/CT | 3 | 0 | 7 | 19 | 8 | 0 | 2 | 19 | OK
Fischer et al. (2007)5 | Metastasis to osseous structures | FDG PET/CT vs. Bone scintigraphy | 7 | 0 | 2 | 19 | 7 | 8 | 2 | 11 | OK | These data treat equivocal bone scintigraphy results as positives
Fischer et al. (2007)5 | Metastasis to osseous structures | FDG PET/CT vs. Bone scintigraphy | 7 | 0 | 2 | 19 | 2 | 3 | 7 | 16 | OK | These data treat equivocal bone scintigraphy results as negatives
Brink et al. (2004)6 | Metastases to osseous structures | Bone scintigraphy only | 14 | 2 | 9 | 51 | NA | NA | NA | NA | OK | Subset of patients who had bone scan
Wada et al. (2010)4 | Metastasis to mediastinal and hilar lymph nodes | EBUS only | 27 | 0 | 1 | 8 | NA | NA | NA | NA | OK
Brink et al. (2004)6 | Metastasis to lymph node(s) (>1cm defined positivity) | CT only | 37 | 4 | 16 | 61 | NA | NA | NA | NA | OK | Excluded two cases where CT and PET disagreed and no reference diagnosis was obtained
Brink et al. (2004)6 | Metastases to adrenal glands | CT only | 15 | 4 | 9 | 92 | NA | NA | NA | NA | OK
Brink et al. (2004)6 | Metastases to liver | CT only | 23 | 2 | 3 | 92 | NA | NA | NA | NA | OK
Brink et al. (2004)6 | Metastases to spleen | CT only | 3 | 0 | 1 | 116 | NA | NA | NA | NA | OK
Sohn et al. (2012)3 | Distant metastasis | Standard staging vs. FDG PET/CT | 12 | 0 | 14 | 47 | 24 | 2 | 2 | 45 | Discrepancies | The two false positives were termed by authors as positives tests at first, but then termed equivocal tests; these data treat them as false positives
Palomar Munoz et al. (2012)2 | Metastases to brain | FDG PET/CT of the brain only | 3 | 0 | 2 | 16 | NA | NA | NA | NA | OK

NA=Not applicable; NR=not reported

Table C-7 Analyses of accuracy data for tests of interest in included studies

Study | Staging Determination | Test(s) | Sensitivity Test 1 (95% CI)^a^ | Sensitivity Test 2 (95% CI) a | Specificity Test 1 (95% CI) a | Specificity Test 2 (95% CI) a | 95% CI Around the Difference in Logit Sensitivities a | 95% CI Around the Difference in Logit Specificities a
Fischer et al. (2007)5 | LD/ED | Standard staging vs. FDG PET/CT | 86% (66% to 95%) (19/22) | 95% (78% to 99%) (21/22) | 100% (60% to 100%) (6/6) | 100% (60% to 100%) (6/6) | -3 to 1.1 | -3.6 to 3.6
Shen et al. (2002)7 | LD/ED | Standard staging only | 93% (70% to 99%) (14/15) | NA | 90% (59% to 98%) (9/10) | NA | NA | NA
Lee et al. (2012)1 | Metastasis to osseous structures | FDG PET/CT vs. Bone scintigraphy | 100% (88% to 100%) (30/30) | 37% (22% to 55%) (11/30) | 100% (94% to 100%) (65/65) | 92% (83% to 97%) (60/65) | 2.2 to 7.1 Favors FDG PET/CT | -0.1 to 4.9
Fischer et al. (2007)5 | Metastasis to osseous structures | CT vs. Bone scintigraphy (treating equivocals as positive) | 22% (7% to 55%) (2/9) | 78% (45% to 93%) (7/9) | 100% (83% to 100%) (19/19) | 58% (36% to 77%) (11/19) | -4.4 to -0.3 Favors bone scint. | 0.8 to 5.9 Favors CT.
Fischer et al. (2007)5 | Metastasis to osseous structures | CT vs. Bone scintigraphy (treating equivocals as negative) | 22% (7% to 55%) (2/9) | 22% (7% to 55%) (2/9) | 100% (83% to 100%) (19/19) | 84% (62% to 94%) (16/19) | -1.9 to 2.2 | -0.7 to 4.6
Fischer et al. (2007)5 | Metastasis to osseous structures | CT vs. FDG PET/CT | 30% (11% to 60%) (3/10) | 80% (49% to 94%) (8/10) | 100% (83% to 100%) (19/19) | 100% (83% to 100%) (19/19) | -3.9 to -0.1 Favors FDG PET/CT | -3.4 to 3.4
Fischer et al. (2007)5 | Metastasis to osseous structures | FDG PET/CT vs. Bone scintigraphy (treating equivocals as positive) | 78% (45% to 93%) (7/9) | 78% (45% to 93%) (7/9) | 100% (83% to 100%) (19/19) | 58% (36% to 77%) (11/19) | -2.2 to 1.9 | 0.8 to 5.9 Favors FDG PET/CT.
Fischer et al. (2007)5 | Metastasis to osseous structures | FDG PET/CT vs. Bone scintigraphy (treating equivocals as negative | 78% (45% to 93%) (7/9) | 22% (7% to 55%) (2/9) | 100% (83% to 100%) (19/19) | 84% (62% to 94%) (16/19) | 0.3 to 4.4 Favors FDG PET/CT | -0.7 to 4.6
Brink et al. (2004)6 | Metastases to osseous structures | Bone scintigraphy only | 61% (41% to 78%) (14/23) | NA | 96% (87% to 99%) (51/53) | NA | NA | NA
Wada et al. (2010)4 | Metastasis to mediastinal and hilar lymph nodes | EBUS only | 96% (82% to 99%) (27/28) | NA | 100% (67% to 100%) (8/8) | NA | NA | NA
Brink et al. (2004)6 | Metastasis to lymph node(s) (>1cm defined positivity) | CT only | 70% (56% to 80%) (37/53) | NA | 94% (85% to 97%) (61/65) | NA | NA | NA
Brink et al. (2004)6 | Metastases to adrenal glands | CT only | 63% (43% to 79%) (15/24) | NA | 96% (90% to 98%) (92/96) | NA | NA | NA
Brink et al. (2004)6 | Metastases to liver | CT only | 88% (71% to 96%) (23/26) | NA | 98% (92% to 99%) (92/94) | NA | NA | NA
Brink et al. (2004)6 | Metastases to spleen | CT only | 75% (30% to 95%) (3/4) | NA | 100% (97% to 100%) (116/116) | NA | NA | NA
Sohn et al. (2012)3 | Distant metastasis | Standard staging vs. FDG PET/CT | 46% (29% to 65%) (12/26) | 92% (76% to 98%) (24/26) | 100% (86% to 99%) (47/47) | 96% (92% to 100%) (45/47) | -4.1 to -1.1 Favors FDG PET/CT | -1.2 to 4.1
Palomar Munoz et al. (2012)2 | Metastases to brain | PET/CT of the brain only | 60% (23% to 88%) (3/5) | NA | 100% (80% to 100%) (16/16) | NA | NA | NA

a Calculated by investigators.

NA=Not applicable; NR=not reported