# List of Excluded Full Articles

Alatas F, Dundar E, Yildirim H, et al. Role of real-time endobronchial ultrasound-guided transbronchial needle aspiration in the diagnosis and mediastinal staging of lung cancer. Turk Klin J Med Sci. 2012;32(2):407-14. One test of interest, but no data on SCLC staging accuracy.
Al-Kadi OS, Watson D. Texture analysis of aggressive and nonaggressive lung tumor CE CT images. IEEE Trans Biomed Eng. Jul. 2008;55(7):1822-30. Unclear whether any patients had SCLC. [pmid: 18595800].
Allen-Auerbach M, Yeom K, Park J, et al. Standard PET/CT of the chest during shallow breathing is inadequate for comprehensive staging of lung cancer. J Nucl Med. Feb. 1. 2006;47(2):298-301. Not SCLC. [pmid: 16455636].
An YS, Sheen SS, Oh YJ, et al. Nonionic intravenous contrast agent does not cause clinically significant artifacts to 18F-FDG PET/CT in patients with lung cancer. Ann Nucl Med. Dec. 2007;21(10):585-92. Epub 2007 Dec 25. Fewer than 10 patients with SCLC. [pmid: 18092135].
Anantham D, Koh MS. Endobronchial Ultrasound-guided Tranbronchial Needle Aspiration (EBUS-TBNA) in the diagnosis and staging of lung cancer. Chin J Lung Cancer. May. 2010;13(5):418-23. Not a study (e.g., review, opinion). [pmid: 20677635].
Andrade RS, Groth SS, Rueth NM, et al. Evaluation of mediastinal lymph nodes with endobronchial ultrasound: the thoracic surgeon's perspective. J Thorac Cardiovasc Surg. Mar. 2010;139(3):578-83. Fewer than 10 patients with SCLC. [pmid: 20176204].
Annema JT, Versteegh MI, Veselic M, et al. Endoscopic ultrasound-guided fine-needle aspiration in the diagnosis and staging of lung cancer and its impact on surgical staging. J Clin Oncol. 2005;23(33):8357-61. No separate SCLC data. [pmid: 16219935].
Aquino SL, Fischman AJ. Does whole-body 2-[18F]-fluoro-2-deoxy-D-glucose positron emission tomography have an advantage over thoracic positron emission tomography for staging patients with lung cancer?. Chest. Sep. 2004;126(3):755-60. Not SCLC. [pmid: 15364753].
Araz O, Demirci E, Ucar EY, et al. Roles of Ki-67, p53, transforming growth factor-β and lysyl oxidase in the metastasis of lung cancer. Respirology. Oct. 2014;19(7):1034-9. Epub 2014 Jul 3. One test of interest, but no data on SCLC staging accuracy. [pmid: 24995672].
Araz O, Demirci E, Yilmazel Ucar E, et al. Roles of Ki-67, p53, transforming growth factor-ß and lysyl oxidase in the metastasis of lung cancer. Respirology. Oct. 2014;19(7):1034-9. Epub 2014 Jul 3. Not staging before treatment. [pmid: 24995672].
Ardengh JC, Bammann RH, de Giovani M, et al. Endoscopic ultrasound-guided biopsies for mediastinal lesions and lymph node diagnosis and staging. Clinics. 2011;66(9):1579-83. Fewer than 10 patients with SCLC. [pmid: 22179163].
Arslan N, Tuncel M, Kuzhan O, et al. Evaluation of outcome prediction and disease extension by quantitative 2-deoxy-2-[18F] fluoro-D-glucose with positron emission tomography in patients with small cell lung cancer. Ann Nucl Med. Jul. 2011;25(6):406-13. One test of interest, but no data on SCLC staging accuracy. [pmid: 21409347].
Azad A, Chionh F, Scott AM, et al. High impact of 18F-FDG-PET on management and prognostic stratification of newly diagnosed small cell lung cancer. Mol Imaging Biol. Aug. 2010;12(4):443-51. None of the modalities of interest. [pmid: 19921339].
Bae W, Kim H, Kim YA, et al. Diagnostic concordance rate between histologic and cytologic specimens of endobronchial ultrasound-guided transbronchial needle aspiration in lung cancer: a single institution experience. Thorac Cancer. Mar. 2014;5(2):174-8. No separate SCLC data. [pmid: 26766996].
Bayrak SB, Ceylan E, Serter M, et al. The clinical importance of bone metabolic markers in detecting bone metastasis of lung cancer. Int J Clin Oncol. Apr. 2012;17(2):112-8. None of the modalities of interest. [pmid: 21691728].
Bayram N, Borekci S, Uyar M, et al. Transbronchial needle aspiration in the diagnosis and staging of lung cancer. Indian J Chest Dis Allied Sci. Jul-Sep. 2008;50(3):273-6. Fewer than 10 patients with SCLC. [pmid: 18630793].
Behrendt FF, Temur Y, Verburg FA, et al. PET/CT in lung cancer: Influence of contrast medium on quantitative and clinical assessment. Eur Radiol. Nov. 2012;22(11):2458-64. Epub 2012 Jun 4. http://dx.doi.org/10.1007/s00330-012-2515-1. Unclear whether any patients had SCLC. [pmid: 22661058].
Benveniste H, Zhang S, Reinsel RA, et al. Brain metabolomic profiles of lung cancer patients prior to treatment characterized by proton magnetic resonance spectroscopy. Int J Clin Exp Med. 2012;5(2):154-64. Not SCLC. [pmid: 22567176].
Biersack HJ, Bender H, Ruhlmann J, et al. Clinical PET in oncology. Rev Esp Med Nucl. Jun. 1. 2000;19(3):219-24. Not SCLC. [pmid: 11062087].
Bilaceroglu S, Chhajed P, Mavis A, et al. Computed tomography-guided transthoracic needle aspiration in diagnosing and staging hilar and mediastinal masses of lung cancer after negative bronchoscopy. J Bronchol. Jul. 2007;14(3):149-55. None of the modalities of interest.
Block MI. Transition from mediastinoscopy to endoscopic ultrasound for lung cancer staging. Ann Thorac Surg. Mar. 2010;89(3):885-90. Fewer than 10 patients with SCLC. [pmid: 20172149].
Blum R, MacManus MP, Rischin D, et al. Impact of positron emission tomography on the management of patients with small-cell lung cancer: preliminary experience. Am J Clin Oncol. Apr. 2004;27(2):164-71. None of the modalities of interest. [pmid: 15057156].
Bocchino M, Valente T, Somma F, et al. Detection of skeletal muscle metastases on initial staging of lung cancer: a retrospective case series. Jpn J Radiol. Mar. 2014;32(3):164-71. Fewer than 10 patients with SCLC. [pmid: 24452325].
Bocchino M, Valente T, Somma F, et al. Detection of skeletal muscle metastases on initial staging of lung cancer: a retrospective case series. Jpn J Radiol. Mar. 2014;32(3):164-71. Fewer than 10 patients with SCLC. [pmid: 24452325].
Bolton WD, Johnson R, Banks E, et al. Utility and accuracy of endobronchial ultrasound as a diagnostic and staging tool for the evaluation of mediastinal adenopathy. Surg Endosc. Apr. 2013;27(4):1119-23. Fewer than 10 patients with SCLC. [pmid: 23239294].
Bradley JD, Dehdashti F, Mintum MA, et al. Positron emission tomography in limited-stage small-cell lung cancer: a prospective study. J Clin Oncol. 2004;22(16):3248-54. One test of interest, but no data on SCLC staging accuracy. [pmid: 15310768].
Brakel K, Van Overhagen H, Heijenbrok MW, et al. Detection and diagnosis of supraclavicular lymph node metastases in patients with symptoms of lung cancer by palpation, ultrasound and CT. Nederlands Tijdschrift Voor Geneeskunde. Jan. 22. 2005;149(4):189-95. No separate SCLC data.
Buchbender C, Hartung-Knemeyer V, Beiderwellen K, et al. Diffusion-weighted imaging as part of hybrid PET/MRI protocols for whole-body cancer staging: does it benefit lesion detection?. Eur J Radiol. May. 2013;82(5):877-82. Epub 2013 Feb 18. Not SCLC. [pmid: 23428414].
Buck AK, Herrmann K, Schreyogg J, et al. PET/CT for staging lung cancer: costly or cost-saving?. Eur J Nucl Med Mol Imaging. May. 2011;38(5):799-801. Epub 2011 Mar 26. Not a study (e.g., review, opinion). [pmid: 21442260].
Bugalho A, Ferreira D, Barata R, et al. Endobronchial ultrasound-guided transbronchial needle aspiration for lung cancer diagnosis and staging in 179 patients. Rev Port Pneumol. Sep/Oct. 2013;19(5):192-9. Fewer than 10 patients with SCLC. [pmid: 23850376].
BuilBruna N, Sahota T, López-Picazo JM, et al. Early Prediction of Disease Progression in Small Cell Lung Cancer: Toward Model-Based Personalized Medicine in Oncology. Cancer Research. 2015. None of the modalities of interest.
Chan WL, Freund J, Pocock NA, et al. Coincidence detection FDG PET in the management of oncological patients: attenuation correction versus non-attenuation correction. Nucl Med Commun. 2001;22(11):1185-92. Not SCLC. [pmid: 11606883].
Chin R Jr, McCain TW, Miller AA, et al. Whole body FDG-PET for the evaluation and staging of small cell lung cancer: a preliminary study. 2002;37(1):1-6. One test of interest, but no data on SCLC staging accuracy. [pmid: 12057859].
Cho AR, Lim I, Na II, et al. Evaluation of adrenal masses in lung cancer patients using F-18 FDG PET/CT. Nucl Med Mol Imaging. Mar. 2011;45(1):52-8. Fewer than 10 patients with SCLC. [pmid: 24899978].
Chodorowska A, Rzechonek A, Dyla T, et al. CT-guided fine-needle biopsy of focal lung lesions as the method for reducing the number of invasive diagnostic procedures. Polish J Radiol. Apr. 2010;75(2):55-7. None of the modalities of interest.
Chong S, Lee KS, Kim BT, et al. Integrated PET/CT of pulmonary neuroendocrine tumors: diagnostic and prognostic implications. AJR Am J Roentgenol. May. 2007;188(5):1223-31. One test of interest, but no data on SCLC staging accuracy. [pmid: 17449764].
Chooi WK, Matthews S, Bull MJ, et al. Multislice computed tomography in staging lung cancer: the role of multiplanar image reconstruction. J Comput Assist Tomogr. May/Jun. 2005;29(3):357-60. Unclear whether any patients had SCLC. [pmid: 15891507].
Chou PC, Lin SM, Lo CY, et al. Endobronchial mucosa invasion predicts survival in patients with small cell lung cancer. PLoS ONE. Oct. 4. 2012;7(10):e47613. Epub 2012 Oct 4. No outcomes of interest. [pmid: 23056644].
Claessens NJ, Maas KW, Kummer JA, et al. Lung cancer staging by endobronchial ultrasound with transbronchial needle aspiration. Nederlands Tijdschrift Voor Geneeskunde. 2012;156(46):A4741. Other: Full article no obtainable. [pmid: 23151327].
Cucuruz B, Dango S, Jurinovic V, et al. MAGE qPCR improves the sensitivity and accuracy of EBUS-TBNA for the detection of lymphatic cancer spread. J Thorac Oncol. Apr. 2012;7(4):690-7. Fewer than 10 patients with SCLC. [pmid: 22237266].
Cullen JP, Glynn C, Murtagh E, et al. Auditing a new lung cancer service. Ir Med J. Oct. 2004;97(9):281-3. No separate SCLC data. [pmid: 15568588].
Dane F, Turk HM, Sevinc A, et al. The markers of bone turnover in patients with lung cancer. J Natl Med Assoc. Apr. 2008;100(4):425-8. No outcomes of interest. [pmid: 18481482].
Dango S, Cucuruz B, Mayer O, et al. Detection of disseminated tumour cells in mediastinoscopic lymph node biopsies and endobronchial ultrasonography-guided transbronchial needle aspiration in patients with suspected lung cancer. Jun. 2010;68(3):383-8. One test of interest, but no data on SCLC staging accuracy. [pmid: 19733415].
Debevec L, Erzen J, Debeljak A, et al. Exploratory thoracotomy and its influence on the survival of patients with lung cancer. Wiener Klinische Wochenschrift. Aug. 2006;118(15):479-84. Fewer than 10 patients with SCLC. [pmid: 16957979].
DeLappe E, Dunphy M. 18F-2-Deoxy-d-Glucose positron emission tomography-computed tomography in lung cancer. Semin Roentgenol. Jul. 2011;46(3):208-23. Not a study (e.g., review, opinion). [pmid: 21726705].
Delattre C, Fournier C, Bouchindhomme B, et al. Endoscopic ultrasound guided transbronchial fine needle aspiration: a French Department of Pathology's 4-year experience. J Clin Pathol. Dec. 2011;64(12):1117-22. Epub 2011 Sep 30. No separate SCLC data. [pmid: 21965831].
Dubey S, Powell CA. Update in lung cancer 2006. Am J Respir Crit Care Med. May. 1. 2007;175(9):868-74. Not a study (e.g., review, opinion). [pmid: 17446343].
Evison M, Crosbie PA, Martin J, et al. EBUS-TBNA in elderly patients with lung cancer: safety and performance outcomes. J Thorac Oncol. Mar. 2014;9(3):370-6. No separate SCLC data. [pmid: 24518088].
Evison M, Crosbie PA, Martin J, et al. EBUS-TBNA in elderly patients with lung cancer: Safety and performance outcomes. J Thorac Oncol. Mar. 2014;9(3):370-6. No separate SCLC data. [pmid: 24518088].
Farjah F, Flum DR, Ramsey SD, et al. Multi-modality mediastinal staging for lung cancer among Medicare beneficiaries. J Thorac Oncol. Mar. 2009;4(3):355-63. Not SCLC. [pmid: 19156000].
Feller-Kopman D, Yung RC, Burroughs F, et al. Cytology of endobronchial ultrasound-guided transbronchial needle aspiration: a retrospective study with histology correlation. Cancer Cytopathol. Dec. 25. 2009;117(6):482-90. Fewer than 10 patients with SCLC. [pmid: 19834962].
Fernandez FG, Kozower BD, Crabtree TD, et al. Utility of mediastinoscopy in clinical stage I lung cancers at risk for occult mediastinal nodal metastases. J Thorac Cardiovasc Surg. Jan. 2015;149(1):35-41. 42.e1. Not SCLC. [pmid: 25439769].
Figueiredo VR, Cardoso PF, Jacomelli M, et al. Endobronchial ultrasound-guided transbronchial needle aspiration for lung cancer staging: early experience in Brazil. Jornal Brasileiro De Pneumologia : Publicaça O Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia. 2015;41(1):23-30. Fewer than 10 patients with SCLC.
Flechsig P, Kratochwil C, Schwartz LH, et al. Quantitative volumetric CT-histogram analysis in N-staging of 18F-FDG-equivocal patients with lung cancer. J Nucl Med. Apr. 1. 2014;55(4):559-64. Epub 2014 Feb 13. Fewer than 10 patients with SCLC. [pmid: 24525209].
Flechsig P, Kratochwil C, Schwartz LH, et al. Quantitative volumetric CT-histogram analysis in N-staging of 18F-FDG-equivocal patients with lung cancer. J Nucl Med. Apr. 1. 2014;55(4):559-64. Epub 2014 Feb 13. Fewer than 10 patients with SCLC. [pmid: 24525209].
Fournel P. Criteria of choice for 1(st) line CT. Rev Pneumol Clin. Nov. 2004;60(5). Not SCLC. [pmid: 15687986].
Fujiwara T, Yasufuku K, Nakajima T, et al. The utility of sonographic features during endobronchial ultrasound-guided transbronchial needle aspiration for lymph node staging in patients with lung cancer: a standard endobronchial ultrasound image classification system. Chest. Sep. 1. 2010;138(3):641-7. No separate SCLC data. [pmid: 20382710].
Fukushima T, Tateishi K, Hanaoka M, et al. Clinical outcomes in patients with small cell lung cancer in a single institute: Comparative analysis of radiographic screening with symptom-prompted patients. Lung Cancer. 2015;88(1):48-51. No outcomes of interest. [pmid: 25703893].
Fukushima T, Tateishi K, Hanaoka M, et al. Clinical outcomes in patients with small cell lung cancer in a single institute: Comparative analysis of radiographic screening with symptom-prompted patients. Lung Cancer. 2015. Feb. 9. Duplicate of already-identified article.
Fusaroli P, Caletti G. Endoscopic ultrasonography. Endoscopy. Jan. 2007;39(1):17-20. Not a study (e.g., review, opinion). [pmid: 17252454].
Garcia-Olive I, Monso E, Andreo F, et al. Sensitivity of linear endobronchial ultrasonography and guided transbronchial needle aspiration for the identification of nodal metastasis in lung cancer staging. Ultrasound Med Biol. Aug. 2009;35(8):1271-7. No separate SCLC data. [pmid: 19540652].
Gerke O, Hermansson R, Hess S, et al. Cost-effectiveness of PET and PET/computed tomography: A systematic review. Pet Clinics. 2015;10(1):105-24. Not SCLC. [pmid: 25455883].
Go SI, Song HN, Kang JH, et al. The clinical impact of the sum of the maximum standardized uptake value on the pretreatment with F-FDG-PET/CT in small-cell lung cancer. Oncology. Jan. 2014;86(1):1-9. Epub 2013 Dec 10. One test of interest, but no data on SCLC staging accuracy. [pmid: 24335538].
Gomez DR, Gladish GW, Wei X, et al. Prognostic value of positron emission tomography/computed tomography findings in limited-stage small cell lung cancer before chemoradiation therapy. Am J Clin Oncol. Feb. 2014;37(1):77-80. One test of interest, but no data on SCLC staging accuracy. [pmid: 23111360].
Graeter TP, Hellwig D, Hoffmann K, et al. Mediastinal lymph node staging in suspected lung cancer: comparison of positron emission tomography with F-18-fluorodeoxyglucose and mediastinoscopy. Ann Thorac Surg. Jan. 1. 2003;75(1):231-6. Fewer than 10 patients with SCLC. [pmid: 12537221].
Grahek D, Tofighi M, Montravers F, et al. 18FDG CDET in staging of lung cancer. Med Nucl. 2000;24(2):99-106. Fewer than 10 patients with SCLC.
Gregory DL, Brennan SM, Stillie A, et al. Impact of 18F-fluorodeoxyglucose positron emission tomography in the staging and treatment response assessment of extra-pulmonary small-cell cancer. J Med Imaging Radiat Oncol. Apr. 2010;54(2):100-7. Not SCLC. [pmid: 20518871].
Guerra L, Meregalli S, Zorz A, et al. Comparative evaluation of CT-based and respiratory-gated PET/CT-based planning target volume (PTV) in the definition of radiation treatment planning in lung cancer: Preliminary results. Eur J Nucl Med Mol Imag. Apr. 2014;41(4):702-10. Fewer than 10 patients with SCLC.
Halter G, Buck AK, Schirrmeister H, et al. Lymph node staging in lung cancer using [18F]FDG-PET. Thorac Cardiovasc Surg. Apr. 2004;52(2):96-101. Not SCLC. [pmid: 15103582].
Halter G, Buck AK, Schirrmeister H, et al. [18F] 3-deoxy-3'-fluorothymidine positron emission tomography: alternative or diagnostic adjunct to 2-[18f]-fluoro-2-deoxy-D-glucose positron emission tomography in the workup of suspicious central focal lesions?. J Thorac Cardiovasc Surg. Apr. 2004;127(4):1093-9. Fewer than 10 patients with SCLC. [pmid: 15052207].
Han TJ, Kim HJ, Wu HG, et al. Comparison of treatment outcomes between involved-field and elective nodal irradiation in limited-stage small cell lung cancer. Jpn J Clin Oncol. Oct. 2012;42(10):948-54. Other: Did not separate data of standalone PET patients from PET/CT patients. [pmid: 22811409].
Harders SW. Lucis: Lung Cancer Imaging Studies. Dan Med J. 2012;59(11):1-30. PMID:. Not a study (e.g., review, opinion).
Hashizume T, Yamada K, Suzuki R, et al. Correlation between clinical characteristics, radiological findings, pathological findings, and prognosis in patients with a peripheral lung adenocarcinoma less than 15 mm in diameter. Jpn J Lung Cancer. Aug. 2005;45(4):311-7. PMID:. Not SCLC.
Hattori A, Suzuki K, Maeyashiki T, et al. The presence of air bronchogram is a novel predictor of negative nodal involvement in radiologically pure-solid lung cancer. Eur J Cardiothorac Surg. Apr. 2014;45(4):699-702. Not SCLC. [pmid: 24135955].
Hattori A, Suzuki K, Matsunaga T, et al. Tumour standardized uptake value on positron emission tomography is a novel predictor of adenocarcinoma in situ for c-Stage IA lung cancer patients with a part-solid nodule on thin-section computed tomography scan. Interact Cardiovasc Thorac Surg. Mar. 2014;18(3):329-34. Not SCLC. [pmid: 24351509].
Hauber HP, Bohuslavizki KH, Lund CH, et al. Positron emission tomography in the staging of small-cell lung cancer: a preliminary study. Chest. 2001;119(3):950-4. Fewer than 10 patients with SCLC. [pmid: 11243980].
Henschke CI, Yankelevitz DF, Miettinen OS. Computed tomographic screening for lung cancer: the relationship of disease stage to tumor size. Arch Intern Med. Feb. 13. 2006;166(3):321-5. One test of interest, but no data on SCLC staging accuracy. [pmid: 16476872].
Herth FJ, Becker HD, Ernst A, et al. Ultrasound-guided transbronchial needle aspiration: an experience in 242 patients. Chest. Feb. 1. 2003;123(2):604-7. No separate SCLC data. [pmid: 12576386].
Herth FJF, Krasnik M, Vilmann P. EBUS-TBNA for the diagnosis and staging of lung cancer. Endoscopy. Jun. Suppl 1. 2006;38:S101-5. Not a study (e.g., review, opinion). [pmid: 16802239].
Herth FJF, Schuler H, Gompelmann D, et al. Endobronchial ultrasound-guided lymph node biopsy with transbronchial needle forceps: a pilot study. Eur Respir J. Feb. 1. 2012;39(2):373-7. Fewer than 10 patients with SCLC. [pmid: 21700609].
Herth R, Becker HD, Manegold C, et al. Endobronchial ultrasound (EBUS)--assessment of a new diagnostic tool in bronchoscopy for staging of lung cancer. Onkologie. Apr. 2001;24(2):151-4. Unclear whether any patients had SCLC. [pmid: 11441295].
Hillner BE, Tosteson AN, Tosteson TD, et al. Intended versus inferred care after PET performed for initial staging in the national oncologic PET registry. J Nucl Med. Dec. 1. 2013;54(12):2024-31. One test of interest, but no data on SCLC staging accuracy. [pmid: 24221994].
Hochstenbag MMH, Twijnstra A, Wilmink JT, et al. Asymptomatic brain metastases (BM) in small cell lung cancer (SCLC): MR-imaging is useful at initial diagnosis. J Neurooncol. 2000;48(3):243-8. One test of interest, but no data on SCLC staging accuracy. [pmid: 11100822].
Hsu LH, Ko JS, You DL, et al. Transbronchial needle aspiration accurately diagnoses subcentimetre mediastinal and hilar lymph nodes detected by integrated positron emission tomography and computed tomography. Respirology. Nov. 2007;12(6):848-55. Not SCLC. [pmid: 17986113].
Hu Y, Puri V, Crabtree TD, et al. Attaining proficiency with endobronchial ultrasound-guided transbronchial needle aspiration. J Thorac Cardiovasc Surg. Dec. 2013;146(6):1387-1392.e1. No separate SCLC data. [pmid: 24075565].
Huang D, Zhang Y, Zhao F, et al. Clinical significance of (99m)Tc-tetrofosmin SPECT in the diagnosis of lung neoplasms and mediastinal lymph node involvement. Chin J Lung Cancer. Feb. 20. 2007;10(1):25-38. No separate SCLC data.
Huang D, Zhang Y, Zhao F, et al. Clinical significance of 99mTc-tetrofosmin SPECT in the diagnosis of lung neoplasms and mediastinal lymph node involvement. Chin J Lung Cancer. Feb. 2007;10(1):25-38. Fewer than 10 patients with SCLC.
Huang GJ, Zhang DC, Mao YS, et al. Comparison of clinical and surgico-pathological TNM stage of 2007 lung cancer patients. Zhonghua Zhong Liu Za Zhi. Sep. 2005;27(9):551-3. No separate SCLC data. [pmid: 16438855].
Huellner MW, Collen TD, Gut P, et al. Multiparametric PET/CT-perfusion does not add significant additional information for initial staging in lung cancer compared with standard PET/CT. EJNMMI Res. 2014;4(1):6. Fewer than 10 patients with SCLC. [pmid: 24450990].
Huellner MW, Collen TD, Gut P, et al. Multiparametric PET/CT-perfusion does not add significant additional information for initial staging in lung cancer compared with standard PET/CT. Ejnmmi Research. 2014;4(1):1-13. Fewer than 10 patients with SCLC. [pmid: 24382020].
Igdem T, Alco G, Ercan T, et al. The application of positron emission tomography/computed tomography in radiation treatment planning: effect on gross target volume definition and treatment management. Clin Oncol (R Coll Radiol). Apr. 2010;22(3):173-8. Fewer than 10 patients with SCLC. [pmid: 20116979].
Imamura F, Kuriyama K, Seto T, et al. Detection of bone marrow metastases of small cell lung cancer with magnetic resonance imaging: early diagnosis before destruction of osseous structure and implications for staging. Mar. 2000;27(3):189-97. Other: Authors analyzed only a component of the full MR imaging procedure. [pmid: 10699692].
Ippolito D, Capraro C, Guerra L, et al. Feasibility of perfusion CT technique integrated into conventional 18FDG/PET-CT studies in lung cancer patients: clinical staging and functional information in a single study. Eur J Nucl Med Mol Imaging. Jan. 2013;40(2):156-65. Epub 2012 Nov 10. Fewer than 10 patients with SCLC. [pmid: 23143661].
Iwano S, Ito S, Tsuchiya K, et al. What causes false-negative PET findings for solid-type lung cancer?. Lung Cancer. Feb. 2013;79(2):132-6. Fewer than 10 patients with SCLC. [pmid: 23177277].
Jacob T, Grahek D, Kerrou K, et al. Usefulness of [18F]-FDOPA pet as an adjunct to [18F]-FDG PET in the imaging of small cell lung carcinoma. Preliminary results. Med Nucl. Jul. 1. 2003;27(7):353-8. Fewer than 10 patients with SCLC.
Jennings SG, Winer-Muram HT, Tann M, et al. Distribution of stage I lung cancer growth rates determined with serial volumetric CT measurements. Radiology. Nov. 2006;241(2):554-63. Epub 2006 Sep 27. Fewer than 10 patients with SCLC. [pmid: 17005771].
Jernlas B, Nyberger H, Ek L, et al. Diagnostic yield and efficacy of endobronchial ultrasound-guided transbronchial needle aspiration in mediastinal lymphadenopathy. Clin Respir J. Apr. 2012;6(2):88-95. One test of interest, but no data on SCLC staging accuracy. [pmid: 21651742].
Jerusalem G, Hustinx R, Beguin Y, et al. The value of positron emission tomography (PET) imaging in disease staging and therapy assessment. Ann Oncol. 2002;13(Suppl 4):227-34. Not a study (e.g., review, opinion). [pmid: 12401695].
Jeyabalan A, Shelley-Fraser G, Medford AR. Impact of needle gauge on characterization of endobronchial ultrasound-guided transbronchial needle aspiration (EBUS-TBNA) histology samples. Respirology. Jul. 2014;19(5):735-9. No separate SCLC data. [pmid: 24697875].
Kamel EM, Kamel EM, McKee TA, et al. Occult lung infarction may induce false interpretation of 18F-FDG PET in primary staging of pulmonary malignancies. Eur J Nucl Med Mol Imaging. Jun. 2005;32(6):641-6. Epub 2005 Feb 22. Unclear whether any patients had SCLC. [pmid: 15726357].
Kamel EM, Zwahlen D, Wyss MT, et al. Whole-body (18)F-FDG PET improves the management of patients with small cell lung cancer. J Nucl Med. Dec. 2003;44(12):1911-7. One test of interest, but no data on SCLC staging accuracy. [pmid: 14660716].
Kamiyoshihara M, Kawashima O, Ishikawa S, et al. Mediastinal lymph node evaluation by computed tomographic scan in lung cancer. J Cardiovasc Surg (Torino). 2001;42(1):119-24. Not SCLC. [pmid: 11292919].
Kandemir O, Karakus K, Katrancioglu O, et al. Semi-quantitative investigation of primary tumor and bone metastasis in lung cancer patients using the PET-CT approach. Int J Clin Exp Med. Sep. 30. 2014;7(9):2624-31. No separate SCLC data. [pmid: 25356118].
Karathanos E, Datseris I, Vlontzou E, et al. Contribution of (99m)Tc-depreotide (Neospect) scintigraphy in lung cancer staging. J BUON. Jan-Mar. 2010;15(1):147-52. None of the modalities of interest. [pmid: 20414943].
Kazawa N, Kitaichi M, Hiraoka M, et al. Small cell lung carcinoma: eight types of extension and spread on computed tomography. J Comput Assist Tomogr. Jul/Aug. 2006;30(4):653-61. One test of interest, but no data on SCLC staging accuracy. [pmid: 16845299].
Kies P, Schober O, Presselt N, et al. What role does FDG-PET play in staging bronchial carcinoma?. Chir Prax. Oct. 2003;62(1):25-8. Not a study (e.g., review, opinion).
Kim HK, Ha SI, Kim YR, et al. The usefulness of ultrasound-guided fine needle aspiration cytology of impalpable neck nodes in patients with lung cancer. Tuberc Respir Dis (Seoul). May. 2004;56(5):505-13. One test of interest, but no data on SCLC staging accuracy.
Kim MA, Lee JC, Choi CM. Bronchial anthracofibrosis and macroscopic tissue pigmentation on EBUS-TBNA predict a low probability of metastatic lymphadenopathy in Korean lung cancer patients. J Korean Med Sci. Mar. 2013;28(3):383-7. Not staging before treatment. [pmid: 23486741].
Kim TJ, Park CM, Goo JM, et al. Is there a role for FDG PET in the management of lung cancer manifesting predominantly as ground-glass opacity?. AJR Am J Roentgenol. Jan. 2012;198(1):83-8. Not SCLC. [pmid: 22194482].
Kirmani BH, Rintoul RC, Win T, et al. Stage migration: results of lymph node dissection in the era of modern imaging and invasive staging for lung cancer. Eur J Cardiothorac Surg. Jan. 2013;43(1):104-10. Not SCLC. [pmid: 22529185].
Kitase M, Hara M, Katoh K, et al. FDG-PET in patient with clinical T1N0 lung cancer; Determination of nodal status. Rinsho Hoshasen. 2000;45(1):209-14. Not SCLC.
Kobayashi T, Tanaka N, Matsumoto T, et al. HRCT findings of small cell lung cancer measuring 30 mm or less located in the peripheral lung. Jpn J Radiol. Feb. 2015;33(2):67-75. No outcomes of interest. [pmid: 25511305].
Krupski W, Zlomaniec J. The usefulness of computed tomography spatial imaging in diagnosing lung tumours. Ann Univ Mariae Curie Sklodowska Med. 2002;57(2):112-8. Not staging before treatment. [pmid: 12898828].
Kushibe K, Kawaguchi T, Nishimoto Y, et al. Operative indications for lung cancer with satellite lesions. Asian Cardiovasc Thorac Ann. Aug. 2006;14(4):316-20. Not SCLC. [pmid: 16868106].
Kut V, Spies W, Spies S, et al. Staging and monitoring of small cell lung cancer using [18F]fluoro-2-deoxy- D-glucose-positron emission tomography (FDG-PET). Am J Clin Oncol. Feb. 2007;30(1):45-50. One test of interest, but no data on SCLC staging accuracy. [pmid: 17278894].
La Fianza A, Pellegrini C, Berton F, et al. Diagnostic imaging of lung cancer after heart transplantation. Tumori. Sep/Oct. 2006;92(5):429-32. Not SCLC. [pmid: 17168437].
Laking G, Price P. 18-Fluorodeoxyglucose positron emission tomography (FDG-PET) and the staging of early lung cancer. Thorax. 2001;56:ii38-44. Not a study (e.g., review, opinion). [pmid: 11514705].
Ladrón de Guevara HD, Furnaro LF, et al. Positron emission tomography/computed tomography for lung cancer staging. Revista Médica De Chil. 2015;143(1):22-9. No separate SCLC data.
Lannes D, Monteiro AS, Toscano E, et al. Transbronchial needle aspiration of hilar and mediastinal lymph nodes. Rev Port Pneumol. Sep/Oct. 2007;13(5):651-8. Not staging before treatment. [pmid: 17962884].
Lee J, Kim JO, Jung CK, et al. Metabolic Activity on [(18)F]-Fluorodeoxyglucose-Positron Emission Tomography/Computed Tomography and Glucose Transporter-1 Expression might predict clinical outcomes in patients with limited disease small-cell lung cancer who receive concurrent chemoradiation. Clin Lung Cancer. Mar. 2014;15(2):e13-e21. Not staging before treatment. [pmid: 24368212].
Lee KJ, Suh GY, Chung MP, et al. Combined endobronchial and transesophageal approach of an ultrasound bronchoscope for mediastinal staging of lung cancer. PLoS ONE. Mar. 14. 2014;9(3). Fewer than 10 patients with SCLC.
Lee KJ, Suh GY, Chung MP, et al. Combined endobronchial and transesophageal approach of an ultrasound bronchoscope for mediastinal staging of lung cancer. Plos One. Mar. 14. 2014;9(3). Fewer than 10 patients with SCLC.
Lee ST, Berlangieri SU, Poon AMT, et al. Prevalence of occult metastatic disease in patients undergoing 18F-FDG PET for primary diagnosis or staging of lung carcinoma and solitary pulmonary nodules. Intern Med J. Nov. 2007;37(11):753-9. Unclear whether any patients had SCLC. [pmid: 17517082].
Lennon AM, Rintoul RC, Penman ID. Competition for EUS (a) EBUS-TBNA (b) video assisted thoracoscopy. Endoscopy. Jun. Suppl 1. 2006;38:S80-3. Not a study (e.g., review, opinion). [pmid: 16802233].
Lesser TG. Endothoracic sonography improves the estimation of operability in locally advanced lung cancer. Ann Thorac Surg. Jul. 2010;90(1):217-21. Not SCLC. [pmid: 20609778].
Letonturier P. What's new in lung cancer. Presse Med. Mar. 2007;36(3 Pt 1):441-3. Not a study (e.g., review, opinion). [pmid: 17436450].
Li S, Zhao B, Wang X, et al. Overestimated value of (18)F-FDG PET/CT to diagnose pulmonary nodules: analysis of 298 patients. Clin Radiol. Aug. 2014;69(8):e352-e357. Fewer than 10 patients with SCLC. [pmid: 24877581].
Liao R, Yang X, Wang B, et al. Diagnosis and staging of mediastinal lymphadenopathy: EBUS-TBNA versus mediastinoscopy. Chin J Clin Oncol. Dec. 30. 2011;38(24):1501-4. Fewer than 10 patients with SCLC.
Lin LF, Huang PT, Tsai MH, et al. Role of endoscopic ultrasound-guided fine-needle aspiration in lung and mediastinal lesions. J Chin Med Assoc. Oct. 2010;73(10):523-9. Fewer than 10 patients with SCLC. [pmid: 21051029].
Lin WY, Hsu WH, Lin KH, et al. Role of preoperative PET-CT in assessing mediastinal and hilar lymph node status in early stage lung cancer. J Chin Med Assoc. May. 2012;75(5):203-8. Fewer than 10 patients with SCLC. [pmid: 22632985].
Liu H, Liu Y, Yu T, et al. Evaluation of apparent diffusion coefficient associated with pathological grade of lung carcinoma, before therapy. J Mag Res Imag. 2014. Dec. 24. Fewer than 10 patients with SCLC.
Liu Q, Peng Z, Liu Q, et al. Comparison of (11)C-choline PET/CT and enhanced CT in the evaluation of patients with pulmonary abnormalities and locoregional lymph node involvement in lung cancer. Clin Lung Cancer. Jul. 2012;13(4):312-20. Fewer than 10 patients with SCLC. [pmid: 22182444].
Liu XG, Wang Y, Liang MZ, et al. The relationship between the peripheral lung cancer and the bronchi, pulmonary artery and vein: a multislice helical CT observation. Chin J Radiol. Jun. 2008;42(6):592-6. No separate SCLC data.
Luo J, Ni J, Zheng H, et al. Clinical analysis of 88 cases with combined small cell carcinoma. Feb. 2009;29(2):156-9. No outcomes of interest.
Mall JW, Schwenk W, Philipp AW, et al. Serum vascular endothelial growth factor levels correlate better with tumour stage in small cell lung cancer than albumin, neuron-specific enolase or lactate dehydrogenase. Respirology. 2002;7(2):99-102. One test of interest, but no data on SCLC staging accuracy. [pmid: 11985730].
Matsuguma H, Yokoi K, Anraku M, et al. Proportion of ground-glass opacity on high-resolution computed tomography in clinical T1 N0 M0 adenocarcinoma of the lung: A predictor of lymph node metastasis. J Thorac Cardiovasc Surg. Aug. 2002;124(2):278-84. Not SCLC. [pmid: 12167787].
Maya Martinez M, Carrion Valero F, Diaz Lopez J, et al. Influence of computed tomography of the abdomen for staging lung cancer. Arch Bronconeumol. Mar. 2002;38(3):123-9. Other: Outdated CT. [pmid: 11900689].
Mazzone PJ, Marchi N, Fazio V, et al. Small vessel ischemic disease of the brain and brain metastases in lung cancer patients. PLoS ONE. Sep. 30. 2009;4(9):e7242. Unclear whether any patients had SCLC. [pmid: 19789633].
Meyers BF, Haddad F, Siegel BA, et al. Cost-effectiveness of routine mediastinoscopy in computed tomography- and positron emission tomography-screened patients with stage I lung cancer. J Thorac Cardiovasc Surg. Apr. 2006;131(4). Not SCLC. [pmid: 16580440].
Mezzetti M, Calati AM, Schubert L, et al. Positron emission-computed tomography in diagnosis and staging of lung neoplasms. Personal experience. Minerva Chir. 2002;57(4):461-5. None of the modalities of interest. [pmid: 12145576].
Min JW, Um SW, Yim JJ, et al. The role of whole-body FDG PET/CT, Tc 99m MDP bone scintigraphy, and serum alkaline phosphatase in detecting bone metastasis in patients with newly diagnosed lung cancer. J Korean Med Sci. Apr. 2009;24(2):275-80. No separate SCLC data. [pmid: 19399270].
Mohan A, Naik S, Pandey RM, et al. Diagnostic utility of endobronchial ultrasound guided transbronchial needle aspiration for mediastinal lesions: a prospective three year, single centre analysis. Thorac Cancer. Nov. 2011;2(4):183-9. One test of interest, but no data on SCLC staging accuracy.
Moodie K, Cherk M, Lau E, et al. Evaluation of pulmonary nodules and lung cancer with one-inch crystal gamma coincidence positron emission tomography/CT versus dedicated positron emission tomography/CT. J Med Imaging Radiat Oncol. Feb. 2009;53(1):32-9. Unclear whether any patients had SCLC. [pmid: 19453526].
Morimoto D, Takashima S, Sakashita N, et al. Differentiation of lung neoplasms with lepidic growth and good prognosis from those with poor prognosis using computer-aided 3D volumetric CT analysis and FDG-PET. Acta Radiol. Jun. 2014;55(5):563-9. Not SCLC. [pmid: 24003260].
Mortensen J, Enevoldsen H, Friberg L, et al. 4. Preliminary findings of a prospective study of FDG-PET in patients with possible lung cancer. Clin Positron Imaging. Jul. 2000;3(4):158. Other: Not a full length paper (e.g., abstract, poster). [pmid: 11150761].
Mortensen J, Enevoldsen H, Friberg L, et al. Preliminary Findings of a Prospective Study of FDG-PET in Patients with Possible Lung Cancer. Clinical Positron Imaging: Official Journal Of The Institute For Clinical P.E.T. Jul. 2000;3(4):158. Not a full length paper (e.g., abstract, poster). [pmid: 11150761].
Murakami Y, Oki M, Saka H, et al. Endobronchial ultrasound-guided transbronchial needle aspiration in the diagnosis of small cell lung cancer. Respir Investig. May. 2014;52(3):173-8. Not staging before treatment.
Nabil H, Maher KM, Mahdy SAR. Follow up in chest tumors: value of integrated PET/CT. Egypt J Radiol Nucl Med. Sep. 2014;45(3):679-88. Fewer than 10 patients with SCLC.
Nabil H, Maher KM, Mahdy SAR. Follow up in chest tumors: value of integrated PET/CT. Egypt J Radiol Nucl Med. Sep. 2014;45(3):679-88. Fewer than 10 patients with SCLC.
Nanguzgambo AB, Aubeelack K, Von Groote-Bidlingmaier F, et al. Radiologic features, staging, and operability of primary lung cancer in the Western cape, South Africa: a 1-year retrospective study. J Thorac Oncol. Feb. 2011;6(2):343-50. One test of interest, but no data on SCLC staging accuracy. [pmid: 21173714].
Natu S, Hoffman J, Siddiqui M, et al. The role of endobronchial ultrasound guided transbronchial needle aspiration cytology in the investigation of mediastinal lymphadenopathy and masses, the North Tees experience. J Clin Pathol. May. 2010;63(5):445-51. One test of interest, but no data on SCLC staging accuracy. [pmid: 20299387].
Niho S, Fujii H, Murakami K, et al. Detection of unsuspected distant metastases and/or regional nodes by FDG-PET [corrected] scan in apparent limited-disease small-cell lung cancer. Lung Cancer. Sep. 2007;57(3):328-33. Epub 2007 May 29. One test of interest, but no data on SCLC staging accuracy. [pmid: 17537538].
Nomori H, Ohtsuka T, Naruke T, et al. Histogram analysis of computed tomography numbers of clinical T1 N0 M0 lung adenocarcinoma, with special reference to lymph node metastasis and tumor invasiveness. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1584-9. Not SCLC. [pmid: 14666037].
Oturai PS, Mortensen J, Enevoldsen H, et al. Gamma-camera 18F-FDG PET in diagnosis and staging of patients presenting with suspected lung cancer and comparison with dedicated PET. J Nucl Med. Aug. 2004;45(8):1351-7. Fewer than 10 patients with SCLC. [pmid: 15299061].
Ouboukdir R, Ghfir I, Rais NB. Bone scintigraphy with 99mTc-HMDP in the staging of lung cancer - about 136 cases. Med Nucl. Apr. 2011;35(4):219-23. One test of interest, but no data on SCLC staging accuracy.
Ost DE, Niu J, Elting LS, et al. Quality gaps and comparative effectiveness in lung cancer staging and diagnosis. Chest. Feb. 2014;145(2):331-45. No outcomes of interest. [pmid: 24091637].
Ozgul MA, Cetinkaya E, Tutar N, et al. Endobronchial ultrasound-guided transbronchial needle aspiration for the diagnosis of intrathoracic lymphadenopathy in patients with extrathoracic malignancy: a study in a tuberculosis-endemic country. J Cancer Res Ther. Jul-Sep. 2013;9(3):416-21. Not SCLC. [pmid: 24125976].
Pandit N, Gonen M, Krug L, et al. Prognostic value of [18F]FDG-PET imaging in small cell lung cancer. Eur J Nucl Med Mol Imaging. Jan. 1. 2003;30(1):78-84. Epub 2002 Oct 31. One test of interest, but no data on SCLC staging accuracy. [pmid: 12483413].
Pauls S, Aschoff AJ, Wahl J, et al. Multi-detector row CT: is prospective electrocardiographic triggering improving the detection of small pulmonary tumors?. Acad Radiol. May. 2005;12(5):614-9. Unclear whether any patients had SCLC. [pmid: 15866135].
Pauls S, Schmidt SA, Juchems MS, et al. Diffusion-weighted MR imaging in comparison to integrated [(18)F]-FDG PET/CT for N-staging in patients with lung cancer. Eur J Radiol. Jan. 2012;81(1):178-82. Epub 2010 Oct 6. Fewer than 10 patients with SCLC. [pmid: 20932700].
Pitman AG, Hicks RJ, Binns DS, et al. Performance of sodium iodide based (18)F-fluorodeoxyglucose positron emission tomography in the characterization of indeterminate pulmonary nodules or masses. Br J Radiol. 2002;75(890):114-21. Fewer than 10 patients with SCLC. [pmid: 11893634].
Rakheja R, Ko JP, Friedman K. Lung cancer: positron emission tomography/computed tomography and the new staging system. Semin Roentgenol. Oct. 2013;48(4):308-22. Not a study (e.g., review, opinion). [pmid: 24034263].
Razek AA, Fathy A, Gawad TA. Correlation of apparent diffusion coefficient value with prognostic parameters of lung cancer. J Comput Assist Tomogr. Mar-Apr. 2011;35(2):248-52. Fewer than 10 patients with SCLC. [pmid: 21412099].
Remiszewski P, RoszkowskiSliz K, Wiatr E, et al. Prognosis in limited disease (LD) small cell lung cancer (SCLC) patients (PTS) according to status performance, local extension of lesions, type of treatment and the completeness of staging. Pneumonol Alergol Pol. 2003;71(3):139-47. No outcomes of interest. [pmid: 14587419].
Ridge CA, Huang J, Cardoza S, et al. Comparison of multiplanar reformatted CT lung tumor measurements to axial tumor measurement alone: impact on maximal tumor dimension and T stage. AJR Am J Roentgenol. Nov. 2013;201(5):959-63. Not SCLC. [pmid: 24147464].
Rintoul RC. Towards complete endoscopic staging of the mediastinum?. Endoscopy. Jun. Suppl 1. 2006;38:S110-3. Not a study (e.g., review, opinion). [pmid: 16802241].
Rintoul RC, Tournoy KG, El Daly H, et al. EBUS-TBNA for the clarification of PET positive intra-thoracic lymph nodes-an international multi-centre experience. J Thorac Oncol. Jan. 2009;4(1):44-8. Fewer than 10 patients with SCLC. [pmid: 19096305].
Roman MR, Rossleigh MA, Angelides S, et al. Staging and managing lung tumors using F-18 FDG coincidence detection. Clin Nucl Med. 2001;26(5):383-8. Fewer than 10 patients with SCLC. [pmid: 11317014].
Saadati K, Hashemzade S, Izadi S. The use of surgical methods in lung cancer staging and its impact on selection of treatment in 100 patients with lung cancer in Imam Khomeini hospital of Tabriz, Iran. J Zanjan Univ Med Sci Health Serv. 2014;23(97):14-20. Fewer than 10 patients with SCLC.
Sahiner I, Atasever T, Akdemir UO, et al. Relationship between primary lesion metabolic parameters and clinical stage in lung cancer. Rev Esp Med Nucl Imagen Mol. Nov-Dec. 2013;32(6):357-63. One test of interest, but no data on SCLC staging accuracy. [pmid: 23747221].
Saisho S, Yasuda K, Maeda A, et al. Role of 2-[18F]fluoro-2-deoxyglucose positron emission tomography in preoperative management of solid-type small-sized lung cancer. Ann Nucl Med. Jul. 2013;27(6):515-22. Fewer than 10 patients with SCLC. [pmid: 23504519].
de Cos Escuin JS, Menna DM, Gonzalez MA, et al. Silent brain metastasis in the initial staging of lung cancer. Evaluation by computed tomography and magnetic resonance imaging. Arch Bronconeumol. Jul. 2007;43(7):386-91. No separate SCLC data. [pmid: 17663891].
Sanchez de Cos Escuin J, Serra Mitjans M, Hernandez Hernandez J, et al. The Spanish Society of Pulmonology and Thoracic Surgery Lung Cancer Cooperative Group-II registry. A descriptive study. Arch Bronconeumol. Nov. 2013;49(11):462-7. Epub 2013 Jul 6. No separate SCLC data. [pmid: 23838409].
Sanz-Santos J, Andreo F, Sanchez D, et al. Usefulness of a lung cancer rapid diagnosis specialist clinic. Contribution of ultrasound bronchoscopy. Arch Bronconeumol. Dec. 2010;46(12):640-5. No separate SCLC data. [pmid: 20888680].
Sarwate D, Sarkar S, Krimsky WS, et al. Optimization of mediastinal staging in potential candidates for stereotactic radiosurgery of the chest. J Thorac Cardiovasc Surg. Jul. 2012;144(1):81-5. Not SCLC. [pmid: 22498085].
Sas-Korczynska B, Wojcik E, Luczynska E, et al. The diagnosis of limited stage small-cell lung cancer. Contemp Oncol (Pozn). 2008;12(1):1-5. No outcomes of interest.
Schmid RA, Hautmann H, Poellinger B, et al. Staging of recurrent and advanced lung cancer with 18F-FDG PET in a coincidence technique (hybrid PET). Nucl Med Commun. Jan. 2003;24(1):37-45. Fewer than 10 patients with SCLC. [pmid: 12501018].
Schmid-Bindert G, Henzler T, Chu TQ, et al. Functional imaging of lung cancer using dual energy CT: how does iodine related attenuation correlate with standardized uptake value of 18FDG-PET-CT?. Eur Radiol. Jan. 2012;22(1):93-103. Other: More than 3 weeks elapsed between imaging tests. [pmid: 21822784].
Schmid-Bindert G, Jiang H, Kahler G, et al. Predicting malignancy in mediastinal lymph nodes by endobronchial ultrasound: a new ultrasound scoring system. Respirology. Nov. 2012;17(8):1190-98. Not SCLC. [pmid: 22789110].
Schneider J. Early detection of lung cancers - Comparison of computed tomography, cytology and fuzzy-based tumor markers panels. Cancer Biomark. 2009;6(3):149-62. Not a study (e.g., review, opinion). [pmid: 20660961].
Schumacher T, Brink I, Mix M, et al. FDG-PET imaging for the staging and follow-up of small cell lung cancer. Eur J Nucl Med. 2001;28(4):483-8. One test of interest, but no data on SCLC staging accuracy. [pmid: 11357499].
Schwartz LE, Aisner DL, Baloch ZW, et al. The diagnostic efficacy of combining bronchoscopic tissue biopsy and endobronchial ultrasound-guided transbronchial needle aspiration for the diagnosis of malignant lesions in the lung. Diagn Cytopathol. Nov. 2013;41(11):929-35. No separate SCLC data. [pmid: 22362678].
Schwenzer NF, Schraml C, Muller M, et al. Pulmonary lesion assessment: comparison of whole-body hybrid MR/PET and PET/CT imaging - pilot study. Radiology. Aug. 2012;264(2):551-8. Not SCLC. [pmid: 22653189].
Seemann MD, Schaefer JF, Englmeier KH. Virtual positron emission tomography/computed tomography-bronchoscopy: possibilities, advantages and limitations of clinical application. Eur Radiol. Mar. 2007;17(3):709-15. Not SCLC. [pmid: 16909219].
Seidel C, Hambsch P, Hering K, et al. Analysis of frequency of deep white matter metastasis on cerebral MRI. J Neuro-Oncology. 2015;123(1):135-9. No outcomes of interest.
Shetty CM, Lakhkar BN, Gangadhar VSS, et al. Changing pattern of bronchogenic carcinoma: a statistical variation or a reality?. Indian J Radiol Imaging. May. 2005;15(2):233-8. Not staging before treatment.
Shibata H, Nomori H, Uno K, et al. 11C-acetate for positron emission tomography imaging of clinical stage IA lung adenocarcinoma: comparison with 18F-fluorodeoxyglucose for imaging and evaluation of tumor aggressiveness. Ann Nucl Med. Sep. 2009;23(7):609-16. Not SCLC. [pmid: 19562438].
Shinozaki T, Utano K, Fujii H, et al. Routine use of dual time (18)F-FDG PET for staging of preoperative lung cancer: does it affect clinical management?. Jpn J Radiol. Aug. 2014;32(8):476-81. Fewer than 10 patients with SCLC. [pmid: 24866251].
Shinozaki T, Utano K, Fujii H, et al. Routine use of dual time (18)F-FDG PET for staging of preoperative lung cancer: does it affect clinical management?. Jpn J Radiol. Aug. 2014;32(8):476-81. Fewer than 10 patients with SCLC. [pmid: 24866251].
Shirvani SM, Komaki R, Heymach JV, et al. Positron emission tomography/computed tomography-guided intensity-modulated radiotherapy for limited-stage small-cell lung cancer. Int J Radiat Oncol Biol Phys. Jan. 1. 2012;82(1):e91-7. Epub 2011 Apr 12. One test of interest, but no data on SCLC staging accuracy. [pmid: 21489716].
Shweihat YR, Samant RS, Joshi M, et al. Endobronchial ultrasound-guided transbronchial needle aspiration in a geographical region with endemic histoplasmosis infection. J Bronchol Intervent Pulmonol. Oct. 2010;17(4):295-300. Fewer than 10 patients with SCLC.
Singh P, Camazine B, Jadhav Y, et al. Endoscopic ultrasound as a first test for diagnosis and staging of lung cancer: a prospective study. Am J Respir Crit Care Med. Feb. 15. 2007;175(4):345-54. Not SCLC. [pmid: 17068326].
Soja J, Szlubowski A, Kocon P, et al. Usefulness of transbronchial needle aspiration for initial lung cancer staging. Pol Arch Med Wewn. Jul-Aug. 2010;120(7):264-9. None of the modalities of interest. [pmid: 20693956].
Stewart AG. Routine PET for early lung cancer. Thorax. Mar. 2010;65(3):279. Not a study (e.g., review, opinion).
Sun JY, Zhao H, Zhang J, et al. First 30 endobronchial ultrasound-guided transbronchial needle aspirations: a single institution's early experience. Chin Med J. Jun. 2011;124(12):1818-23. Fewer than 10 patients with SCLC. [pmid: 21740839].
Sun R, Chen QS, Cai L, et al. Value of 18F-FDG PET/CT in staging and prognosis prediction of patients with small cell lung cancer. Chinese Journal of Medical Imaging Technology. Apr. 2011;27(4):743-6. Not staging before treatment.
Suzuki K, Yamamoto M, Hasegawa Y, et al. Magnetic resonance imaging and computed tomography in the diagnoses of brain metastases of lung cancer. Lung Cancer. Dec. 2004;46(3):357-60. Other: CT was single detector, and no accuracy data on MRI. [pmid: 15541821].
Szlubowski A, Soja J, Kocon P, et al. A comparison of the combined ultrasound of the mediastinum by use of a single ultrasound bronchoscope versus ultrasound bronchoscope plus ultrasound gastroscope in lung cancer staging: a prospective trial. Interact Cardiovasc Thorac Surg. Sep. 2012;15(3):442-6. Epub 2012 May 23. Other: Less than 10 SCLC patients for each modality. [pmid: 22623626].
Szlubowski A, Kuzdzal J, Pankowski J, et al. Ultrasound guided transbronchial needle aspiration as a diagnostic tool for lung cancer and sarcoidosis. Pneumonol Alergol Pol. 2008;76(4):229-36. Fewer than 10 patients with SCLC. [pmid: 18785127].
Tamura M, Oda M, Matsumoto I, et al. Radiologic and nuclear medicine predictors of tumor invasiveness in patients with clinical stage IA lung adenocarcinoma. World J Surg. Sep. 2011;35(9):2010-5. Not SCLC. [pmid: 21633846].
Tanaka R, Horikoshi H, Yoshida T, et al. Diffusion-weighted magnetic resonance imaging in differentiating the invasiveness of small lung adenocarcinoma. Acta Radiol. Sep. 1. 2011;52(7):750-5. Not SCLC. [pmid: 21565888].
Taneja S, Talwar V, Jena A, et al. Incidence of asymptomatic brain metastasis in lung cancer patients at initial staging work-up - a study of 211 cases. J Indian Acad Clin Med. Oct-Dec. 2007;8(4):312-5. One test of interest, but no data on SCLC staging accuracy.
Tatci E, Ozmen O, Gokcek A, et al. 18F-FDG PET/CT rarely provides additional information other than primary tumor detection in patients with pulmonary carcinoid tumors. Ann Thorac Med. Oct. 1. 2014;9(4):227-31. Not SCLC. [pmid: 25276242].
Taulelle M. Lung cancer. Rev Mal Respir. Jun. 2004;21(4):5S54-5S61. Not a study (e.g., review, opinion).
Thatcher N, Faivre-Finn C, Blackhall F, et al. Small Cell Lung Cancer (SCLC); any progress?. Eur J Cancer Suppl. Sep. 2007;5(5):398-9. Not a study (e.g., review, opinion).
Uemura S, Yasuda I, Kato T, et al. Preoperative routine evaluation of bilateral adrenal glands by endoscopic ultrasound and fine-needle aspiration in patients with potentially resectable lung cancer. Endoscopy. 2013;45(3):195-201. Fewer than 10 patients with SCLC. [pmid: 23299524].
Ulger S, Demirci NY, Aydinkarahaliloglu E, et al. PET-CT guided curative conformal radiation therapy in limited stage small cell lung cancer. J Thorac Dis. 2015;7(3):295-302. Not staging before treatment. [pmid: 25922706].
Ulger S, Demirci NY, Aydinkarahaliloglu E, et al. PET-CT guided curative conformal radiation therapy in limited stage small cell lung cancer. J Thorac Dis. 2015;7(3):295-302. Duplicate of already-identified article. [pmid: 25922706].
Uramoto H, Sugio K, Nakata S, et al. Clinical usefulness of FDG-PET in the diagnosis of lung cancer. Jpn J Lung Cancer. Apr. 2006;46(2):127-31. Fewer than 10 patients with SCLC.
Usuda K, Sagawa M, Motono N, et al. Relationships between EGFR mutation status of lung cancer and preoperative factors - are they predictive?. Asian Pac J Cancer Prev. 2014;15(2):657-62. Fewer than 10 patients with SCLC. [pmid: 24568474].
Vaccarili M, Lococo A, Fabiani F, et al. Clinical diagnostic application of 111In-DTPA-octreotide scintigraphy in small cell lung cancer. Tumori. May/Jun. 2000;86(3):224-8. None of the modalities of interest. [pmid: 10939603].
van Loon J, De Ruysscher D, Wanders R, et al. Selective nodal irradiation on basis of (18)FDG-PET scans in limited-disease small-cell lung cancer: a prospective study. Int J Radiat Oncol Biol Phys. Jun. 1. 2010;77(2):329-36. Treatment study. [pmid: 19782478].
van Loon J, Offermann C, Bosmans G, et al. 18FDG-PET based radiation planning of mediastinal lymph nodes in limited disease small cell lung cancer changes radiotherapy fields: a planning study. Radiother Oncol. Apr. 2008;87(1):49-54. Epub 2008 Mar 14. One test of interest, but no data on SCLC staging accuracy. [pmid: 18342967].
Van Overhagen H, Brakel K, Heijenbrok MW, et al. Metastases in supraclavicular lymph nodes in lung cancer: assessment with palpation, US, and CT. Radiology. Jul. 2004;232(1):75-80. No separate SCLC data. [pmid: 15166326].
Vansteenkiste J, Dooms C, Becker H, et al. Staging procedures. Eur J Cancer Suppl. Oct. 2005;3(3):7-19. Not a study (e.g., review, opinion).
Varadarajulu S, Schmulewitz N, Wildi SF, et al. Accuracy of EUS in staging of T4 lung cancer. Gastrointest Endosc. Mar. 2004;59(3):345-8. Not SCLC. [pmid: 14997129].
Veronesi G, Maisonneuve P, Pelosi G, et al. Screening-detected lung cancers: is systematic nodal dissection always essential?. J Thorac Oncol. Mar. 2011;6(3):525-30. Fewer than 10 patients with SCLC. [pmid: 21289523].
Vilmann P, Krasnik M, Larsen SS, et al. Transesophageal endoscopic ultrasound-guided fine-needle aspiration (EUS-FNA) and endobronchial ultrasound-guided transbronchial needle aspiration (EBUS-TBNA) biopsy: a combined approach in the evaluation of mediastinal lesions. Endoscopy. Sep. 2005;37(9):833-9. Not SCLC. [pmid: 16116534].
Vincent BD, El-Bayoumi E, Hoffman B, et al. Real-time endobronchial ultrasound-guided transbronchial lymph node aspiration. Ann Thorac Surg. Jan. 2008;85(1):224-30. Fewer than 10 patients with SCLC. [pmid: 18154815].
Viney RC, Boyer MJ, King MT, et al. Staging lung cancer using positron emission tomography and the impact on care. J Clin Outcome Manag. Aug. 2004;11(8):486-8. Not a study (e.g., review, opinion).
Vinjamuri M, Craig M, Campbell-Fontaine A, et al. Can positron emission tomography be used as a staging tool for small-cell lung cancer?. Clin Lung Cancer. Jan. 2008;9(1):30-4. Other: Clinical diagnosis reported only for select cases. [pmid: 18282355].
Wang Memoli JS, El Bayoumi E, Pastis NJ, et al. Using endobronchial ultrasound features to predict lymph node metastasis in patients with lung cancer. Chest. Dec. 2011;140(6):1550-6. Fewer than 10 patients with SCLC. [pmid: 21636663].
Wang F, Ma S, Shen L, et al. Application of (18)F-FDG PET/CT in pulmonary disease: a report of 419 cases. Chin J Lung Cancer. 2012;15(1):21-6. No separate SCLC data. [pmid: 22237120].
Wang L, Hayes S, Paskalev K, et al. Dosimetric comparison of stereotactic body radiotherapy using 4D CT and multiphase CT images for treatment planning of lung cancer: evaluation of the impact on daily dose coverage. Radiother Oncol. Jun. 2009;91(3):314-24. Not SCLC. [pmid: 19111362].
Wardeh R, Lee JG, Gu M. Endoscopic ultrasound-guided paracentesis of ascitic fluid: a morphologic study with ultrasonographic correlation. Cancer Cytopathol. Feb. 25. 2011;119(1):27-36. Fewer than 10 patients with SCLC. [pmid: 21072835].
Williamson S. Lung cancer diagnosis and management. Pharm Pract. Nov/Dec. 2008;18(8):265-71. Not a study (e.g., review, opinion).
Wong R. Are symptoms reliable as an indication for the necessity of bone scans in lung cancer metastases?. Nat Clin Pract Oncol. Nov. 2004;1(1):18-9. Not a study (e.g., review, opnion). [pmid: 16264792].
Xanthopoulos EP, Corradetti MN, Mitra N, et al. Impact of PET staging in limited-stage small-cell lung cancer. J Thorac Oncol. Jul. 2013;8(7):899-905. One test of interest, but no data on SCLC staging accuracy. [pmid: 23608814].
Yang RM, Li L, Wei XH, et al. Differentiation of central lung cancer from atelectasis: comparison of diffusion-weighted MRI with PET/CT. PLoS ONE. Apr. 4. 2013;8(4):e60279. Fewer than 10 patients with SCLC. [pmid: 23593186].
Yasufuku K, Chiyo M, Koh E, et al. Endobronchial ultrasound guided transbronchial needle aspiration for staging of lung cancer. Lung Cancer. Dec. 2005;50(3):347-54. No separate SCLC data. [pmid: 16171897].
Yasufuku K, Nakajima T, Motoori K, et al. Comparison of endobronchial ultrasound, positron emission tomography, and CT for lymph node staging of lung cancer. Chest. Sep. 2006;130(3):710-8. Fewer than 10 patients with SCLC. [pmid: 16963667].
Yildirim D, Tamam M, Sanli Y, et al. Virtual bronchoscopy using FDG-PET/CT images for the evaluation of lung cancer. Eur Rev Med Pharmacol Sci. 2012;16(14):1951-60. Unclear whether any patients had SCLC. [pmid: 23242722].
Yue L, Sun LL. Clinical application of CT eight-type classification of small cell lung cancer. Chin J Intervent Imaging Ther. Jun. 2012;9(6):459-62. One test of interest, but no data on SCLC staging accuracy.
Zhang J, Cui LB, Tang X, et al. DW MRI at 3.0 T versus FDG PET/CT for detection of malignant pulmonary tumors. Int J Cancer. 2013;134(3):606-11. No separate SCLC data. [pmid: 23893610].
Zhao Y, De Bock GH, Vliegenthart R, et al. Performance of computer-aided detection of pulmonary nodules in low-dose CT: comparison with double reading by nodule volume. Eur Radiol. Oct. 2012;22(10):2076-84. Not SCLC. [pmid: 22814824].
Zimny M, Hochstenbag M, Lamers R, et al. Mediastinal staging of lung cancer with 2-[fluorine-18]-fluoro-2-deoxy-D-glucose positron emission tomography and a dual-head coincidence gamma camera. Eur Radiol. Apr. 1. 2003;13(4):740-7. Epub 2002 Sep 7. Fewer than 10 patients with SCLC. [pmid: 12664112].