# Search Strategy

## Search Strategies

The strategy below is presented in EMBASE syntax; the search was simultaneously conducted across EMBASE and MEDLINE. A similar strategy was used to search the databases comprising the Cochrane Library, and PubMed.

EMBASE/MEDLINE (2000–2014)

Set Number | Concept | Search Statement | Retrieval
1 | Small cell lung cancer | ‘small cell lung carcinoma’/exp OR ‘small cell lung carcinoma’ OR ‘carcinoma small cell’/exp OR ‘carcinoma small cell’ OR ‘lung small cell cancer’:de AND [2000-2014]/py | 20,124
2 | Small cell lung cancer | ‘small-cell lung cancer’ OR ‘small cell lung cancer’ OR ‘oat cell’ OR sclc AND [2000-2014]/py | 71,843
3 | Small cell lung cancer | #1 OR #2 | 75,550
4 | Small cell lung cancer | #3 NOT (‘non-small cell’:ti OR ‘non-small-cell’:ti OR ‘non small cell’:ti OR ‘nonsmall cell’:ti OR nsclc:ti) AND [2000-2014]/py | 44,281
5 | Lung Symptoms | ‘lung disease’/mj OR ‘lung tumor’/mj AND [2000-2014]/py | 24,811
6 | Lung Symptoms | lung*:ti OR pulmonary:ti OR bronch*:ti OR chest:ti AND (age*:ab,ti OR smok*:ab,ti OR symptom*:ab,ti OR wheez*:ab,ti OR cough*:ab,ti OR edema:ab,ti OR fibrosis:ab,ti OR asthma:ab,ti OR ‘shortness of breath’:ab,ti OR pain*:ab,ti OR nodule*:ab,ti) | 130,089
7 | Lung Symptoms | #5 OR #6 | 147,159
8 | Lung Symptoms | #7 NOT (‘non-small cell’:ti OR ‘non-small-cell’:ti OR ‘non small cell’:ti OR ‘nonsmall cell’:ti OR nsclc:ti) AND [2000-2014]/py | 133,916
9 | Imaging | ‘computer assisted tomography’/exp OR ‘emission tomography’/de OR ‘nuclear magnetic resonance imaging’/exp OR ‘diagnostic imaging’/exp OR ‘tomography’/de OR ‘respiratory-gated imaging’ OR ‘bone scintiscanning’ AND [2000-2014]/py | 910,744
10 | Imaging | pet NEXT/1 ct OR sdct:ab,ti OR mdct:ab,ti OR mri:ab,ti OR ct:ab,ti OR cat:ab,ti OR pet:ab,ti OR fdg NEAR/1 pet OR ‘computed tomography’:ab,ti OR ‘positron emission’:ab,ti OR ‘magnetic resonance’:ab,ti OR multislice:ab,ti OR ‘multi slice’:ab,ti OR bone NEXT/2 scan* AND [2000-2014]/py | 704,685
11 | Imaging | ‘endosonography’/exp OR ‘endosonography’ OR ‘eus’ OR endoscop* NEXT/1 (ultrasound OR ultrasonography* OR echograph*) AND [2000-2014]/py | 22,797
12 | Imaging | ‘endobronchial ultrasonography’/exp OR ‘endobronchial echography’ OR ‘endobronchial ultrasound’ OR ‘ebus’/exp OR ‘ebus’ OR endobronch* NEXT/1 (ultrasound OR ultrasonography* OR echograph*) AND [2000-2014]/py | 2,889
13 | Imaging | #9 OR #10 OR #11 OR #12 | 1,129,897
14 | Pretreatment staging and planning | ‘cancer classification’/mj OR ‘cancer classification’ OR ‘cancer staging’/exp OR cancer NEAR/2 stag* AND [2000-2014]/py | 170,380
15 | Pretreatment staging and planning | (cancer OR tumor* OR tumour* OR mass* OR neoplasm*) NEAR/2 (stage OR staging OR class*) AND [2000-2014]/py | 194,534
16 | Pretreatment staging and planning | ‘pre-treatment’:ab,ti OR pretreatment:ab,ti OR ‘pretreatment’ NEXT/2 staging OR ‘pre-treatment’ NEXT/2 plan* AND [2000-2014]/py | 114,512
17 | Pretreatment staging and planning | #14 OR #15 OR #16 | 307,057
18 | Prognosis | ‘cancer prognosis’/exp OR ‘cancer prognosis’ OR prognos* OR predict* OR outcome* OR ‘survival’/de OR survival OR ‘quality of life’/de OR ‘quality of life’ OR qol AND [2000-2014]/py | 3,322,222
19 | Combine Small Cell Lung Cancer AND Imaging | #4 AND #13 | 8,415
20 | Combine Lung Symptoms AND Imaging | #7 AND #13 | 33,186
21 | Combine SCLC AND Imaging AND Pretreatment staging and planning (KQ 1) | #17 AND #19 | 2,470
22 | Combine Lung Symptoms AND Imaging AND Pretreatment staging and planning (KQ 1) | #17 AND #20 | 2,860
23 | Combine SCLC AND Imaging AND Pretreatment staging and planning AND prognosis (KQ 2) | #18 AND #21 | 1,412
24 | Combine Lung Symptoms AND Imaging AND Pretreatment staging and planning AND prognosis (KQ 2) | #18 AND #22 | 1,694
25 | Combine final sets | #21 OR #22 OR #23 OR #24 | 4,660
26 | Apply limits | #25 AND [humans]/lim AND [2000-2014]/py | 4,442
27 | Limit by publication and study type | #26 AND (‘clinical article’/exp OR ‘clinical article’ OR ‘clinical trial’/exp OR ‘clinical trial’ OR ‘controlled study’/exp OR ‘controlled study’ OR ‘intermethod comparison’/exp OR ‘intermethod comparison’ OR ‘major clinical study’/exp OR ‘major clinical study’ OR ‘retrospective study’/exp OR ‘retrospective study’) | 2,029
28 | Guidelines | #26 AND (‘practice guideline’/exp OR ‘practice guideline’ OR ‘professional standard’:de OR ‘practice parameter’ OR ‘position statement’ OR ‘position paper’ OR ‘policy statement’ OR standard*:ti OR guideline*:ti OR ‘white paper’ OR ‘clinical pathway’/exp OR ‘clinical pathway’ OR ‘clinical guideline’ OR ‘consensus development’/exp OR ‘consensus development’) | 218
29 | Systematic Reviews | #26 AND (‘research synthesis’ OR pooled OR ‘systematic review’/de OR ‘meta analysis’/de OR (‘evidence base’ OR ‘evidence based’ OR methodol* OR systematic OR quantitative* OR studies OR search* AND (‘review’/de OR review/it))) | 340
30 | Remove unwanted publication types | #26 NOT (‘conference abstract’/it OR ‘conference paper’/it OR ‘editorial’/it OR ‘letter’/it OR ‘note’/it OR ‘case report’/de) | 2,632
31 | Combine final sets | #27 OR #28 OR #29 OR #30 | 2,931

EMBASE.com Syntax

* | = truncation character (wildcard)
NEAR/n | = search terms within a specified number (n) of words from each other in any order
NEXT/n | = search terms within a specified number (n) of words from each other in the order specified
/ | = search as a subject heading
exp | = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
mj | = denotes a term that has been searched as a major subject heading
:de | = search in the descriptors field
:lnk | = floating subheading
:it,pt. | = source item or publication type
:ti. | = limit to title
:ti,ab. | = limit to title and abstract fields

PUBMED (PreMEDLINE)

Set Number | Concept | Search Statement
1 | Small cell lung cancer | ((“small-cell” OR “small cell”) AND (lung OR bronch*)) OR “oat cell” OR sclc
2 | Small cell lung cancer | 2 NOT (“non-small cell”[ti] OR “non-small-cell”[ti] OR “non small cell”[ti] OR “nonsmall cell”[ti] OR nsclc[ti])
3 | Lung Symptoms | (lung*[ti] OR pulmonary[ti] OR bronch*[ti] OR chest[ti]) AND (age* OR smok* OR symptom* OR wheez* OR cough* OR edema OR fibrosis OR asthma OR “shortness of breath” OR pain* OR nodule*)
4 | Imaging | sdct OR mdct OR mri OR ct OR (cat AND scan*) OR pet OR (fdg AND pet) OR “computed tomography” OR “positron emission” OR “magnetic resonance” OR “multislice” OR “multi slice” OR “bone scan” OR “bone scintigraphy” OR (bone AND scan*)
5 | Imaging | “endosonography” OR “eus” OR (endoscop* AND (ultrasound OR ultrasonography* OR echograph*))
6 | Imaging | “endobronchial echography” OR “endobronchial ultrasound” OR “ebus” OR (endobronch* AND (ultrasound OR ultrasonography* OR echograph*))
7 | Imaging | #4 OR #5 OR #6
8 | Pretreatment staging and planning | (cancer OR tumor* OR tumour* OR mass* OR neoplasm*) AND (stage OR staging OR class*)
9 | Pretreatment staging and planning | (cancer[tiab] OR neoplasm[tiab] OR tumor*[tiab] OR tumour*[tiab]) AND (care[tiab] OR treatment[tiab] OR therapy[tiab] OR pretreatment[tiab] OR “pre-treatment”[tiab] OR plan[tiab])
10 | Pretreatment staging and planning | #8 OR #9
11 | Prognosis | “cancer prognosis” OR prognos* OR predict* OR outcome* OR survival OR “quality of life” OR qol
12 | Combine SCLC OR Lung Symptoms | #2 OR #3
13 | Combine SCLC OR Lung Symptoms with imaging | #7 AND #12
14 | Combine SCLC OR Lung Symptoms with imaging and pretreatment planning | #10 AND #13
15 | Combine with prognosis | #11 AND #14
16 | In process | #15 AND (pubmednotmedline[sb] OR inprocess[sb] OR [publisher[sb])
17 | English | #16 AND English[la]

PubMed Syntax

* | = truncation character (wildcard)
[ti] | = limit to title field
[tiab] | = limit to title and abstract fields
[tw] | = text word