# Abbreviations and Acronyms

95% CI: 95% confidence interval
CT: Computed tomography
EBUS: Endobronchial ultrasound
EUS: Endoscopic ultrasound
FDG: Fluorodeoxyglucose
MBq: Megabecquerel
MHz: Megahertz
MRI: Magnetic resonance imaging
NA: Not applicable
NR: Not reported
PET/CT: Combined positron emission tomography and computed tomography
QUADAS: Quality assessment tool for diagnostic accuracy studies
SCLC: small cell lung cancer
SD: Standard deviation
TBNA: transbronchial needle aspiration
Tc99m-MDP: Technetium-99m methylene diphosphonate