# Results

## Results of Literature Searches

We included 166 publications in our previous review. After excluding studies without a comparison or an outcome relevant to this update, and cohort studies not meeting our revised quality criteria, we included 105 studies (published in 107 articles) in this update.

We retrieved 19,171 unique citations from our updated literature search (Figure 2). After reviewing titles, abstracts, and full text, we included 114 new studies (published in 142 new articles). Ten of the new publications were either extensions or additional analyses of studies included in the previous review.

Figure 2 Summary of the search (number of articles)

FDA = Food and Drug Administration

* Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

† Comorbid condition restrictions were end-stage renal disease, end-stage liver disease, cancer, new onset diabetes after transplant, or a cardiovascular event within 3 months (e.g., acute coronary syndrome, acute myocardial infarction, post-coronary artery bypass graft surgery, or with drug-eluting stents)

Summary of the search starting with databases and broken down into retrieved, title review, abstract review and so forth.

In total, we include in this review 219 studies, published in 249 articles.

## Study Duration of RCTs for All Key Questions (KQ1–KQ4)

Of the 177 included randomized controlled trials (RCTs) for all Key Questions combined, most studies were less than a year (Figure 3). Only 4 percent of studies lasted over 2 years, making it difficult to draw any firm conclusions about long-term outcomes. Unless stated otherwise in the text or figures below, results and conclusions for all the Key Questions are for short-term outcomes.

Figure 3 Duration of followup for randomized controlled trials comparing the effects of diabetes medications among adults with type 2 diabetes (N = 177)

Duration of followup for randomized controlled trials comparing the effects of diabetes medications among adults with type 2 diabetes (N=177). The table shows 3 to 6 months as the highest and less than 1 to 1.5 years as the lowest.

## Key Questions 1a and 1b Intermediate Outcomes

### Study Design and Population Characteristics

One hundred sixty-two RCTs (reported in 189 articles) evaluated intermediate clinical outcomes for adults with type 2 diabetes and met our inclusion criteria (Appendix D, Tables D1 to D4). All trials were parallel arm RCTs, except one which also used a crossover design47 and one which also used a factorial design.48 About half of the trials answering Key Question 1 occurred partly or exclusively in the United States (US) (n = 26), Japan (n=13), Italy (n = 12), and/or were multi-national (n = 56); the rest of the trials occurred in developed or newly industrialized countries. These RCTs lasted from 12 weeks to 5.5 years; however, most studies (81%) lasted less than 1 year, and only six studies lasted more than 2 years (including the well-known Rosiglitazone Evaluated for Cardiac Outcomes and Regulation of Glycemia in Diabetes (RECORD), and A Diabetes Outcome Progression Trial (ADOPT)).49-54 Only 12 percent of studies (n=20) reported receiving no pharmaceutical support, while about 14 percent of RCTs (n = 22) did not describe whether or not they received pharmaceutical support. The number of studies not describing their pharmaceutical support dropped from 25 percent of the studies included in the last diabetes medication comparative effectiveness report16 to only 5 percent of the newly included 87 studies in this update. The use of rescue therapy (i.e., the addition of another diabetes medication when the blood sugar was not controlled on the randomized treatment regimen) was not reported in 41 of the 87 studies included (47.1%), was not allowed in 20 studies (23.0%), and was allowed in 26 studies (29.9%). In the studies where rescue therapy was allowed, 12 studies did not specify which medications were used and, when reported, the medications varied greatly.

Study participants were mainly middle-aged, overweight, or obese adults who had had diabetes for 3 to 7 years. The exclusion criteria were generally similar for most trials: significant renal, cardiovascular, and hepatic disease. About half of the trials (58%) excluded older subjects (generally over the age of 75 to 80). Almost all of the studies included men and women. About 28% of the RCTs did not report race/ethnicity. In this update, the percent not reporting race/ethnicity increased from 20% of the 119 studies in the prior report16 to 38% of the 89 studies in the newly included studies. In these studies, when race was reported, most subjects were Caucasian, but between 10% and 20% of the enrolled population was of other races. The mean baseline HbA1c among study subjects varied from 6 to 12 absolute percentage points, with most subjects having a mean baseline HbA1c between 7 and 9 absolute percentage points.

### Risk of Bias

All of the studies included in this section were described as randomized (Figure 4). Fifty percent described their randomization scheme; 66 percent described their study as double-blinded. About one-third (36%) of all double-blinded RCTs also described the steps taken to ensure blinding. The majority of trials (86%) described the withdrawals and dropouts. Twelve of the fifteen studies with at least 2 years of followup had over 20% losses to followup.

Figure 4 Summary of the risk of bias of randomized controlled trials evaluating intermediate outcomes

Summary of the risk of bias of randomized controlled trials evaluating intermediate outcomes.

### Key Points and Evidence Grades for Intermediate Outcomes

#### Hemoglobin A1c

##### Monotherapy Comparisons

- Most oral diabetes medications had similar efficacy in achieving reductions in hemoglobin A1c (HbA1c).
  ○ In the prior report, the strength of evidence was graded as high that metformin was similar to sulfonylurea (pooled between-group difference of 0.1%; 95% confidence interval [CI], -0.1% to 0.3%). Therefore, we did not update this comparison for HbA1c in this review.
  ○ The strength of evidence (SOE) was graded as high that metformin was similar to thiazolidinedione (pooled between-group difference of -0.04%; 95% CI, -0.11% to 0.03%).
  ○ Thiazolidinediones performed similarly to sulfonylureas (pooled between-group difference of -0.04%; 95% CI, -0.13% to 0.06%). (SOE: High)
  ○ The SOE was graded as low or insufficient for all the monotherapy comparisons of the newer classes of sodium-glucose cotransporter (SGLT-2) inhibitors and glucagon-like peptide-1 (GLP-1) agonists, and will warrant further study.
- The one exception was that metformin had a greater reduction in HbA1c compared with dipeptidyl peptidase-4 (DPP-4) inhibitors (pooled between-group difference of -0.4%; 95% CI, -0.5% to -0.3%). (SOE: High)

##### Metformin-Based Combination Comparisons

- The combination of metformin plus GLP-1 receptor agonists reduced HbA1c more than metformin plus DPP-4 inhibitors, with a pooled between-group difference of -0.65% (95% CI, -0.75% to -0.54%) in the short-term. (SOE: Moderate)
- Most other combination therapy comparisons had either no significant or no clinically meaningful (<0.3%) between-group differences in HbA1c between arms.
- The evidence was graded as moderate for the following comparisons: metformin plus a thiazolidinedione versus metformin plus a sulfonylurea, metformin plus a thiazolidinedione versus metformin plus a DPP-4 inhibitor, metformin plus a sulfonylurea versus metformin plus an SGLT-2 inhibitor, metformin plus a DPP-4 inhibitor versus metformin plus an SGLT-2 inhibitor, and metformin plus a DPP-4 inhibitor versus metformin plus a GLP-1 receptor agonist.
- Despite the clinical interest in comparing metformin plus injectables, there was insufficient or low strength of evidence on glycemic control for the following comparisons: metformin plus the GLP-1 receptor agonists versus metformin plus basal or premixed insulin, and metformin plus premixed insulin versus metformin plus basal insulin.

#### Weight

##### Monotherapy Comparisons

- In the 2011 report, metformin had greater weight reduction than thiazolidinediones (pooled mean between-group difference of -2.6 kg; 95% CI, -4.1 kg to -1.2 kg) or sulfonylureas (pooled mean between-group difference of -2.7 kg; 95% CI, -3.5 kg to -1.9 kg) with high strength of evidence. Therefore, we did not update these two comparisons in this report.
- Metformin had greater weight reduction than DPP-4 inhibitors (pooled mean between-group difference, -1.3 kg; 95% CI, -1.6 kg to -1.0 kg). (SOE: High)
- SGLT-2 inhibitors had greater weight reduction when compared with metformin or DPP-4 inhibitors (between-group differences ranging from -1.3 kg to -2.7 kg). (SOE: Moderate for both comparisons)
- DPP-4 inhibitors and GLP-1 receptor agonists both decreased weight more than thiazolidinediones (between-group differences ranging from -2.3 kg to -3.5 kg). (SOE: Moderate for both comparisons)
- GLP-1 receptor agonists decreased weight more than sulfonylureas (pooled mean between-group difference, -2.3 kg; 95% CI, -3.3 kg to -1.2 kg). (SOE: Moderate)
- Sulfonylureas caused slightly less weight gain when compared with thiazolidinediones (between-group difference of -1.2 kg; 95% CI, -1.8 kg to -0.6 kg). (SOE: Moderate)

##### Metformin Versus Metformin-Based Combination Comparisons

- Metformin monotherapy reduced weight more than the combination of metformin plus a thiazolidinedione (pooled mean between-group difference, -2.2 kg; 95% CI, -2.6 kg to -1.9 kg) or metformin plus a sulfonylurea (pooled mean between-group difference, -2.2 kg, 95% CI, -3.4 kg to -1.0 kg). (SOE: High for both comparisons)
- When compared with metformin monotherapy, the combination of metformin plus
  ○ SGLT-2 inhibitor had greater weight reduction (pooled mean between-group difference, -2.0 kg; 95% CI, -2.5 kg to -1.5 kg). (SOE: High)
  ○ GLP-1 receptor agonist had greater weight reduction (pooled mean between-group difference, -2.0 kg; 95% CI, -2.7 kg to -1.3 kg). (SOE: Moderate)
- Metformin monotherapy had no significant differences in weight when compared with the combination of metformin plus DPP-4 inhibitors (pooled mean between-group difference, -0.1 kg; 95% CI, -0.2 kg to 0.03 kg). (SOE: Moderate)

##### Metformin-Based Combination Comparisons

- The combinations of metformin plus a sulfonylurea, metformin plus a GLP-1 receptor agonist, and metformin plus a DPP-4 inhibitor all had a more favorable effect on weight compared with metformin plus a thiazolidinedione (range in between-group differences, -0.9 kg to -5.1 kg). (SOE: Moderate for all comparisons)
- When compared with the combination of metformin plus a sulfonylurea, the combination of metformin plus
  ○ DPP-4 inhibitors had more favorable effects on weight (pooled mean between-group difference, -2.2 kg; 95% CI, -1.8 kg to -2.5 kg). (SOE: High)
  ○ SGLT-2 inhibitors had more favorable effects on weight (pooled mean between-group difference, -4.7 kg; 95% CI, -4.4 kg to -5.0 kg). (SOE: High)
  ○ GLP-1 receptor agonist had more favorable effects on weight (range in mean between-group differences, -2.4 kg to -12.3 kg). (SOE: Moderate)
  ○ Premixed insulin or basal insulin had less favorable effects on weight (range in mean between-group differences, 0.5 kg to 1.7 kg). The strength of evidence was low for both comparisons, due to the small number of studies. However, taken together, the strength of evidence would be moderate favoring metformin plus sulfonylurea over metformin plus a premixed or long-acting insulin.
- When compared with metformin plus a DPP-4 inhibitor, the combination of metformin plus
  ○ GLP-1 receptor agonist had greater reductions in weight (pooled mean between-group difference, -1.8 kg; 95% CI, -1.1 kg to -2.5 kg). (SOE: Moderate)
  ○ SGLT-2 inhibitors had greater reductions in weight (between-group differences of around -2.5 kg). (SOE: Moderate)
- Despite the clinical interest in comparing metformin plus injectables, there was low strength of evidence on weight for the following comparisons: metformin plus the GLP-1 receptor agonists versus metformin plus basal or premixed insulin, and metformin plus premixed insulin versus metformin plus basal insulin.

#### Systolic Blood Pressure (for Comparisons That Include SGLT-2 Inhibitors or GLP-1 Receptor Agonists)

##### Monotherapy Comparisons

- SGLT-2 inhibitors had a greater reduction in systolic blood pressure compared with metformin, (pooled between-group difference of -2.8 mmHg; 95% CI, -2.6 mmHg to -3.0 mmHg). (SOE: Moderate)
- The strength of evidence was graded low or insufficient for the following comparisons:
  ○ SGLT-2 inhibitors versus DPP-4 inhibitors, and
  ○ GLP-1 receptor agonists versus metformin, thiazolidinediones, sulfonylureas, and DPP-4 inhibitors.

##### Metformin Versus Metformin-Based Combination Comparisons

- Metformin plus a SGLT-2 inhibitor reduced systolic blood pressure more than metformin alone (pooled between-group difference of -4.4 mmHg; 95% CI, -2.9 to -6.0 mmHg) for shorter studies. (SOE: High)
- Metformin plus a GLP-1 receptor agonist reduced systolic blood pressure more than metformin alone (pooled between-group difference of -3.1 mmHg; 95% CI, -1.4 to -4.9 mmHg). (SOE: Moderate)

##### Metformin-Based Combination Comparisons

- Metformin plus a SGLT-2 inhibitor reduced systolic blood pressure more than metformin plus a sulfonylurea (pooled between-group difference, -5.0 mmHg; 95% CI, -4.2 mmHg to -6.0 mmHg) or metformin plus a DPP-4 inhibitor (pooled between-group difference, -4.1 mmHg; 95% CI, -3.6 mmHg to -4.6 mmHg). (SOE: High and Moderate, respectively)

#### Heart Rate (for Comparisons That Include SGLT-2 Inhibitors or GLP-1 Receptor Agonists)

##### Monotherapy Comparisons

- Metformin compared with a GLP-1 receptor agonist yielded no differences in heart rate between arms. (SOE: Moderate)

##### Metformin Versus Metformin-Based Combination Comparisons

- There was low or insufficient evidence for all metformin combination therapies compared with metformin alone.

##### Metformin-Based Combination Comparisons

- Combination therapy with metformin plus a SGLT-2 inhibitor resulted in less increase in heart rate compared with metformin plus a sulfonylurea (pooled between group difference in heart rate, -1.5 bpm; 95% CI, -0.6 bpm to -2.3 bpm). (SOE: Moderate)

### Evidence for Hemoglobin A1c

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

Twenty-three RCTs, each lasting approximately one year or less, directly compared metformin with a thiazolidinedione, and showed no between-group differences in HbA1c (pooled between-group difference of -0.04%; 95% CI, -0.11% to 0.03%) (Figure 5).55-77 We tested the effect of each individual study on the combined point estimate. No single study influenced the pooled results. No substantial heterogeneity was identified.

Figure 5 Pooled mean between-group difference in hemoglobin A1c comparing metformin with thiazolidinediones

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing metformin with thiazolidinediones.

Three additional trials examined this comparison but were excluded from the pooled results, one with a median study duration of 4 years,50 one which reported median HbA1c instead of means,78 and one study where the mean difference between groups could not be calculated.79 The 4-year, double-blind RCT (known as the ADOPT study), with around a 60% loss to followup, was designed to compare long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for adults with type 2 diabetes.50 The authors found a statistically significant but small difference between groups favoring rosiglitazone (mean difference between groups 0.1%; 95% CI, 0.05% to 0.2%). Of note, the HbA1c decreased in all groups for the first 6 months and then increased in all groups over the rest of the study. The other two short duration RCTs excluded from the meta-analysis were consistent with the pooled results. One study reported no between-group differences in median HbA1c.78 The second study was missing the number in each arm needed to calculate the between-group difference. Since this was an RCT, we calculated the between-group difference with the assumption of equal numbers in each arm which showed no statistically significant differences between-groups in HbA1c.79 (SOE: High; Neither drug favored)

##### Metformin Versus Sulfonylureas

In the prior report, we graded the evidence as high showing no differences in HbA1c between groups for this comparison. Therefore, we did not re-evaluate this comparison for HbA1c.

##### Metformin Versus DPP-4 Inhibitors

Six short duration RCTs (reported in nine articles) compared metformin with DPP-4 inhibitors (sitagliptin, alogliptin, linagliptin and saxagliptin).73, 80-87 These studies reported greater reductions in HbA1c with metformin (pooled between-group difference in HbA1c of -0.4%; 95% CI, -0.5% to -0.3%) (Figure 6). No single study strongly influenced the meta-analysis results. In the three studies using both low and high metformin dosages compared with the maximum dose DPP-4 inhibitor, we included the maximum dose metformin arm in the meta-analysis to make the drug dosages most comparable. The lower dose metformin arms (1000 mg) compared with maximum dose DPP-4 showed no statistically significant between-group differences in HbA1c.84-86

Figure 6 Pooled mean between-group difference in hemoglobin A1c comparing metformin with DPP-4 inhibitors

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing metformin with DPP-4 inhibitors.

Two RCTs (in five articles) were reported as extension studies.80, 81, 83, 85, 87 The shorter duration results were included in the meta-analysis, since their study durations were more similar to the other studies in the meta-analysis. The first RCT comparing metformin 1000 mg twice daily with sitagliptin 100 mg daily reported HbA1c at 24 weeks,80 54 weeks,81 and 104 weeks.85 The between-group difference in HbA1c of -0.5 percent favored metformin over sitagliptin at both 24 and 54 weeks of followup. At week 104, there was no significant difference between groups in HbA1c, but there were high and differential losses to followup among the arms (74% loss to followup in the sitagliptin arm and 48% in the metformin arm). The second 76-week study87 was an RCT initially reported at 24 weeks comparing metformin up to 1000 mg twice daily with saxagliptin 10 mg daily. In this study, the between-group difference of -0.3 in HbA1c non-significantly favored metformin at 24 weeks83 and statistically significantly favored metformin at 76 weeks (mean difference between-groups in HbA1c, -0.2%; 95% CI, -0.5% to -0.03%),87 which is consistent with the meta-analysis results. (SOE: High; Metformin favored)

##### Metformin Versus SGLT-2 Inhibitors

Three short duration and one longer duration RCTs (reported in three articles) compared metformin with an SGLT-2 inhibitor, showing no consistent between-group differences in HbA1c among the studies.88-90 We did not combine these studies in a meta-analysis due to dosing and study duration differences. Two of the short duration studies reported in one article compared metformin XR titrated to 2000 mg with dapagliflozin 5 mg in the first study, and compared metformin XR titrated to 2000 mg with dapagliflozin 10 mg in the second study.88 Both studies, each lasting 24 weeks, reported no significant between-group differences in HbA1c.88 The study comparing metformin XR to the lower dose dapagliflozin arm of 5 mg had a mean difference between-groups in HbA1c which favored metformin by 0.16 percent although non-significantly, and the study comparing metformin XR to the higher dose dapagliflozin arm of 10 mg did not favor either arm. The third study comparing a lower dose of metformin XR of 1500 mg daily with dapagliflozin 10 mg daily for 12 weeks favored the dapagliflozin arm (calculated mean between-group difference in HbA1c of 0.12%; 95% CI, 0.08% to 0.16%).89 The 90-week RCT comparing metformin 1000 mg twice daily with empagliflozin 10 mg daily and 25 mg daily reported no significant differences between groups in HbA1c.90 (SOE: Low; Neither drug favored)

##### Metformin Versus GLP-1 Receptor Agonists

Three studies, each lasting one year or less, compared metformin versus a GLP-1 receptor agonist, with no consistent between-group differences in HbA1c.73, 91, 92 We did not combine the studies in a meta-analysis due to study duration and dosing differences. Each study, lasting 24 to 52 weeks in duration, compared metformin at 1500 mg or higher to a GLP-1 receptor agonist (exenatide twice daily in one study, exenatide weekly in a second study, and dulaglutide weekly in a third study). Only one study had a borderline significant result, favoring dulaglutide 1.5 mg weekly over metformin titrated to 2000 mg daily after 52 weeks (calculated mean between-group difference in HbA1c of 0.2%; 95% CI, 0.0% to 0.4%).91 This same study also had a lower-dose dulaglutide arm at 0.75 mg weekly, which showed no significant difference in HbA1c when compared with metformin titrated to 2000 mg daily.91 (SOE: Low; Neither drug favored)

##### Thiazolidinediones Versus Sulfonylureas

Thiazolidinediones (pioglitazone and rosiglitazone) and sulfonylureas (glibenclamide, glimepiride, and glyburide) had similar effects on HbA1c in 15 short duration RCTs (pooled mean between-group difference of -0.04%; 95% CI, -0.13% to 0.06%) (Figure 7).60, 61, 63, 74, 93-103 In a sensitivity analysis, we found no single study influenced the results , and there was no substantial heterogeneity between studies. We excluded one short duration RCT from the meta-analysis, since it did not report a number for analysis in each arm.79 This open-label 12-week RCT compared rosiglitazone titrated to 4-8 mg daily with glipizide titrated to 5-15 mg daily and reported a greater reduction in HbA1c in the thiazolidinedione arm (-0.9%) compared with the glipizide arm (-0.3%).79

Figure 7 Pooled mean between-group difference in hemoglobin A1c comparing thiazolidinediones with sulfonylureas

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group differenec in hemoglobin A1c comparing thiazolidinediones with sulfonylureas.

We excluded the ADOPT study from the meta-analysis due to its long duration (median followup of 4 years).50 As mentioned previously, this double-blind RCT evaluated the long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for type 2 diabetic adults, and had a 62 percent, 63 percent, and 56 percent loss to followup, respectively, in each treatment arm. The between-group difference between rosiglitazone and glyburide favored rosiglitazone after 4 years (mean difference between-groups of -0.4%; 95% CI, -0.5% to -0.3%). Of note, glyburide reduced HbA1c more than rosiglitazone, initially. HbA1c then rose higher in the glyburide arm than in the rosiglitazone arm after 1.5 years. (SOE: High; Neither drug favored in the short-term. SOE: Insufficient for the long-term.)

##### Thiazolidinediones Versus DPP-4 Inhibitors

Three RCTs, each lasting less than 26 weeks, compared pioglitazone with the DPP-4 inhibitors alogliptin and sitagliptin with no clear between-group differences in HbA1c (range in between-group differences of -0.48% to 0.23%).48, 73, 104 We did not combine the studies due to dosing differences among the studies. The one RCT with maximal dosing in both arms (pioglitazone titrated to 45 mg daily in one arm and sitagliptin 100 mg daily in the other arm) favored pioglitazone over sitagliptin (between-group difference in HbA1c of -0.5%; 95% CI -0.7% to -0.3%).73 The other two RCTs used maximum dose DPP-4 inhibitors compared with moderately-dosed pioglitazone at 30 mg daily and reported no significant between-group differences in HbA1c.48, 104 (SOE: Insufficient)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

Two comparably-dosed RCTs compared pioglitazone with exenatide in differing dosing regimens, with mixed results.73, 105 One double-blind, moderately-sized RCT compared pioglitazone titrated to 45 mg daily with exenatide 2 mg weekly.73 After 26 weeks, the mean between-group difference in HbA1c was -0.1% with a reported 98.3% CI of -0.15% to 0.35%.73 The second open-label RCT compared pioglitazone at 45 mg daily with exenatide 10 ug twice daily. After 48 weeks, the calculated mean between-group difference in HbA1c favored exenatide by 0.3% (95% CI, 0.0% to 0.6%).105 (SOE: Insufficient)

##### Sulfonylureas Versus DPP-4 Inhibitors

Three RCTs, each lasting 54 weeks or less, compared a sulfonylurea (glipizide or glimepiride) with a DPP-4 inhibitor (sitagliptin or linagliptin) with no clear between-group differences in HbA1c.106-108 We did not combine these studies in a meta-analysis due to dosing differences and study population differences. Two RCTs non-significantly favored sulfonylureas over the DPP-4 inhibitor arms (between-group differences in HbA1c of -0.22% and -0.28%).106, 108 The third RCT enrolled patients with moderate or severe renal insufficiency at baseline and compared glipizide (mean dose 7.7 mg) with sitagliptin at 25 or 50 mg daily, depending on the participant's renal function.107 This study showed no significant between-group differences in HbA1c.107 (SOE: Insufficient)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Four RCTs (reported in five articles) compared sulfonylureas directly with a GLP-1 receptor agonist (all studies using liraglutide).109-113 Three of the four studies favored liraglutide over sulfonylureas.109, 110, 112, 113 We did not combine these trials in a meta-analysis due to dosing differences between studies. Only two of the four studies used comparable dosing in the two arms. The first reported no statistically significant differences between the two arms.111 The second RCT favored the GLP-1 arm (between-group difference in HbA1c of 0.6%; 95% CI, 0.4% to 0.8%, at 52 weeks, and 0.3%; 95% CI, 0.2% to 0.4%, at the 104-week followup).112, 113 The two other RCTs, lasting 24 and 52 weeks, significantly favored the liraglutide arm by 0.5% each;109, 110 yet both of these studies used relatively lower doses in the sulfonylurea arm compared with the liraglutide arm, making it difficult to discern drug differences versus dosing differences.109, 110 (SOE: Insufficient)

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

Only one double-blind, moderately-sized RCT, lasting 24 weeks, compared the DPP-4 inhibitor sitagliptin at 100 mg daily with the SGLT-2 inhibitor empagliflozin at 10 mg and 25 mg daily.114 The lower dose empagliflozin arm showed no significant between-group differences in HbA1c when compared with sitagliptin 100 mg daily. The higher dose empagliflozin 25 mg arm was favored slightly, but not significantly, over sitagliptin 100 mg (between-group difference in HbA1c of 0.01%; 95% CI, -0.03% to 0.3%).114 (SOE: Insufficient)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

Two short duration RCTs compared a DPP-4 inhibitor with a GLP-1 receptor agonist, favoring the GLP-1 receptor agonists.73, 115 The first double-blind, moderately-sized RCT compared sitagliptin at 100 mg daily with exenatide 2 mg weekly for 26 weeks (calculated between-group difference in HbA1c of 0.4%; 95% CI, 0.07% to 0.49%) favoring exenatide.73 A second open-label RCT, with 40 participants and lasting 24 weeks, compared sitagliptin at 50 mg daily with liraglutide titrated to 0.9 mg daily (calculated mean between-group difference in HbA1c of 1.3%; 95% CI, -0.6% to 3.2%) non-significantly favoring liraglutide.115 (SOE: Low; GLP-1 receptor agonists favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

Fourteen studies lasting less than one year compared metformin with the combination of metformin plus a thiazolidinedione (eight studies with rosiglitazone and six studies with pioglitazone)55, 59, 67, 116-126 and showed a greater improvement in HbA1c with the combination therapy, in all the studies. The pooled between-group difference for all the studies combined had marked heterogeneity, but the meta-regression and stratified meta-analysis results showed consistent superiority of combination therapy (Table 5). The baseline HbA1c and dosing differences between arms were significant sources of heterogeneity. Studies with higher baseline HbA1c (HbA1c ≥ 8%) had greater between-group differences than studies with lower baseline HbA1c (HbA1c < 8%). Studies with smaller dosing differences between study arms had smaller between-group differences in HbA1c than studies with larger dosing differences between arms. One long study,127 with 80 weeks of followup, compared metformin titrated to 2000 mg daily with metformin plus rosiglitazone titrated to 2000/8 mg daily. In that study, with around 5 percent loss to followup, the adjusted mean between-group difference in HbA1c favored combination therapy by 0.5 percent, consistent with the results in the shorter studies. (SOE: High; Combination of metformin plus a thiazolidinedione favored)

Table 5 Pooled mean between-group difference in HbA1c comparing metformin with a combination of metformin plus a thiazolidinedione stratified by baseline HbA1c and dosing differences

Variables | N of Studies | WMD (95% CI) | I^2^ | Summary
Baseline HbA1c <8% | 7 | 0.43% (0.23% to 0.63%) | 79% | Favored metformin + thiazolidinedione
Baseline HbA1c >=8% | 7 | 0.88% (0.73% to 1.04%) | 18% | Favored metformin + thiazolidinedione
Small dosing differences between study arms^*^ | 4 | 0.25% (0.16% to 0.34%) | 0% | Favored metformin + thiazolidinedione
Large dosing differences between study arms^*^ | 10 | 0.79% (0.64% to 0.95%) | 57% | Favored metformin + thiazolidinedione

CI = confidence interval; HbA1c = hemoglobin A1c; WMD = weighted mean difference

* Studies were grouped together that had similar between-group differences in study dosing between arms. This led to two categories: those studies with smaller and larger between-group differences in drug dosing. We used the DerSimonian and Laird random effects point estimate for the weighted mean difference of the large dosing differences since profile likelihood estimate results would not converge.

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

Fifteen RCTs, each lasting less than one year, compared metformin with the combination of metformin plus a sulfonylurea, with all of the studies favoring the combination arm over monotherapy (pooled between-group difference, 0.9%; 95% CI, 0.7% to 1.2%) (Figure 8).47, 55, 128-140

Figure 8 Pooled mean between-group difference in hemoglobin A1c comparing metformin with a combination of metformin plus a sulfonylurea

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing metformin with a combination of metformin plus a sulfonylurea.

No single study markedly influenced the results. Meta-regression was conducted due to substantial heterogeneity, but none of the a priori variables were found to be significant, including study duration, dosing differences, appropriate randomization, double blinding, baseline HbA1c, or whether the study reported on withdrawals and dropouts. The study by Blonde et al. showed the greatest between-group differences; this study used a high-dose combination and started with the highest baseline HbA1c compared with other studies.131 The study with the smallest between-group difference underdosed the metformin arm substantially in the metformin plus sulfonylurea arm.55 Three of the six dose-response studies showed a dose-response gradient favoring greater reductions in HbA1c with a higher dose combination than with a lower dose combination.131, 132, 134 One crossover study initially showed a difference between groups at the first crossover and then a negative rebound effect when changing the combination to monotherapy.47 A study by Ahren et al. was excluded from the meta-analysis since the study duration was longer than the other studies.141 This study, lasting 104 weeks, compared metformin at ≥ 1500 mg daily to the combination of metformin at ≥ 1500 mg daily plus glimepiride (up to 4 mg daily), and showed a between-group difference in HbA1c of 0.63 percent, favoring the combination arm, which was consistent with the results of the shorter studies included in the meta-analysis. (SOE: High; combination of metformin plus a sulfonylurea favored)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Twenty-seven RCTs, each lasting one year or less, directly compared metformin with the combination of metformin plus a DPP-4 inhibitor, with all favoring the combination arm (pooled between-group difference of 0.65%; 95% CI, 0.60% to 0.70%) (Figure 9).51, 80, 83, 84, 86, 118, 126, 139, 142-160 No single study markedly influenced the results, and no substantial heterogeneity was identified.

Figure 9 Pooled mean between-group difference in hemoglobin A1c comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

Three short studies were not included in the meta-analysis due to dosing differences in two studies161, 162 and median HbA1c being reported in the other study.163 Two RCTs had 1000 mg more metformin in the monotherapy arm compared with the combination arm; therefore, these two studies161, 162 had smaller between-group differences than the other studies. The 12-week study163 reporting median HbA1c described a non-significant between-group difference in median HbA1c of 0.9% (p=0.1) favoring the combination arm of metformin (>1000 mg daily) plus sitagliptin (100 mg daily) over metformin alone (>1000 mg daily).

Four longer studies (two of which were extension studies), each lasting 76 to 104 weeks with 30 percent to 50 percent losses to followup, also compared metformin with metformin plus a DPP-4 inhibitor, with results consistent with the shorter studies.85, 87, 141, 164 All four favored the combination arm (pooled between-group difference in HbA1c of 0.53%; 95% CI, 0.47% to 0.59%) (Figure 9). No single study markedly influenced the results, and no substantial heterogeneity was found. (SOE: High; Combination of metformin plus a DPP-4 inhibitor favored in the shorter duration studies) (SOE: Moderate; Combination of metformin plus a DPP-4 inhibitor favored in the longer duration studies)

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Nine RCTs (reported in eight articles), each lasting less than one year, compared metformin alone with metformin plus an SGLT-2 inhibitor, with all studies favoring the combination arm (pooled between-group difference in HbA1c, 0.61%; 95% CI, 0.52% to 0.71%) (Figure 10).88, 153, 156, 158, 165-168 No single study markedly influenced the results. Heterogeneity was identified attributable to the Schumm-Draeger study which had the smallest between-group difference in HbA1c. No clear design differences exist between this study and the other studies in the meta-analysis, so we included it in the meta-analysis. Consistent with the meta-analysis results, two additional RCTs, each lasting 102 weeks, had statistically significant between-group differences in HbA1c of 0.4 percent and 0.8 percent, favoring the combination arms.169, 170 (SOE: High; Combination of metformin plus a SGLT-2 inhibitor favored)

Figure 10 Pooled mean between-group difference in hemoglobin A1c comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Five short RCTs, each lasting less than one year, and one RCT, lasting 2 years, compared metformin with metformin plus a GLP-1 receptor agonist (albiglutide, liraglutide, dulaglutide, and exenatide), with all studies significantly favoring the combination arm over the monotherapy arm (range in between-group differences in HbA1c of 0.5% to 1.3%).141, 159, 171-174 We did not combine these studies in a meta-analysis due to differences in baseline HbA1c, study duration, and drug dosing. The two studies with low mean baseline HbA1c of 6.3 percent and 7.2 percent had between-group differences in HbA1c of 0.5 percent,172, 173 and the four studies with higher mean baseline HbA1c of around 8.0 percent had between-group differences in HbA1c ranging from 0.8 percent to 1.3 percent.141, 159, 171, 174 The one study with a lower dose and higher dose combination arm showed a dose-response relationship, with a smaller between-group difference in HbA1c of 0.5 percent in the lower dose combination and a larger between-group difference in HbA1c of 0.9 percent with the higher dose combination arm.174 (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Eight comparably-dosed RCTs, each lasting less than one year, directly compared the combination of metformin plus a thiazolidinedione with metformin plus a sulfonylurea (pooled between-group difference in HbA1c of -0.06%; 95% CI, -0.19% to 0.06%) (Figure 11).175-182 No single study markedly influenced the results, and no substantial heterogeneity was found. We excluded four studies from the meta-analysis due to dosing concerns within the studies.55, 183-185 Two studies used lower doses in the metformin plus sulfonylurea arms than in the comparator arms and found between-group differences in HbA1c favoring the metformin plus thiazolidinedione arms (-0.3% in both studies).55, 183 Two additional studies used submaximal sulfonylurea in the metformin plus sulfonylurea arm; one of the two studies favored the metformin plus thiazolidinedione arm. A sensitivity analysis including these four studies in the meta-analysis showed no marked differences in the pooled estimate and confidence interval, but more heterogeneity.

Figure 11 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; Met = metformin; SU = sulfonylurea; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea

In the meta-analysis, we included the 18-month results from the Rosiglitazone Evaluated for Cardiovascular Outcomes in Oral Agent Combination Therapy for Type 2 Diabetes (RECORD) study, since the study duration was comparable to the other included studies.176 The RECORD study was a multicenter, open-label RCT evaluating 4,447 patients with type 2 diabetes and uncontrolled glycemia already on metformin or sulfonylurea monotherapy.49, 176 The investigators randomly assigned subjects to the addition of rosiglitazone or to a combination of metformin and sulfonylurea. They reported glycemic control at a mean of 18 months for the first set of participants and a mean of 5.5 years after the start of the study for all included subjects not lost to followup.49, 176 The between-group difference in HbA1c of -0.07 percent was small and not significant for the first 516 subjects with 18-month followup.176 In the article reporting on the mean followup of 5.5 years in 2,222 subjects, the between-group difference in HbA1c of -0.29 percent significantly favored metformin plus rosiglitazone over metformin plus sulfonylurea.49 (SOE: Moderate; Neither drug combination favored)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Five short RCTs compared metformin plus rosiglitazone with the combination of metformin plus sitagliptin and slightly favored the metformin plus thiazolidinedione arms (pooled between-group difference in HbA1c, -0.12%; 95% CI, -0.21% to -0.02%) (Figure 12).118, 126, 186-188 No substantial heterogeneity was identified in the meta-analysis. Removing the study by Bergenstal et al.188 changed the confidence interval to non-significant (95% CI with Bergenstal et al. removed, -0.19% to 0.01%). This study188 was not qualitatively different than the other studies, so we included it in the overall meta-analysis. This meta-analysis may underestimate the effect of metformin plus thiazolidinedione over metformin plus DPP-4 inhibitors, since two of the studies used lower drug doses in the metformin plus thiazolidinedione arms.186, 187 (SOE: Moderate; Combination of metformin plus a thiazolidinedione favored)

Figure 12 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; Met = metformin; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a DPP-4 inhibitor.

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two short RCTs, with adequate dosing in both arms, compared metformin plus thiazolidinediones (pioglitazone or rosiglitazone) with metformin plus a GLP-1 receptor agonist (exenatide) and had conflicting results.188, 189 The 20-week RCT comparing a combination of metformin and rosiglitazone with the combination of metformin and exenatide showed no significant between-group differences in HbA1c (between-group difference, -0.1%; P = 0.7).189 The 26-week RCT comparing the combination of metformin and pioglitazone with the combination of metformin and weekly exenatide favored the metformin plus exenatide arm (mean difference in HbA1c, 0.3%; 95 CI, 0.05% to 0.55%).188 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Nine studies (reported in ten articles) compared the combination of metformin plus sulfonylurea with metformin plus a DPP-4 inhibitor. We combined four RCTs, each lasting 1 year or less, comparing metformin plus a sulfonylurea with metformin plus a DPP-4 inhibitor, and found no significant between-groups differences in HbA1c (pooled between-group difference, -0.09%; 95 CI, -0.21% to 0.03%) (Figure 13).190-193 However, all four RCTS used a moderate dose of sulfonylurea in the metformin plus sulfonylurea arms while using the maximum dose of the DPP-4 inhibitors. If we exclude the study by Nauck and colleagues,192 the pooled result would then significantly favor the combination of metformin plus sulfonylurea (pooled between group difference -0.13%, 95% CI -0.24% to -0.02%). However, there is no clear difference between this study and the other studies. No other study substantially changed the meta-analysis results. One additional short RCT was excluded from the meta-analysis, since we were unable to calculate a measure of variability.139 This study reported a mean change from baseline in HbA1c that significantly favored the metformin plus sulfonylurea arm over the metformin plus DPP-4 inhibitor arm of -0.2%, despite a lower dose of the sulfonylurea.

Figure 13 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; Met = metformin; pl = profile likelihood estimate; SU = sulfonylurea

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95% CI for each study. The line at the bottom of the graph indicates the 95% CI for the profile likelihood pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration.

Five longer studies, lasting 104 weeks and with over 20 percent loss to followup, also compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor, and showed no significant pooled between-group difference in HbA1c (-0.03%; 95% CI, -0.15% to 0.09%) (Figure 13).141, 194-197 However, all five RCTs titrated the sulfonylurea to a moderate dose and compared this to a fixed maximum dose of a DPP-4 inhibitor. One of the longer studies was an extension of a study included in the meta-analysis of the shorter studies.192 No single study strongly influenced the results. (SOE: Low; Neither drug combination favored for both shorter and longer duration studies when comparing moderate dose sulfonylureas plus metformin with maximum dose DPP-4 inhibitors plus metformin)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs (reported in five articles), each lasting 1 to 4 years, compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a SGLT-2 inhibitor (empagliflozin, dapagliflozin, or canagliflozin).54, 198-201 All three studies lasting 2 years with 20 percent to 30 percent losses to followup favored the combination of metformin plus an SGLT-2 inhibitor (pooled between-group difference in HbA1c of 0.17%; 95% CI, 0.14% to 0.20%) (Figure 14).199-201 No single study markedly influenced the results, and no substantial heterogeneity was identified. While all three studies used the maximum fixed dose of the SGLT-2 inhibitor, the sulfonylurea arms were all uptitrated to a moderate dose (mean glimepiride dose of 3 mg in one study, mean glimepiride dose of 5.6 mg in a second study, and a mean glipizide dose of 16 mg in the third study). One of the three studies also compared the combination of metformin plus a lower dose SGLT-2 inhibitor arm of canagliflozin 100 mg daily with the combination of metformin plus glimepiride (mean dose of 5.6 mg daily), reporting no significant between-group differences in HbA1c of 0.01%.198 The 1-year and 4-year study findings were consistent with the 2-year results shown in the meta-analysis.54, 198 (SOE: Moderate; Combination of metformin plus a SGLT-2 inhibitor favored)

Figure 14 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; Met = metformin; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Six RCTs compared metformin plus sulfonylurea with metformin plus a GLP-1 receptor agonist, with conflicting results.53, 141, 202-205 While no clear source of heterogeneity was identified, intraclass differences could be part of the reason for the conflicting results. Three short-duration RCTs, each lasting one year or less, compared metformin plus sulfonylurea with metformin plus exenatide, all favoring the combination of metformin plus sulfonylurea despite submaximal doses of sulfonylureas being compared with maximal doses of daily exenatide (pooled between-group difference in HbA1c, -0.26%; 95% CI, -0.48% to -0.03%) (Figure 15).202, 203, 205 No single study strongly influenced the results, and no substantial heterogeneity was identified. An additional longer duration RCT, excluded from the meta-analysis due to dosing and study duration differences, compared metformin plus low dose glimepiride (mean daily dose: 2 mg) with metformin plus high dose exenatide (mean daily dose: 17 micrograms) with about a 75 percent loss to followup among the treatment groups over 48 months. The primary outcome was time to treatment failure which was not clearly defined except to state that they were in line with the American Diabetes Association recommendations for requiring alternative treatment due to inadequate glycemic control. They also evaluated HbA1c using a mixed model repeated measures analysis at different time points and reported no significant between-group differences at 1 year. At 2 years, they reported a significant between-group difference in HbA1c, favoring the metformin plus exenatide group by 0.2 percent which was maintained at 3 years.53

Figure 15 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus daily exenatide

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); GLP-1 agonists = glucagon-like peptide-1 receptor agonist (here, all exenatide); HbA1c = hemoglobin A1c; Met = metformin; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus daily exenatide.

Two RCTs also compared metformin plus a sulfonylurea with metformin plus other types of GLP-1 receptor agonists (albiglutide or liraglutide), with conflicting results.141, 204 These were excluded from the meta-analysis due to dosing, drug type, and study duration differences. The first 16-week RCT compared metformin plus glimepiride (titrated to 4 mg daily) with similarly dosed metformin plus liraglutide (titrated to 1.8 micrograms daily), favoring the combination of metformin plus sulfonylurea (mean between-group difference, -0.3%; 95% CI, -0.34% to -0.27%).204 The 104-week RCT, with over 30 percent loss to followup, compared metformin plus submaximal dose glimepiride (titrated to 4 mg daily) with the combination of metformin plus maximum dose albiglutide (titrated to 50 mg weekly), favoring the metformin plus albiglutide arm (mean between-group difference in HbA1c, 0.3%; 95% CI, 0.1% to 0.5%).141 (SOE: Low; Combination of metformin plus exenatide favored; SOE: Insufficient for combination of metformin plus other GLP-1 receptor agonists)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Basal Insulin

One small, open-label RCT, lasting 48 weeks, compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a basal insulin, showing no significant between-group differences in HbA1c of 0.1% (95% CI, -0.5% to 0.7%).206 Patients were kept on their prior metformin doses and were randomized to uptitration of glimepiride (mean daily dose of 4 mg) versus uptitration of insulin glargine (mean daily dose of 23 units). Uptitration was stopped after reaching fasting plasma glucose titration goals.206 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Premixed Insulin

Two 16-week RCTs compared metformin plus glibenclamide with the combination of metformin plus a premixed insulin analogue – insulin aspart 70/30 in one study and insulin lispro 75/25 in the other study, with different results.207, 208 These differences may have been due to differences in dosing of the medications. The RCT207 that showed no significant between-group differences in HbA1c (-0.11%, p = 0.238) reported the mean total dose for each combination arm, while the other RCT, which significantly favored the metformin plus premixed insulin analogue (insulin aspart 70/30) arm over the metformin plus sulfonylurea arm (between-group difference of 0.46%, p = 0.027), did not clearly report mean total or maximum doses.208 Another possible difference may have been the type of premixed insulin analogue. (SOE: Insufficient)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Four short, sufficiently-dosed RCTs, each lasting one year or less, compared the combination of metformin plus a DPP-4 inhibitor (sitagliptin or saxagliptin) with the combination of metformin plus an SGLT-2 inhibitor (canagliflozin, empagliflozin, or dapagliflozin). The studies significantly favored the combination of metformin plus an SGLT-2 inhibitor (pooled between-group difference in HbA1c, 0.17%; 95% CI, 0.08% to 0.26%) (Figure 16).153, 156, 158, 209 No single study strongly influenced the results, and no substantial heterogeneity was found in the meta-analysis.

Figure 16 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; Met = metformin; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a SGLT-2 inhibitor.

One longer RCT, lasting 90 weeks and with less than 10 percent loss to followup, comparing metformin plus sitagliptin with metformin plus empagliflozin at maximum doses was consistent with the shorter studies' pooled results, favoring slightly the metformin plus empagliflozin arm (mean between-group difference in HbA1c, 0.2%; 95% CI, 0.0% to 0.5%).90 (SOE: Moderate; Combination of metformin plus a SGLT-2 inhibitor favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three adequately-dosed RCTs, lasting one year or less, compared the combination of metformin plus sitagliptin with the combination of metformin plus a GLP-1 receptor agonist (liraglutide or exenatide). All three RCTs significantly favored the combination of metformin plus a GLP-1 receptor agonist (pooled between-group difference in HbA1c, 0.65%; 95% CI, 0.54% to 0.75%) (Figure 17).159, 188, 210 No single study markedly influenced the meta-analysis results, and no substantial heterogeneity was identified. One longer study, lasting 104 weeks, compared metformin plus sitagliptin with metformin plus albiglutide, significantly favoring the metformin plus albiglutide arm by 0.4 percent, consistent with the shorter studies' pooled results.141 (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

Figure 17 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); GLP-1 = glucagon-like peptide-1; HbA1c = hemoglobin A1c; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist.

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a Basal Insulin

One moderately-sized, 24-week RCT compared metformin plus sitagliptin (100 mg daily) with metformin plus insulin glargine titrated to 0.5 units per kg, significantly favoring the metformin plus insulin glargine arm (mean between-group difference in HbA1c of 0.59%; 95% CI, 0.42% to 0.76%).211 (SOE: Low; Combination of metformin plus a basal insulin favored)

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Basal Insulin

One 26-week RCT compared metformin plus exenatide (2 mg weekly) with metformin plus glargine insulin, with a reported between-group difference in HbA1c favoring the combination of metformin plus exenatide by -0.2% (95% CI, -0.3% to -0.02%).212 (SOE: Insufficient)

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Premixed Insulin

One moderately-sized RCT, lasting 26 weeks, compared the combination of metformin plus exenatide (titrated to 20 micrograms) with the combination of metformin plus premixed insulin (titrated to glucose target, mean dose 28 units), showing no significant between-group difference in HbA1c of 0.14% (95% CI, -0.003% to 0.29%).213 (SOE: Insufficient)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

Three RCTs directly compared the combination of metformin plus basal insulin with the combination of metformin plus premixed insulin, showing no between-group differences in HbA1c (pooled between-group difference, 0.3%; 95% CI, -0.3% to 0.9%) (Figure 18).214-216 No single study strongly influenced the results, and no substantial heterogeneity was found. (SOE: Low; Neither drug favored)

Figure 18 Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a basal insulin with a combination of metformin plus a premixed insulin

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); HbA1c = hemoglobin A1c; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in hemoglobin A1c comparing a combination of metformin plus a basal insulin with a combination of metformin plus a premixed insulin.

#### Strength of Evidence for Hemoglobin A1c

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 6, Table 7, and Table 8 and summarized in the Key Points. All studies were RCTs. Study limitations for most comparisons were low or medium with only three comparisons having high study limitations due to lack of blinding, lack of description of withdrawals and dropouts, or very high losses to followup. Where quality influences the results, we describe that under the appropriate comparisons. In general, we did not find strong differences in outcomes in the lower versus higher quality studies. We did not find any evidence of publication bias using the Begg's and Egger's tests in most of the comparisons for HbA1c. A few of the monotherapy versus combination therapy comparisons had a statistically significant results on the publication bias test; however, these comparisons are likely to be missing both large and small negative studies favoring monotherapy. Therefore, we did not feel these statistically significant results represented a true publication bias. We also did not find any evidence of publication bias or reporting bias in the grey literature review which would change the overall conclusions. The grey literature was consistent with our findings for each of the comparisons, except for two comparisons (metformin versus DPP-4 inhibitors and metformin plus sulfonylurea versus metformin plus SGLT-2 inhibitors) where each had one study with results conflicting with the published results. These two studies under-dosed one of the study arms, making it more likely that conflicting results were from differing doses as opposed to publication bias. Only three studies did not report a measure of dispersion; therefore, we were able to combine most of the studies in meta-analyses, where appropriate.

Table 6 Strength of evidence domains for monotherapy comparisons in terms of hemoglobin A1c among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD | 25 (7365) | Medium | Consistent | Direct | Precise | Undetected | High | Neither drug favored; -0.04% (-0.11% to 0.03%)
Metformin vs. SU^‡^ | NA | NA | NA | NA | NA | NA | High | Neither drug favored; 0.1% (-0.1% to 0.3%)
Metformin vs. DPP-4 inhibitors | 6 (6700) | Low | Consistent | Direct | Precise | Undetected | High | Metformin favored-0.43% (-0.55% to -0.31%)
Metformin vs. SGLT-2 inhibitors | 3 (1633) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither drug favored
Metformin vs. GLP-1 receptor agonists | 3 (1089) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither drug favored
TZD vs. SU | 17 (6212) | Medium | Consistent | Direct | Precise | Undetected | High | Neither drug favored; -0.04% (-0.13% to 0.06%)
TZD vs. DPP-4 inhibitors | 3 (1686) | Low | Inconsistent | Direct | Imprecise | Suspected^†^ | Insufficient^¶^ | Unable to determine
TZD vs. GLP-1 receptor agonists | 2 (1048) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
SU vs. DPP-4 inhibitors | 3 (1271) | Low | Inconsistent | Direct | Imprecise | Suspected^‡^ | Insufficientǁ | Unable to determine
SU vs. GLP-1 receptor agonists | 4 (2056) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient^§^ | Unable to determine
DPP-4 inhibitors vs. SGLT-2 inhibitors | 1 (899) | Low | Unable to determine | Direct | Imprecise | Undetected | Insufficient | Unable to determine
DPP-4 inhibitors vs. GLP-1 receptor agonists | 2 (860) | Medium | Consistent | Direct | Imprecise | Undetected | Low | GLP-1 receptor agonist favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; NA = not applicable; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating hemoglobin A1c.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

‡ We did not re-evaluate hemoglobin A1c for the comparison of metformin with sulfonylureas, because we previously rated this comparison as having high strength of evidence.16

¶ For thiazolidinediones versus DPP-4 inhibitors, we graded the strength of evidence as insufficient, since there was only one comparably-dosed study which used maximum doses in each arm. We suspected reporting bias, since one study was found in the grey literature which favored thiazolidinediones while two of the three published studies showed no significant difference between-groups in hemoglobin A1c but underdosed the thiazolidinedione arms compared to the DPP-4 inhibitor arms.

ǁ For sulfonylureas versus DPP-4 inhibitors, we graded the strength as insufficient, since two of the three studies minimally favored sulfonylureas while one study did not favor either medication. Two additional studies found in the grey literature minimally favored sulfonylurea. Probably, sulfonylurea is mildly favored overall. We will be able to form a more formative opinion by the final report, since these two studies will be included in the updated search we will do between the draft and final report.

§ For sulfonylurea versus GLP-1 receptor agonist, only two comparably-dosed studies were identified and each showed different results. The two non-comparably-dosed studies favored the GLP-1 receptor agonist.

Table 7 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of hemoglobin A1c among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + TZD | 15 (6090) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin +TZD favored; range in pooled mean between-group differences in HbA1c, 0.3% to 0.9%
Metformin vs. metformin + SU | 17 (5210) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SU favored; 0.9% (0.7% to 1.2%)
Metformin vs. metformin + DPP-4 inhibitors (shorter duration studies) | 30 (18,056) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin + DPP-4 inhibitor favored; 0.65% (0.6% to 0.7%)
Metformin vs. metformin + DPP-4 inhibitors (longer duration studies) | 4 (4013) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + DPP-4 inhibitor favored; 0.5% (0.47% to 0.6%)
Metformin vs. metformin + SGLT-2 inhibitors | 9 (5778) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SGLT-2 inhibitor favored; 0.6% (0.5% to 0.7%)
Metformin vs. metformin + GLP-1 receptor agonists | 5 (2556) | Medium | Inconsistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 receptor agonist; range in between-group differences in HbA1c, 0.5% to 1.3%

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; HbA1c = hemoglobin A1c; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating hemoglobin A1c.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

Table 8 Strength of evidence domains for metformin-based combination comparisons in terms of hemoglobin A1c among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin +SU | 14 (3294) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Neither drug combination favored; -0.1% (-0.2% to 0.1)
Metformin + TZD vs. metformin +DPP-4 inhibitors | 5 (2413) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + TZD favored; -0.1% (-0.2% to -0.02%)
Metformin + TZD vs. metformin +GLP-1 receptor agonists | 2 (604) | Low | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin +DPP-4 inhibitors (shorter duration studies) | 5 (3300) | Medium | Inconsistent | Direct | Precise | Undetected | Low | Neither drug combination favored
Metformin + SU vs. metformin +DPP-4 inhibitors (longer duration studies) | 5 (7270) | High | Consistent | Direct | Precise | Undetected | Low | Neither drug combination favored
Metformin + SU vs. metformin +SGLT-2 inhibitors (longer duration studies) | 3 (3815) | Low | Consistent | Direct | Precise | Undetected | Moderate | Metformin + SGLT-2 inhibitor favored; 0.2% (0.1% to 0.2%)
Metformin + SU vs. metformin +GLP-1 receptor agonists | 7 (4375) | Medium | 1. Consistent for Met + SU vs Met + exenatide; 2. Inconsistent for Met + SU vs Met + other GLP-1 receptor agonist | Direct | Precise | Undetected | Low for #1 and insufficient for #2 | 1. Metformin + exenatide favored; 2. Unable to determine
Metformin + SU vs. metformin + basal insulin | 1 (75) | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + premixed insulin | 2 (827) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + DPP-4 inhibitors vs. metformin +SGLT-2 inhibitors | 4 (3423) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + SGLT-2 inhibitor favored; 0.2% (0.1% to 0.3%)
Metformin + DPP-4 inhibitors vs. metformin +GLP-1 receptor agonists | 4 (3322) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 receptor agonist favored; 0.7% (0.5% to 0.8%)
Metformin + DPP-4 inhibitors vs. metformin + basal insulin | 1 (515) | Medium | Unable to determine | Direct | Precise | Undetected | Low | Metformin + basal insulin favored
Metformin + GLP-1 receptor agonists vs. metformin + basal insulin | 1 (321) | Medium | Unable to determine | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + GLP-1 receptor agonists vs. metformin + premixed insulin | 1 (363) | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + basal insulin vs. metformin + premixed insulin | 3 (530) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating hemoglobin A1c.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Weight

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

In the prior report, we graded the evidence as high16 that metformin was significantly favored, with weight gain in the thiazolidinedione arms and weight loss in the metformin arms. Therefore, we did not re-evaluate this comparison for weight. (SOE: High; Metformin favored)

##### Metformin Versus Sulfonylureas

In the prior report, we graded the evidence as high16 that metformin was significantly favored, with weight gain in the sulfonylurea arms and mild weight loss in the metformin arms. Therefore, we did not re-evaluate this comparison for weight. (SOE: High; Metformin favored)

##### Metformin Versus DPP-4 Inhibitors

Six short RCTs (reported in nine articles) compared metformin with DPP-4 inhibitors, reporting greater reductions in weight with metformin (pooled between-group difference, -1.3 kg; 95% CI, -1.6 kg to -1.0 kg) (Figure 19).73, 80-87 No substantial heterogeneity was found in the meta-analysis, and no single study markedly influenced the results. Two RCTs (in three articles) were reported as extension studies.81, 85, 87 The extension studies, lasting 76 weeks and 104 weeks and with losses to followup ranging between 20 percent to 76 percent, all favored metformin over the DPP-4 inhibitors (between-group differences of -0.7 kg to -2.9 kg), consistent with the meta-analysis results from the shorter studies. Three RCTs had a lower dose and higher dose metformin arm.84-86 The higher dose metformin arms in two of the studies which compared metformin with alogliptin and sitagliptin both showed greater reductions in weight than the studies comparing lower dose metformin arms with alogliptin and sitagliptin.84, 85 The third RCT, comparing a low dose and high dose metformin arm with linagliptin, did not show this dose response.86 (SOE: High; Metformin favored)

Figure 19 Pooled mean between-group difference in weight comparing metformin with DPP-4 inhibitors

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing metformin with DPP-4 inhibitors.

##### Metformin Versus SGLT-2 Inhibitors

Two 24-week (reported in the same article) and one 90-week RCTs compared metformin with an SGLT-2 inhibitor (dapagliflozin or empagliflozin), showing greater reductions in weight with the SGLT-2 inhibitors (range of between-group differences in weight of -1.3 kg to -1.4 kg).88, 90 These between-group differences were statistically significant in two of the three RCTs.88 (SOE: Moderate; SGLT-2 inhibitors favored)

##### Metformin Versus GLP-1 Receptor Agonists

Three studies, each lasting one year or less, compared metformin with a GLP-1 receptor agonist, with conflicting effects on weight.73, 91, 92 We did not combine the studies in a meta-analysis due to study duration and dosing differences. Each of the three studies, lasting 24 to 52 weeks, compared metformin at 2000 to 2500 mg with a GLP-1 receptor agonist at maximum doses (exenatide 20 micrograms daily in the first study, exenatide 2 mg weekly in the second study, and dulaglutide 1.5 mg weekly in the third study). The first comparably-dosed, 26-week RCT of metformin titrated to 2500 mg daily compared with a fixed dose of 2 mg of exenatide weekly reported a mean between-group difference in weight of 0 kg (95% CI, -0.6 kg to 0.6 kg).73 The second 26-week RCT compared metformin titrated to 2000 mg with exenatide (10 micrograms twice daily).92 This RCT reported a mean between-group difference of 2.0 kg, favoring the GLP-1 receptor agonist arm (95% CI, 1.2 kg to 2.8 kg).92 The last 52-week RCT compared metformin titrated to 2000 mg with dulaglutide of 1.5 mg weekly, and reported a mean between-group difference in weight favoring the metformin arm of -0.7 kg (95% CI, -1.4 kg to -0.03 kg).91 (SOE: Insufficient)

##### Thiazolidinediones Versus Sulfonylureas

Seven studies, each lasting one year or less, compared a thiazolidinedione to a sulfonylurea, showing higher weight gain in the thiazolidinedione arms, with a pooled between-group difference of 1.2 kg (95% CI, 0.6 kg to 1.8 kg) (Figure 20).61, 74, 94, 95, 100, 103, 217 No single study markedly influenced the results, and no substantial heterogeneity was found.

Figure 20 Pooled mean between-group difference in weight comparing thiazolidinediones with sulfonylureas

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing thiazolidinediones with sulfonylureas.

One study showed a dose-response relationship between rosiglitazone and weight; patients treated with 4 mg per day of rosiglitazone gained 1.8 kg and those treated with 8 mg per day gained 3.0 kg, over 52 weeks compared with the glibenclamide arm which gained 1.9 kg.94

We excluded two RCTs from the meta-analysis due to their longer durations of 3 to 4 years.50, 52 Both RCTs had results consistent with the meta-analysis. As mentioned previously, the ADOPT study, with >50 percent loss to followup, evaluated the long-term glycemic control of metformin, rosiglitazone, and glyburide monotherapy as initial treatment for adults with type 2 diabetes, with weight as a secondary outcome.50 The between-group difference between rosiglitazone and glyburide was consistent with the results of the meta-analysis of the shorter studies, favoring sulfonylureas after approximately 5 years of followup (mean between-group difference, 2.5 kg; 95% CI, 2.0 kg to 3.1 kg). Of note, individuals in the glyburide arm gained weight over the first year and then stabilized, while those in the rosiglitazone arm had continued weight gain throughout the study. The second large, 3-year, multicenter study comparing pioglitazone with glibenclamide, also having > 50 percent losses to followup, showed a 5.2 kg weight gain in the pioglitazone-treated group and a 0.9 kg weight gain in the glibenclamide-treated group.52 (SOE: Moderate; Sulfonylurea favored)

##### Thiazolidinediones Versus DPP-4 Inhibitors

Two 26-week RCTs compared thiazolidinediones with DPP-4 inhibitors; both studies significantly favored DPP-4 inhibitors with a mean between-group difference of 2.3 kg and 2.5 kg.73, 104 The thiazolidinedione arms increased weight by around 1.8 kg while the DPP-4 inhibitor arms decreased weight by around 0.5 kg. (SOE: Moderate; DPP-4 inhibitors favored)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

Two comparably-dosed RCTs compared thiazolidinediones (pioglitazone) with GLP-1 receptor agonists (exenatide), with both favoring exenatide by 3.5 kg. One double-blind moderately-sized RCT compared pioglitazone titrated to 45 mg daily with exenatide 2 mg weekly.73 After 26 weeks, the calculated between-group difference in weight favored exenatide by 3.5 kg (95% CI, 2.8 kg to 4.2 kg).73 The pioglitazone arm increased weight by 1.5 kg, and the exenatide arm decreased weight by 2 kg. The second open-label RCT compared pioglitazone at 45 mg daily with exenatide 10 ug twice daily. After 48 weeks, the calculated mean between-group difference in weight favored exenatide by 3.5 kg (95% CI, 2.4 kg to 4.6 kg).105 (SOE: Moderate; GLP-1 receptor agonists favored)

##### Sulfonylureas Versus DPP-4 Inhibitors

Three RCTs, each lasting 54 weeks or less, compared a sulfonylurea (glipizide or glimepiride) with a DPP-4 inhibitor (sitagliptin or linagliptin) and favored the DPP-4 inhibitor arms (range in mean between-group differences of 0.9 kg to 1.8 kg).106-108 This difference was significant in two of the three studies; one study did not provide sufficient data to assess.108 We did not combine these studies due to dosing and study population differences. Sulfonylureas increased weight by about 1.2 kg, and the DPP-4 inhibitors decreased weight by around 0.4 kg, in these studies. (SOE: Low; DPP-4 inhibitors favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Four RCTs comparing sulfonylureas directly with liraglutide showed greater weight gain with a sulfonylurea (pooled mean between-group difference, 2.3 kg; 95% CI, 1.2 kg to 3.3 kg) (Figure 21).109-112 No single study strongly influenced the results. Substantial heterogeneity was found. Potential sources of heterogeneity were dosing differences, study duration differences, and differences in baseline weight. The one study with the largest between-group difference in weight112 lasted at least 24 weeks longer than the other two studies, used medications titrated to the maximum dose in both arms, and started with a higher baseline BMI. (SOE: Moderate; GLP-1 receptor agonists favored)

Figure 21 Pooled mean between-group difference in weight comparing sulfonylureas with GLP-1 receptor agonists

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); GLP-1 = glucagon-like peptide-1; kg = kilogram; pl = profile likelihood estimate

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The line at the bottom of the graph indicates the 95 percent confidence interval for the profile likelihood pooled estimate.

Pooled mean between-group difference in weight comparing sulfonylureas with GLP-1 receptor agonists.

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

One double-blind, moderately-sized, 24-week RCT compared the DPP-4 inhibitor, sitagliptin at 100 mg daily, with the SGLT-2 inhibitor, empagliflozin at 10 mg and 25 mg daily. The results significantly favored the empagliflozin arms (calculated mean between-group difference of 2.5 kg and 2.7 kg for the low dose and high dose empagliflozin arms, respectively).114 The sitagliptin-treated patients maintained weight, and the empagliflozin-treated patients decreased weight, over the 24 weeks. (SOE: Moderate; SGLT-2 inhibitors favored)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

Two RCTs compared a DPP-4 inhibitor (sitagliptin) with a GLP-1 receptor agonist (exenatide or liraglutide), with both favoring the GLP-1 receptor agonist. The first double-blind RCT compared sitagliptin at 100 mg daily with exenatide 2 mg weekly for 26 weeks, with greater weight reduction in the exenatide arm (calculated mean between-group difference in weight of 1.2 kg; 95% CI, 0.5 kg to 1.9 kg).73 A second open-label RCT, with 40 subjects and lasting 24 weeks, compared sitagliptin at 50 mg daily with liraglutide titrated to 0.9 mg daily, with no significant difference in weight between groups (calculated mean between-group difference in weight of 1.5 kg; 95% CI, -24 kg to 27 kg).115 (SOE: Low; GLP-1 receptor agonists favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

We combined six studies which directly compared metformin monotherapy with the combination of metformin plus a thiazolidinedione (mostly rosiglitazone), showing a pooled between-group difference in weight of -2.2 kg (95% CI, -2.6 kg to -1.9 kg) favoring metformin (Figure 22).59, 117, 118, 120, 123, 125 No single study markedly affected the results, and there was no significant heterogeneity between studies. All six studies showed that the metformin arms had weight loss while the combination arms had weight gain. Four studies were excluded from the meta-analysis due to insufficient quantitative data to combine the studies67, 116, 126 or due to study duration differences.127 All four of these studies reported modest weight gain in the combination arms, which was consistent with the studies included in the meta-analysis.67, 116, 126, 127 (SOE: High; Metformin favored)

Figure 22 Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a thiazolidinedione

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a thiazolidinedione.

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

Ten short RCTs compared metformin with the combination of metformin plus a sulfonylurea, favoring metformin monotherapy, with a pooled between-group difference of -2.2 kg (95% CI, -3.4 kg to -1.0 kg) (Figure 23).128-130, 132-137, 139 No single study markedly influenced the results. While heterogeneity existed, all studies favored the metformin arm over the combination arm, with minimal between-group differences among the studies. In meta-regression, baseline weight was identified as a significant source of heterogeneity; dosing differences, double blinding, study duration, and appropriate randomization were not identified as significant. Baseline weight explained 55 percent of the between-study heterogeneity (adjusted r-squared = 55%). We present the stratified meta-analyses in Table 9. One 104-week study with 30 percent to 40 percent loss to followup, depending on the treatment arm, was excluded from the meta-analysis due to its long duration.141 The mean between-group difference in weight favored the metformin monotherapy arm, non-significantly, by 2.2 kg.141 (SOE: High; Metformin favored)

Figure 23 Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a sulfonylurea

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The line at the bottom of the graph indicates the 95 percent confidence interval for the profile likelihood pooled estimate.

Pooled mean dbetween-group difference in weight comparing metformin with a combination of metformin plus a sulfonylurea.

Table 9 Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a sulfonylurea, stratified by baseline weight

Variables | N of Studies | WMD (95% CI) | I^2^ | Summary
Baseline weight ≥ 90 kg^*^ | 5 | -3.2 kg (-4.6 kg to -1.6 kg) | 56% | Favors metformin
Baseline weight < 90 kg | 5 | -1.2 kg (-1.8 kg to -0.6 kg) | 0% | Favors metformin

CI = confidence interval; kg = kilogram; WMD = weighted mean difference

* Analysis was calculated using a profile likelihood estimate.

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

We combined twenty RCTs, each lasting 1 year or less, comparing metformin with the combination of metformin plus a DPP-4 inhibitor (pooled between-group difference of -0.1 kg; 95% CI, -0.24 kg to 0.03 kg) (Figure 24).51, 81, 83, 84, 86, 118, 139, 145, 146, 148, 150-155, 157-160 No substantial heterogeneity was found. In a standard sensitivity analysis, the removal of the study by Lavalle-Gonzalez and colleagues significantly changed the pooled estimate to significantly favor metformin monotherapy slightly. However, there were no clear qualitative differences to prompt removal of this study. Two studies147, 162 were excluded from the meta-analysis due to higher doses of metformin in the monotherapy arms by 500 to 1000 mg daily compared with the combination arms. In these two studies, greater weight loss was seen in the metformin monotherapy arms.147, 162 Six studies with similar results to the other studies were excluded from the short duration meta-analysis due to absence of data needed to quantitatively combine the studies.126, 143, 144, 149, 156, 163

Figure 24 Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration.

We also pooled three longer studies (two of which were extension studies), each lasting 76 to 104 weeks and with greater than 20 percent losses to followup, that compared metformin with a metformin plus a DPP-4 inhibitor. Consistent with the short studies, these trials showed no significant difference in weight (pooled between-group difference in weight of 1.1 kg; 95% CI, -2.3 kg to 0.07 kg) (Figure 24).85, 87, 141 No single study markedly influenced the results, and no substantial heterogeneity was found. (SOE: Moderate; Neither favored for studies 52 weeks or shorter) (SOE: Low; Neither drug favored for studies 1.5 to 2 years)

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Seven RCTs (reported in six articles), each lasting 26 weeks or less, compared metformin alone with the combination of metformin plus an SGLT-2 inhibitor, with greater weight reductions in the combination arm (pooled between-group difference in weight of 2.0 kg; 95% CI, 1.5 kg to 2.5 kg) (Figure 25).88, 153, 158, 165, 166, 168 No single study markedly influenced the results. There was substantial statistical heterogeneity among the studies, yet the individual between-group differences were similar among the studies. One additional short RCT was excluded, since it only reported percent change in weight, but it also favored the combination of metformin plus an SGLT-2 inhibitor.156 Two 102-week RCTs were excluded from the meta-analysis due to study duration differences.169, 170 These longer RCTs, with 20 percent to 40 percent losses to followup, also significantly favored the combination of metformin plus an SGLT-2 inhibitor, with the range in between-group differences in weight of 2.4 kg to 3.1 kg. (SOE: High; Combination of metformin plus a SGLT-2 inhibitor favored)

Figure 25 Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram; pl = profile likelihood estimate; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The line at the bottom of the graph indicates the 95 percent confidence interval for the profile likelihood pooled estimate.

Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Five RCTs, each lasting 48 weeks or less, compared metformin with the combination of metformin plus a GLP-1 receptor agonist, with all five studies showing greater weight reduction in the combination metformin plus GLP-1 receptor agonist arm (pooled between-group difference of 2.0 kg; 95% CI, 1.3 kg to 2.7 kg) (Figure 26).159, 171-174 No one study strongly influenced the pooled results, and no substantial heterogeneity was identified. The one short study which had two dosing arms of the combination showed a smaller between-group difference in weight when comparing the metformin monotherapy arm to the lower dose combination arm versus the higher dose combination arm.159 One 104-week RCT excluded from the meta-analysis showed a non-significant greater weight reduction in the combination arm of 0.2 kg, but had 30 percent to 40 percent losses to followup, depending on the treatment arm.141 (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

Figure 26 Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); GLP-1 = glucagon-like peptide-1; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing metformin with a combination of metformin plus a GLP-1 receptor agonist.

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

We combined six comparably-dosed studies, each lasting less than one year, that directly compared metformin plus a thiazolidinedione with metformin plus a sulfonylurea.175-178, 181, 218 The pooled mean between-group difference favored the combination of metformin plus sulfonylurea by 0.9 kg (95% CI, 0.4 kg to 1.3 kg) (Figure 27). No one study markedly influenced the results, and no substantial heterogeneity was found.

Figure 27 Pooled mean between-group difference in weight comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); Met = metformin; kg = kilogram; SU = sulfonylurea; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea.

In the meta-analysis, we included the short-term results from the large RECORD study.176 The RECORD study was a multicenter, open-label RCT evaluating 4,447 patients with type 2 diabetes and uncontrolled glycemia already on metformin or sulfonylurea monotherapy, with less than 20 percent losses to followup.49, 176 Body weight increased significantly with rosiglitazone plus metformin compared with sulfonylurea plus metformin, with a mean between-group difference of 1.2 kg (95% CI, 0.4 kg to 2.0 kg) after 18 months.176 The mean between-group difference increased to 3.8 kg after 5 years of followup.49

We excluded three short RCTs from the meta-analysis, since the dosing was not comparable with the other studies.180, 184, 185 One180 used a lower dose of metformin in the metformin plus sulfonylurea arm compared with a higher dose of metformin in the metformin plus thiazolidinedione arm. The two other short RCTs used low doses of a sulfonylurea in the metformin plus sulfonylurea arm.184, 185 As a sensitivity analysis, we included these three RCTs in the meta-analysis and noted no meaningful change in results (pooled mean between-group difference in weight of 0.8 kg).180, 184, 185 (SOE: Moderate; Combination of metformin plus a sulfonylurea favored)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Four short-duration RCTs compared metformin plus a thiazolidinedione with the combination of metformin plus a DPP-4 inhibitor, favoring the combination of metformin plus a DPP-4 inhibitor (pooled mean between-group difference of 2.7 kg; 95% CI, 0.8 kg to 4.5 kg) (Figure 28).118, 186-188 The patients in the metformin plus DPP-4 inhibitor arms had a mean weight loss, and the patients in the metformin plus thiazolidinedione arms had a mean weight gain. No single study markedly influenced the results. Substantial heterogeneity was identified; however, all four studies favored the metformin plus DPP-4 inhibitor arms by 1.4 to 3.6 kg. We were unable to quantitatively explore heterogeneity due to the small numbers of studies, but there were differences in baseline weight and drug types.

Figure 28 Pooled mean between-group difference in weight comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); Met = metformin; kg = kilogram; pl = profile likelihood estimate; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The line at the bottom of the graph indicates the 95 percent confidence interval for the profile likelihood pooled estimate.

Pooled mean between-group difference in weight comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a DPP-4 inhibitor.

One additional short-duration RCT comparing metformin plus pioglitazone with metformin plus alogliptin was excluded from the meta-analysis, since it did not have sufficient quantitative data.126 The study reported a decrease in weight of 0.7 kg in the metformin plus alogliptin arms but only stated qualitatively that there was an increase in weight in the metformin plus pioglitazone arm, consistent with the direction of weight change in the other four studies.126 (SOE: Moderate; Combination of metformin plus a DPP-4 inhibitor favored)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two short, comparably-dosed RCTs compared metformin plus thiazolidinediones (pioglitazone or rosiglitazone) with metformin plus a GLP-1 receptor agonist (exenatide).188, 189 Both studies significantly favored the combination of metformin plus a GLP-1 receptor agonist (range in mean between-group differences in weight, 2.7 kg to 5.1 kg). Both studies had weight gain in the metformin plus thiazolidinedione arms and weight loss in the metformin plus GLP-1 receptor agonist arms. (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Nine RCTS (reported in ten articles) compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor.139, 141, 190-197 Both the shorter (1 year or less) and longer (2-year) studies favored the metformin plus DPP-4 inhibitor arms (Figure 29). The metformin plus sulfonylurea arms all had weight gain, and the metformin plus DPP-4 inhibitor arms all had weight loss or weight maintenance. The five RCTs, each lasting 1 year or less, had a pooled between-group difference in weight of 2.1 kg (95% CI, 1.8 kg to 2.3 kg)139, 190-193 and the five RCTs, each lasting 2 years and with greater than 30 percent losses to followup, had a pooled between-group difference of 2.4 kg (95% CI, 1.9 kg to 2.9 kg).141, 194-197 No single study markedly influenced the results. While substantial statistical heterogeneity was identified in the meta-analysis of the longer studies, all studies favored the combination with similar effects. (SOE: High; Combination of metformin plus a DPP-4 inhibitor favored)

Figure 29 Pooled mean between-group difference in weight comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram; Met = metformin; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs, each lasting 52 to 104 weeks, compared the combination of metformin plus a sulfonylurea (glimepiride or glipizide) with the combination of metformin plus an SGLT-2 inhibitor (canagliflozin, dapagliflozin, or empagliflozin).198-200 The combination of metformin plus an SGLT-2 inhibitor was strongly favored (pooled mean between-group difference in weight of 4.7 kg; 95% CI, 4.4 kg to 5.0 kg) (Figure 30). No single study markedly influenced the results, and no substantial heterogeneity was found. One of the RCTs, which had a lower and higher dose metformin plus canagliflozin arm, demonstrated a small dose-response effect in weight reduction, with a smaller mean between-group difference in weight in the lower dose arm of 4.4 kg versus 4.7 kg in the higher dose arm.198 Two extension studies, lasting 2 years201 and 4 years54 with 30 percent to 60 percent losses to followup, were also identified, showing consistent findings to the shorter studies (calculated mean between-group differences in weight of 4.4 kg favoring the combination of metformin plus an SGLT-2 inhibitor). (SOE: High; Combination of metformin plus a SGLT-2 inhibitor favored)

Figure 30 Pooled mean between-group difference in weight comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram; Met = metformin; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Four RCTs, three lasting less than 1 year and one lasting 2 years, compared metformin plus sulfonylurea with metformin plus a GLP-1 receptor agonist.141, 203-205 These favored the combination of metformin and GLP-1 receptor agonist (range in mean between-group differences of 2.4 kg to 12.3 kg). All four RCTs showed weight loss with the combination of metformin and GLP-1 receptor agonists and weight gain with the combination of metformin and sulfonylureas. We did not combine these studies in a meta-analysis due to differences in drug dosing, drug type, and study duration.

One RCT compared metformin plus a sulfonylurea with three different dosing arms of metformin plus liraglutide. The arms with lower doses of liraglutide had smaller between-group differences in weight relative to the higher dose arm.204 (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Basal Insulin

One small, open-label RCT, lasting 48 weeks, compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a basal insulin, favoring metformin plus sulfonylurea (mean between-group difference in weight of -1.7 kg; 95% CI, -3.1 kg to -0.3 kg).206 Patients were kept on their prior metformin doses and were randomized to uptitration of glimepiride (mean daily dose of 4 mg) versus uptitration of insulin glargine (mean daily dose of 23 units) until a fasting plasma glucose target was reached. Individuals in the metformin plus sulfonylurea arm had no change in weight, and those in the metformin plus insulin glargine arm gained weight. (SOE: Low; Combination of metformin plus a sulfonylurea favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Premixed Insulin

Two short RCTs compared metformin plus glibenclamide with the combination of metformin plus a premixed insulin analogue: insulin aspart 70/30 in one study and insulin lispro 75/25 in the other study.207, 208 Both studies favored the metformin plus sulfonylurea arms (range in between-group differences of -0.7 kg to -0.5 kg). One of the two studies showed a statistically significant difference. There was not a mean decrease in weight in any of the study arms.

Of note, if we combine the three studies comparing metformin plus sulfonylurea with metformin plus a premixed or basal insulin (adding in the study described in the prior comparison), metformin plus sulfonylurea is favored, with a weighted mean between-group difference in weight of -0.67 kg (95% CI, -0.83 kg to -0.51 kg). No single study influenced the results and no substantial heterogeneity was identified. Since premixed and basal insulins may have similar effects on weight, it may be reasonable to combine these categories. (SOE: Low; Combination of metformin plus a sulfonylurea favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Five RCTs compared metformin plus a DPP-4 inhibitor with the combination of metformin plus an SGLT-2 inhibitor (range in mean between-group differences in weight of 1.8 kg to 3.6 kg).90, 153, 156, 158, 209 All five studies significantly favored the combination of metformin plus an SGLT-2 inhibitor. We did not combine these studies due to differences in study duration and reporting of the outcome. The first 12-week RCT reported a mean percent change in weight of -0.6 percent in the metformin plus DPP-4 arm versus -3.4 percent in the metformin plus SGLT-2 inhibitor arm.156 The second 12-week RCT reported a mean between-group difference in weight of 1.8 kg (95% CI, 1.9 kg to 2.7 kg).153 The third 24-week RCT had a calculated mean between-group difference in weight of 2.4 kg (95% CI, 1.7 kg to 3.1 kg), favoring the metformin plus dapagliflozin arm over the metformin plus alogliptin arm.209 The two longer RCTs, lasting 52 to 90 weeks and with less than 20 percent losses to follow-up, reported mean between-group differences of 2.9 kg and 3.6 kg, favoring the metformin plus SGLT-2 inhibitor arms.90, 158 Two of the three studies with lower dose and higher dose combinations of metformin plus SGLT-2 inhibitor arm demonstrated a dose-response effect in weight reduction, with smaller between-group differences in the lower dose arms and larger between-group differences in the higher dose arms.90, 158 (SOE: Moderate; Combination of metformin plus a SGLT-2 inhibitor favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

We combined three short RCTs comparing the combination of metformin plus a DPP-4 inhibitor with the combination of metformin plus a GLP-1 receptor agonist.159, 188, 210 All three studies significantly favored the combination of metformin plus a GLP-1 receptor agonist (pooled mean between-group difference, 1.8 kg; 95% CI, 1.1 kg to 2.5 kg) (Figure 31). Individuals in both arms lost weight but the metformin plus GLP-1 receptor agonist decreased weight more than the metformin plus DPP-4 treatment. No single study markedly influenced the results. Moderate heterogeneity was identified, although studies and point estimates were relatively similar.

Figure 31 Pooled mean between-group difference in weight comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); GLP-1 = glucagon-like peptide-1; kg = kilogram; Met = metformin; pl = profile likelihood estimate

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The line at the bottom of the graph indicates the 95 percent confidence interval for the profile likelihood pooled estimate.

Pooled mean between-group difference in weight comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist.

The two studies with both low dose and high dose arms of the GLP-1 receptor agonist showed smaller between-group differences in weight for the lower dose arms (between-group differences for lower dose arms of 1.9 kg and 1.1 kg compared with the higher dose arm of 2.5 kg and 1.5 kg).159, 210

One 104-week RCT, with 30 percent to 40 percent losses to followup depending on the treatment arm, reported a non-significant between-group difference in weight of 0.4 kg (95% CI, -4.7 kg to 5.4 kg).141 (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a Basal Insulin

One 24-week RCT compared metformin plus sitagliptin (100 mg daily) with metformin plus insulin glargine titrated to 0.5 units per kg. The RCT significantly favored the metformin plus DPP-4 arm (mean between-group difference in weight of -1.5 kg; 95% CI, -2.1 kg to -0.9 kg).211 The metformin plus DPP-4 arm decreased weight, and the metformin plus insulin glargine arm increased weight. (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored)

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Basal Insulin

One 26-week, comparably-dosed RCT compared metformin plus exenatide (2 mg weekly) with metformin plus glargine insulin (titrated based on blood sugars). This RCT showed a mean between-group difference of -4.7 kg, favoring the combination of metformin plus a GLP-1 receptor agonist.212 (SOE: Insufficient)

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Premixed Insulin

One moderately-sized RCT, lasting 26 weeks, compared the combination of metformin plus exenatide (titrated to 20 micrograms) with the combination of metformin plus premixed insulin (titrated to glucose target, mean dose 28 units).213 The RCT significantly favored metformin plus exenatide (mean between-group difference in weight of -5.1 kg; 95% CI, -5.7 kg to -4.5 kg). The metformin plus GLP-1 receptor agonist arm decreased weight, and the metformin plus premixed insulin arm increased weight. (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

Three RCTs directly compared the combination of metformin plus basal insulin with the combination of metformin plus premixed insulin, showing no between-group differences in weight (pooled mean between-group difference of -1.8 kg; 95% CI, -7.8 kg to 4.2 kg) (Figure 32).214-216 No single study strongly influenced the results, and no substantial heterogeneity was found. (SOE: Low; Neither treatment favored)

Figure 32 Pooled mean between-group difference in weight comparing a combination of metformin plus a basal insulin with a combination of metformin plus a premixed insulin

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); kg = kilogram; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in weight comparing a combination of metformin plus a basal insulin with a combination of metformin plus a premixed insulin.

#### Strength of Evidence for Weight

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 10, Table 11, and Table 12 and summarized in the Key Points. All studies were RCTs. Study limitations for most comparisons were low or medium, with only two comparisons having high study limitations due to lack of blinding, lack of description of withdrawals and dropouts, and very high losses to followup. Where quality influences results, we describe that under the appropriate comparisons. In general, we did not find strong differences in outcomes in the lower-quality versus higher-quality studies. We did not find any evidence of publication bias in any of the comparisons for weight which would have impacted the results. We also did not find any evidence of publication bias or reporting bias in the grey literature review. Eleven studies did not report a measure of dispersion; however, addition of these studies would not have importantly changed our conclusions or the strength of evidence assessment. We considered weight a direct outcome, since patients care about weight independent of its cardiovascular effects. Several of the comparisons were downgraded due to imprecision. The comparisons were considered imprecise mainly due to the small and not clinically relevant between-group differences in weight of 2 pounds or less.

Table 10 Strength of evidence domains for monotherapy comparisons in terms of weight among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD^‡^ | NA | NA | NA | NA | NA | NA | High | Metformin favored; -2.6 kg (-4.1 to -1.2 kg)
Metformin vs. SU^‡^ | NA | NA | NA | NA | NA | NA | High | Metformin favored; -2.7 kg (-3.5 to -1.9 kg)
Metformin vs. DPP-4 inhibitors | 6 (6700) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin favored; -1.3 kg (-1.6 to -1.0 kg)
Metformin vs. SGLT-2 inhibitors | 3 (1903) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | SGLT-2 inhibitors favored; range of between-group differences, -1.3 to -1.4 kg
Metformin vs. GLP-1 receptor agonists | 3 (1089) | Low | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
TZD vs. SU | 9 (6766) | Medium | Inconsistent | Direct | Precise | Undetected | Moderate | SU favored; 1.2 kg (0.6 to 1.8 kg)
TZD vs. DPP-4 inhibitors | 2 (1475) | Low | Consistent | Direct | Precise | Undetected | Moderate | DPP-4 inhibitors favored; range in between-group differences, 2.3 to 2.5 kg
TZD vs. GLP-1 receptor agonists | 2 (1048) | Low | Consistent | Direct | Precise | Undetected | Moderate | GLP-1 receptor agonists favored; between-group differences for both studies, 3.5 kg
SU vs. DPP-4 inhibitors | 3 (1271) | Low | Consistent | Direct | Imprecise | Undetected | Low | DPP-4 inhibitors favored
SU vs. GLP-1 receptor agonists | 4 (1157) | Medium | Consistent | Direct | Precise | Undetected | Moderate | GLP-1 receptor agonists favored; 2.3 (1.2 to 3.3 kg)
DPP-4 inhibitors vs. SGLT-2 inhibitors | 1 (899) | Low | Unknown | Direct | Precise | Undetected | Moderate | SGLT-2 inhibitors favored; between-group difference, 2.5 to 2.7 kg
DPP-4 inhibitors vs. GLP-1 receptor agonists | 2 (860) | Low | Consistent | Direct | Imprecise | Undetected | Low | GLP-1 receptor agonists favored

DPP-4 = dipeptidyl-peptidase 4; GLP-1 = glucagon-like peptide-1; SGLT-2 = sodium-glucose co-transporter 2; SU = sulfonylurea; TZD = thiazolidinedione

* Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

‡ We did not re-evaluate weight for the comparisons of metformin with thiazolidinediones and metformin with sulfonylureas because we previously rated these comparisons as having high strength of evidence.16

Table 11 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of weight among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + TZD | 10 (5102) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin favored; -2.2 kg (-2.6 to -1.9 kg)
Metformin vs. metformin + SU | 11 (3692) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin favored; -2.2 kg (-3.4 to -1.0 kg)
Metformin vs. metformin + DPP-4 inhibitors (studies 1 year or shorter) | 28 (16,837) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Neither treatment favored; -0.1 kg (-0.2 to 0.03 kg)
Metformin vs. metformin + DPP-4 inhibitors (studies 1.5 to 2 years) | 3 (3446) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. metformin + SGLT-2 inhibitors | 10 (5978) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SGLT-2 inhibitors favored; 2.0 kg (1.5 to 2.5 kg)
Metformin vs. metformin + GLP-1 receptor agonists | 6 (2882) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 receptor agonists favored; 2.0 kg (1.3 to 2.7 kg)

DPP-4 = dipeptidyl-peptidase 4; GLP-1 = glucagon-like peptide-1; SGLT-2 = sodium-glucose co-transporter 2; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

‡ We did not re-evaluate weight for the comparisons of metformin with thiazolidinediones and metformin with sulfonylureas because we previously rated these comparisons as having high strength of evidence.16

Table 12 Strength of evidence domains for metformin-based combination comparisons in terms of weight among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + SU | 9 (2928) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + SU favored; 0.9 kg (0.4 to 1.3 kg)
Metformin + TZD vs. metformin + DPP-4 inhibitors | 5 (2413) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin + DPP-4 inhibitors favored; 2.7 kg (0.8 to 4.5 kg)
Metformin + TZD vs. metformin + GLP-1 receptor agonists | 2 (604) | Low | Consistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 receptor agonists favored; range in mean between-group differences, 2.7 to 5.1 kg
Metformin + SU vs. metformin + DPP-4 inhibitors (studies ≤ 1 year) | 5 (3300) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + DPP-4 inhibitors favored; 2.1 kg (1.8 to 2.3 kg)
Metformin + SU vs. metformin + DPP-4 inhibitors (2-year studies) | 5 (7270) | High | Consistent | Direct | Precise | Undetected | Low | Metformin + DPP-4 inhibitors favored
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer duration studies) | 3 (3815) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SGLT-2 inhibitors favored; 4.7 kg (4.4 to 5.0 kg)
Metformin + SU vs. metformin + GLP-1 receptor agonists | 4 (3304) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin + GLP-1 receptor agonists favored; range in between-group differences 2.4 kg to 12.3 kg
Metformin + SU vs. metformin + basal insulin | 1 (75) | Medium | Unknown | Direct | Precise | Undetected | Low^**^ | Metformin + SU favored
Metformin + SU vs. metformin + premixed insulin | 2 (819) | Medium | Consistent | Direct | Imprecise | Undetected | Low^**^ | Metformin + SU favored
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 5 (3423) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + SGLT-2 inhibitors favored; range in between-group differences 1.8 to 3.6 kg
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | 4 (3322) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 receptor agonists favored; 1.8 kg (1.1 to 2.5 kg)
Metformin + DPP-4 inhibitors vs. metformin + basal insulin | 1 (515) | Medium | Unknown | Direct | Precise | Undetected | Low | Metformin + DPP-4 inhibitors favored
Metformin + GLP-1 receptor agonists vs. metformin + basal insulin | 1 (321) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine effect
Metformin + GLP-1 receptor agonists vs. metformin + premixed insulin | 1 (363) | High | Unknown | Direct | Precise | Undetected | Low | Metformin + GLP-1 receptor agonists favored
Metformin + basal insulin vs. metformin + premixed insulin | 3 (530) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored

DPP-4 = dipeptidyl-peptidase 4; GLP-1 = glucagon-like peptide-1; SGLT-2 = sodium-glucose co-transporter 2; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

** While each of these comparisons are rated low strength of evidence due to low numbers of studies, this would move to moderate if all three studies were combined in a row of metformin plus sulfonylurea versus metformin plus premixed or basal insulin, since all three studies were consistent, direct, precise, study limitations were medium, and reporting bias was undetected. Since premixed and basal insulins may have similar effects on weight, it may be reasonable to combine these categories.

### Evidence for Systolic Blood Pressure

#### Monotherapy Comparisons

##### Metformin Versus SGLT-2 Inhibitors

We combined three short RCTs (reported in two articles) directly comparing metformin with a SGLT-2 inhibitor, favoring SGLT-2 inhibitors in systolic blood pressure reduction.88, 89 Each study compared metformin with dapagliflozin,88, 89 resulting in a pooled mean between-group difference in systolic blood pressure of 2.8 mmHg (95% CI, 2.6 mmHg to 3.0 mmHg) favoring SGLT-2 inhibitors over metformin (Figure 33). The metformin arms decreased mean systolic blood pressure by 0.4 mmHg to 1.8 mmHg, and the SGLT-2 inhibitors arms decreased mean systolic blood pressure by 4.0 mmHg to 6.4 mmHg. No single study markedly influenced the results, and there was no substantial heterogeneity.

Figure 33 Pooled mean between-group difference in systolic blood pressure comparing metformin with SGLT-2 inhibitors

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); mmHg = millimeters mercury; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in systolic blood pressure comparing metformin with SGLT-2 inhibitors.

We excluded one study from the meta-analysis given its length.90 This trial was a randomized, open-label, 78-week extension of two shorter trials of empagliflozin. There was a non-significant between-group difference in systolic blood pressure of 3.7 mmHg (95% CI, -1.3 mmHg to 8.7 mmHg).90 The metformin arm increased the mean systolic blood pressure by 2 mmHg, and empagliflozin (10 mg) increased mean systolic blood pressure by 0.1 mmHg, and empagliflozin (25 mg) decreased mean systolic blood pressure by 1.7 mmHg. (SOE: Moderate; SGLT-2 inhibitors favored)

##### Metformin Versus GLP-1 Receptor Agonists

Two RCTs compared metformin with a GLP-1 receptor agonist, with inconclusive results.73, 91 The first study was a 52-week RCT which compared two doses of dulaglutide with metformin; there was a 20 percent loss to followup in all arms. The RCT reported a non-significant between-group difference in systolic blood pressure of 1.7 mmHg (95% CI, -0.7 mmHg to 4.1 mmHg) with dulaglutide (0.75 mg weekly) and 0.9 mmHg (95% CI, -1.5 mmHg to 3.3 mmHg) with dulaglutide (1.5 mg weekly). The metformin arm increased mean systolic blood pressure by 1.0 mmHg, and the dulaglutide arms increased mean systolic blood pressure by 0.1 mmHg to 2.7 mmHg.91 The second study was a 26-week RCT which showed a systolic blood pressure reduction of 1.3 mmHg with exenatide, but did not provide systolic blood pressure results for the metformin arm.73 (SOE: Low; Neither drug favored)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

Two RCTs, ranging in duration from 26 to 48 weeks, compared pioglitazone with exenatide with inconsistent results.73, 105 One 26-week RCT reported a non-significant between-group difference in systolic blood pressure of 0.4 mmHg (95% CI, -2.1 mmHg to 2.9 mmHg).73 One 48-week RCT reported a significant between-group difference in systolic blood pressure of 3.0 mmHg (95% CI, 0.2 to 5.8 mmHg), favoring the GLP-1 arm.105 (SOE: Insufficient)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

One 104-week RCT compared glimepiride with liraglutide, and showed a non-significant between-group difference in systolic blood pressure of 0.9 mmHg (95% CI, -1.5 mmHg to 3.2 mmHg) with 1.2 mg of liraglutide and 1.9 mmHg (95% CI, -0.5 mmHg to 4.2 mmHg) with 1.8 mg of liraglutide.113 Participants in all arms had a mean decrease in systolic blood pressure. There was high loss to followup of 50 percent to 60 percent, among all arms. (SOE: Low; Neither drug favored)

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

One double-blind, 24-week RCT compared sitagliptin (100 mg daily) to empagliflozin (10 mg and 25 mg daily). This RCT reported significant between-group differences in systolic blood pressure of 3.4 mmHg (95% CI, 1.2 mmHg to 5.7 mmHg) with 10mg of empagliflozin and 4.2 mmHg (95% CI, 2.0 mmHg to 6.5 mmHg) with 25mg of empagliflozin, favoring the SGLT-2 inhibitor over the DPP-4 inhibitor.114 The DPP-4 inhibitor increased mean systolic blood pressure by 0.5 mmHg, and the empagliflozin decreased mean systolic blood pressure by 2.9 to 3.7 mmHg. (SOE: Low; SGLT-2 inhibitors favored)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

Two RCTs, ranging in duration from 24 to 26 weeks, compared sitagliptin with a GLP-1 receptor agonist.73, 115 One 26-week RCT, compared sitagliptin (100 mg daily) with exenatide (2 mg weekly), reporting a non-significant between-group difference in systolic blood pressure of 0.5 mmHg (95% CI -2.0 mmHg to 3.0 mmHg).73 The DPP-4 inhibitor decreased mean systolic blood pressure by 1.8 mmHg, and the GLP-1 receptor agonist decreased mean systolic blood pressure by 1.3 mmHg. One 24-week RCT, comparing sitagliptin (50 mg daily) with liraglutide (titrated to 0.9 mg daily), had a small number of participants in each arm and a high withdrawal rate. They reported a non-significant between-group difference in systolic blood pressure of 6.9 mmHg (95% CI, -13.2 mmHg to 27.0 mmHg). This study reported high loss to followup (16 of 56 participants withdrew).115 (SOE: Low; Neither drug favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Seven RCTs (reported in six articles), each lasting less than one year, compared metformin to a combination of metformin and a SGLT-2 inhibitor. All studies favored the combination arm (pooled mean between-group difference in systolic blood pressure of 4.4 mmHg; 95% CI, 2.9 mmHg to 6.0 mmHg) (Figure 34).88, 153, 156, 158, 165, 166, 168 The metformin arms did not have consistent effects on the change in mean systolic blood pressure, which ranged from -2.2 mmHg to 3.3 mmHg. However, the SGLT-2 inhibitor combination arms consistently decreased mean systolic blood pressure by 2.4 mmHg to 8.5 mmHg. No single study markedly influenced the results, and there was no substantial heterogeneity.

Figure 34 Pooled mean between-group difference in systolic blood pressure comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); mmHg = millimeters mercury; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in systolic blood pressure comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

Two 102-week studies compared metformin with a combination of metformin and a SGLT-2 inhibitor and favored neither arm.169, 170 The first study was a 102-week RCT which compared metformin (at least 1500 mg daily) with a metformin plus two different doses of dapagliflozin. This RCT showed a non-significant between-group difference in systolic blood pressure of 2.6 mmHg (95% CI, -1.6 mmHg to 6.8 mmHg) for the combination with 5mg of dapagliflozin and 1.8 mmHg (95% CI, -2.6 mmHg to 6.2 mmHg) for the combination with 10mg of dapagliflozin.170 The metformin arm increased mean systolic blood pressure by 1.5 mmHg, and the dapagliflozin arms decreased mean systolic blood pressure by 0.3 mmHg to 1.1 mmHg. There was a high loss to followup in this study (47% in the metformin arm and 30% to 40% in the combination arms). The second study was a 102-week RCT with over 20 percent loss to followup in both arms. This second RCT compared metformin at the dosage prior to enrollment with metformin plus dapagliflozin (10 mg daily) and showed a non-significant between-group difference in systolic blood pressure of 2.4 mmHg (95% CI, -1.5 mmHg to 6.3 mmHg).169 The metformin arm increased mean systolic blood pressure by 1.1 mmHg, and the metformin plus SGLT-2 inhibitor arm decreased mean systolic blood pressure by 1.3 mmHg.

One 24-week RCT was excluded from the meta-analysis due to differences in medication dosing for the SGLT-2 inhibitor arm. In this study, metformin was compared with metformin plus 5mg of dapagliflozin, showing a between-group difference in systolic blood pressure of 1.1 mmHg (95% CI, -1.4 mmHg to 3.6 mmHg) with both arms decreasing mean systolic blood pressure.88 (SOE: High; Combination of metformin plus a SGLT-2 inhibitor favored for shorter studies; SOE: Low; Neither favored for longer studies)

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three short RCTs, each lasting less than one year, compared metformin with a combination of metformin plus a GLP-1 receptor agonist. The pooled analysis showed a between-group difference in systolic blood pressure of 3.1 mmHg (95% CI, 1.4 mmHg to 4.9 mmHg), favoring the combination arm over the monotherapy arm (Figure 35).159, 171, 172 These studies used different combinations of metformin plus a GLP-1 receptor agonist (liraglutide, dulaglutide, or exenatide). The metformin arms did not show consistent effects, with the mean change in systolic blood pressure ranging from -3.0 mmHg to 1.1 mmHg; the GLP-1 receptor agonist arms consistently decreased mean systolic blood pressure by 1.7 mmHg to 6.8 mmHg. No single study markedly influenced the results, and there was no substantial heterogeneity.

Figure 35 Pooled mean between-group difference in systolic blood pressure comparing metformin with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; GLP-1 = glucagon-like peptide-1; ES = effect size (mean between-group difference in the change from baseline); mmHg = millimeters mercury

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in systolic blood pressure comparing metformin with a combination of metformin plus a GLP-1 receptor agonist.

We excluded the 104-week RCT from the meta-analysis due to its long duration.141 Consistent with the meta-analysis results, this study reported a significant between-group difference in systolic blood pressure of 3.2 mmHg (95% CI, 0.03 mmHg to 6.4 mmHg), favoring the combination arm.141 The metformin arm increased mean systolic blood pressure by 2.2 mmHg, and the metformin plus albiglutide arm decreased mean systolic blood pressure by 1 mmHg. There were high losses to followup of 30 percent to 40 percent among both arms in this study. One 30-week RCT was not included in the meta-analysis because it did not provide quantitative blood pressure measurements. The study descriptively reported that no changes in systolic blood pressure were observed between intervention arms, which is inconsistent with the meta-analysis results.174 (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

One 26-week RCT compared metformin plus pioglitazone with metformin plus weekly exenatide, reporting a non-significant between-group difference in systolic blood pressure of 2.0 mmHg (95% CI, -0.8 mmHg to 4.8 mmHg).188 The metformin plus pioglitazone combination decreased mean systolic blood pressure by 1.6 mmHg, and the metformin plus exenatide combination decreased mean systolic blood pressure by 3.6 mmHg. (SOE: Low; Neither combination favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three 104-week RCTs compared metformin plus a sulfonylurea with metformin plus a SGLT-2 inhibitor (canagliflozin, empagliflozin, or dapagliflozin), favoring SGLT-2 inhibitors in systolic blood pressure reduction.200, 201, 219 The pooled between-group difference in systolic blood pressure was 5.1 mmHg (95% CI, 4.2 mmHg to 6.0 mmHg) (Figure 36), favoring combinations with a SGLT-2 inhibitor for lowering blood pressure. No single study influenced the results, and no substantial heterogeneity was found. A 208-week extension study was consistent with the pooled results favoring greater systolic blood pressure reduction with the SGLT-2 inhibitor arm.54, 219 (SOE: High; Combination of metformin plus a SGLT-2 inhibitor favored)

Figure 36 Pooled mean between-group difference in systolic blood pressure comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); Met = metformin; mmHg = millimeters mercury; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in systolic blood pressure comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Four RCTs comparing metformin plus a sulfonylurea with metformin plus a GLP-1 receptor agonist reported systolic blood pressure, favoring the combination of metformin plus a GLP-1 receptor agonist for lowering blood pressure.53, 141, 202, 204 These studies were not combined in a meta-analysis due to differences in the duration and absence of sufficient data.53 One 16-week RCT compared metformin plus glimepiride with metformin plus exenatide and showed a non-significant between-group difference in systolic blood pressure of 2.0 mmHg (95% CI, -12.5 mmHg to 16.5 mmHg) with both combinations decreasing mean systolic blood pressure.202

One 16-week RCT compared metformin plus glimepiride with metformin plus liraglutide, showing a significantly greater reduction in systolic blood pressure, by more than 3 mmHg, with the liraglutide combination arms compared with 0.91 mmHg in the glimepiride combination arm (P < 0.05).204 There was a differential loss to followup, with 46 percent to 59 percent, in the higher liraglutide dose arms compared with 16 percent in the metformin plus sulfonylurea arm. One 104-week RCT compared metformin plus glimepiride with metformin plus albiglutide, showing a significant between-group difference in systolic blood pressure favoring the GLP-1 receptor agonist combination by 2.5 mmHg (95% CI, 0.3 mmHg to 4.7 mmHg).141 The metformin plus glimepiride increased mean systolic blood pressure by 1.5 mmHg while the metformin plus albiglutide arm decreased mean systolic blood pressure by 1.0 mmHg. (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

We pooled four short-duration RCTs comparing metformin plus a DPP-4 inhibitor versus metformin plus a SGLT-2 inhibitor.153, 156, 158, 209 The pooled results showed a between-group difference in systolic blood pressure of 4.1 mmHg (95% CI, 3.6 mmHg to 4.6 mmHg) (Figure 37), favoring metformin plus SGLT-2 inhibitors. The DPP-4 inhibitor combinations changed mean systolic blood pressure by +0.3 mmHg to -1.8 mmHg, while the SGLT-2 inhibitor combinations consistently decreased mean systolic blood pressure by 3.5 mmHg to 8.5 mmHg. No single study markedly influenced the results, and there was no substantial heterogeneity.

Figure 37 Pooled mean between-group difference in systolic blood pressure comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; ES = effect size (mean between-group difference in the change from baseline); Met = metformin; mmHg = millimeters mercury; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in systolic blood pressure comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a SGLT-2 inhibitor.

We excluded one 104-week RCT from the meta-analysis due to its long duration.90 The trial compared metformin plus sitagliptin with metformin plus empagliflozin. The trial showed a between-group difference in systolic blood pressure of 5.1 mmHg (95% CI, 1.0 mmHg to 9.2 mmHg) with metformin plus 10 mg of empagliflozin and 4.8 mmHg (95% CI, 0.7 mmHg to 8.9 mmHg) with metformin plus 25 mg of empagliflozin, favoring the combination arm with a SGLT-2 inhibitor.90 These results were consistent with the results from the meta-analysis. The metformin plus sitagliptin arm increased mean systolic blood pressure by 1.8 mmHg, and the metformin plus empagliflozin arms decreased mean systolic blood pressure by 3 mmHg to 3.3 mmHg. (SOE: Moderate; Combination of metformin plus a SGLT-2 inhibitor favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Four RCTs comparing metformin plus a DPP-4 inhibitor with metformin plus a GLP-1 receptor agonist showed no clear differences between-groups.141, 159, 188, 210 We did not combine these RCTs in a meta-analysis because of differences in drug type and study duration.

One 26-week RCT compared metformin plus sitagliptin with metformin plus exenatide and showed a between-group difference in systolic blood pressure of 4.0 mmHg (95% CI, 1.5 mmHg to 6.5 mmHg), favoring the combination arm with GLP-1 receptor agonists. The metformin plus DPP-4 inhibitor arm increased mean systolic blood pressure by 0.2 mmHg, and the metformin plus GLP-1 receptor agonist arm decreased mean systolic blood pressure by 3.6 mmHg.188 A 26-week RCT compared metformin plus sitagliptin with metformin plus liraglutide, showing a non-significant between-group difference in systolic blood pressure of 0.4 mmHg (95% CI, -2.0 mmHg to 2.7 mmHg) with metformin plus 1.2 mg of liraglutide and 0.2 mmHg (95% CI, -2.1 mmHg to 2.6 mmHg) with metformin plus 1.8 mg of liraglutide.210 All arms decreased mean systolic blood pressure.

Among the newest studies, one 52-week RCT compared metformin plus sitagliptin with metformin plus dulaglutide and showed a non-significant between-group difference in systolic blood pressure of 0 mmHg (95% CI, -1.9 mmHg to 1.9 mmHg) with 0.75 mg of dulaglutide weekly and 0.3 mmHg (95% CI, -1.6 mmHg to 2.2 mmHg) with 1.5 mg of dulaglutide weekly.159 All arms decreased mean systolic blood pressure. One 104-week RCT compared metformin plus sitagliptin with metformin plus albiglutide and showed a non-significant between-group difference in systolic blood pressure of 1.2 mmHg (95% CI, -1.1 mmHg to 3.5 mmHg).141 The metformin plus DPP-4 inhibitor arm increased mean systolic blood pressure by 0.2 mmHg, and the metformin plus GLP-1 receptor agonist arm decreased mean systolic blood pressure by 1.0 mmHg. (SOE: Low; Neither combination favored)

#### Strength of Evidence for Systolic Blood Pressure

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 13, Table 14, and Table 15 and summarized in the Key Points. All studies were RCTs. Study limitations for all the comparisons were low or medium. In general, we did not find strong differences in outcomes in the lower-quality versus higher-quality studies. We were unable to assess publication bias given the limited number of studies for each comparison for systolic blood pressure. We also did not find any evidence of publication bias or reporting bias in the grey literature review. We considered this outcome direct, since systolic blood pressure is strongly linked with important long-term clinical outcomes.220-222

Table 13 Strength of evidence domains for monotherapy comparisons in terms of systolic blood pressure among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SGLT-2 inhibitors | 4 (1651) | Medium | Consistent | Direct | Precise | Undetected | Moderate | SGLT-2 inhibitors favored; 2.8 mmHg (2.6 to 3.0 mmHg)
Metformin vs. GLP-1 receptor agonists | 2 (820) | Low | Inconsistent | Direct | Precise | Undetected | Low | Neither drug favored
TZD vs. GLP-1 receptor agonists | 2 (1048) | Low | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
SU vs. GLP-1 receptor agonists | 1 (746) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither drug favored
DPP-4 inhibitors vs. SGLT-2 inhibitors | 1 (899) | Low | Unknown | Direct | Imprecise | Undetected | Low | SGLT-2 inhibitors favored
DPP-4 inhibitors vs. GLP-1 receptor agonists | 2 (860) | Low | Consistent | Direct | Precise | Undetected | Low | Neither drug favored

DPP-4 = dipeptidyl-peptidase 4; GLP-1 = glucagon-like peptide-1; SGLT-2 = sodium-glucose co-transporter 2; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

Table 14 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of systolic blood pressure among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + SGLT-2 inhibitors (shorter studies) | 7 (3988) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SGLT-2 inhibitors favored; 4.4 mmHg (2.9 to 6.0 mmHg)
Metformin vs. metformin + SGLT-2 inhibitors (longer studies) | 2 (728) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + GLP-1 receptor agonists | 5 (2688) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin + GLP-1 receptor agonists favored; 3.1 mmHg (1.4 to 4.9 mmHg)

DPP-4 = dipeptidyl-peptidase 4; GLP-1 = glucagon-like peptide-1; SGLT-2 = sodium-glucose co-transporter 2; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

Table 15 Strength of evidence domains for metformin-based combination comparisons in terms of systolic blood pressure among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + GLP-1 receptor agonists | 1 (514) | Low | Unknown | Direct | Precise | Undetected | Low | Neither combination favored
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer duration studies) | 3 (3815) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SGLT-2 inhibitors favored; 5.0 mmHg (4.2 to 6.0 mmHg)
Metformin + SU vs. metformin + GLP-1 receptor agonists | 4 (3049) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin + GLP-1 receptor agonists favored
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 5 (3423) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + SGLT-2 inhibitors favored; 4.1 mmHg (3.6 to 4.6 mmHg)
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | 4 (3322) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither combination favored

DPP-4 = dipeptidyl-peptidase 4; GLP-1 = glucagon-like peptide-1; SGLT-2 = sodium-glucose co-transporter 2; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Heart Rate

#### Monotherapy Comparisons

##### Metformin Versus SGLT-2 Inhibitors

Two RCTs compared metformin with SGLT-2 inhibitors and showed no differences in heart rate between the arms.89, 90 One 12-week RCT compared metformin with dapagliflozin, showing a non-significant between-group difference in heart rate of 2.1 beats per minute (bpm) (95% CI, -1.3 bpm to 5.5 bpm) with 5 mg of dapagliflozin and 1.1 bpm (95% CI, -2.4 bpm to 4.7 bpm) with 10 mg of dapagliflozin. The metformin arm increased mean heart rate by 1.1 bpm, and the SGLT-2 inhibitor arms decreased mean heart rate by 0.03 bpm to 1 bpm.89 The other 90-week RCT compared metformin and empagliflozin and reported that “reductions in blood pressure were not associated with increases in heart rate.”90 (SOE: Low; Neither drug favored)

##### Metformin Versus GLP-1 Receptor Agonists

Two RCTs compared metformin with a GLP-1 receptor agonist and showed no clear differences in heart rate between the arms.73, 91 One RCT, with 20 percent loss to followup, compared metformin with two doses of dulaglutide, over 52 weeks. There was a non-significant between-group difference in heart rate of 0.5 bpm (95% CI, -1.1 bpm to 2.1 bpm) with 0.75 mg of dulaglutide weekly and 0.7 bpm (95% CI, -0.9 bpm to 2.3 bpm) with 1.5 mg of dulaglutide weekly. All arms had an increase in mean heart rate.91 One 26-week RCT compared metformin with exenatide and showed a non-significant between-group difference in heart rate of 1.2 bpm (95% CI, -0.5 bpm to 2.9 bpm). The metformin arm had a mean heart rate increase of 0.3 bpm, and the GLP-1 receptor agonist arm had an increase of 1.5 bpm.73 (SOE: Moderate; Neither drug favored)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

One double-blind, 26-week RCT compared pioglitazone titrated to 45 mg daily with exenatide (2 mg weekly) and showed a between-group difference in heart rate of 3.2 bpm (95% CI, 1.3 bpm to 5.0 bpm).73 In this study, the pioglitazone arm decreased mean heart rate by 1.7 bpm, and the GLP-1 receptor agonist arm increased mean heart rate by 1.5 bpm. (SOE: Low; Thiazolidinediones favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

One 104-week RCT compared glimepiride with liraglutide, 1.2 mg and 1.8 mg, and showed a non-significant between-group difference in heart rate of 1.4 bpm (95% CI, -0.2 bpm to 2.9 bpm) for the lower dose and 0.2 bpm (95% CI, -1.3 bpm to 1.8 bpm) for the higher dose, favoring glimepiride.113 The sulfonylurea arm increased the mean heart rate by 0.6 bpm, and the liraglutide arms increased mean heart rate between 0.9 bpm to 2.0 bpm. There was high loss to followup of 50 percent to 60 percent among all arms in this study. (SOE: Low; Neither drug favored)

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

One 24-week RCT compared 100 mg of sitagliptin to empagliflozin, 10 mg and 25 mg, and showed a non-significant between-group difference in heart rate of 0.2 bpm (95% CI, -1.5 bpm to 1.9 bpm) with 10 mg of empagliflozin and 0.5 bpm (95% CI, -2.2 bpm to 1.2 bpm) with 25 mg of empagliflozin, favoring empagliflozin.114 The DPP-4 inhibitor arm increased mean heart rate by 0.2 bpm; lower dose empagliflozin increased mean heart rate by 0.02 bpm, and the higher dose decreased mean heart rate by 0.25 bpm. (SOE: Low; Neither drug favored)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

One 26-week RCT compared sitagliptin with exenatide and showed a non-significant between-group difference in heart rate of 1.0 bpm (95% CI, -0.9 bpm to 2.9 bpm). Both arms increased mean heart rate.73 (SOE: Low; Neither drug favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs comparing metformin to a combination of metformin plus a SGLT-2 inhibitor had inconsistent results.156, 165, 169 We did not combine the studies in a meta-analysis due to differences in study duration.

One 12-week RCT compared metformin to metformin plus canagliflozin. Compared to metformin, the between-group difference in heart rate was 1.9 bpm lower (95% CI, 1.5 bpm to 2.3 bpm) with metformin plus 100 mg of canagliflozin, 1.1 bpm (95% CI, 0.7 bpm to 1.5 bpm) lower with metformin plus 200 mg of canagliflozin, and 3.4 bpm (95% CI, 3.0 bpm to 3.8 bpm) lower with metformin plus 300 mg of canagliflozin.156 In this study, the mean heart rate increased by 1.7 bpm in the metformin arm and decreased by 1.7 bpm in the metformin plus 300 mg of canagliflozin arm.

One 18-week RCT compared metformin with metformin plus canagliflozin and reported a between-group difference in heart rate of 0.9 bpm with 100 mg of canagliflozin daily and 1.4 bpm with 300mg of canagliflozin daily. Metformin caused no increase in mean heart rate, and metformin plus canagliflozin increased mean heart rate.165

A 102-week RCT, with over 20 percent loss to followup, compared metformin to metformin plus 10 mg of dapagliflozin and showed a non-significant between-group difference in heart rate of 0.1 bpm (95% CI, -2.8 bpm to 3.0 bpm). Both arms increased mean heart rate slightly.169 (SOE: Low; Neither drug favored)

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three RCTs compared metformin to a combination of metformin plus a GLP-1 receptor agonist, with conflicting results.141, 159, 174 The 104-week RCT compared metformin to metformin plus albiglutide and showed a non-significant between-group difference in heart rate of 1.0 bpm (95% CI, -1.2 bpm to 3.2 bpm), favoring metformin.141 A 26-week RCT compared metformin to metformin plus dulaglutide and showed a between-group difference in heart rate of 2.8 bpm (95% CI, 1.1 bpm to 4.5 bpm), favoring metformin. There was high loss to followup of at least 60 percent in all arms in this study.159 One 30-week RCT compared metformin with metformin plus exenatide. The study reported that no changes in heart rate were observed between intervention arms (no quantitative data available).174 (SOE: Insufficient)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

We pooled three RCTs, each more than 1 year in duration, that compared metformin plus a sulfonylurea with metformin plus a SGLT-2 inhibitor (Figure 38).198-200 A 104-week extension study compared metformin and glimepiride with metformin and canagliflozin, showing a between-group difference of 0.9 bpm (insufficient data to calculate 95% CI). The glimepiride arm increased heart rate by 0.7 bpm, and the canagliflozin arm decreased heart rate by 0.2 bpm, which is consistent with the pooled results.198, 201 (SOE: Moderate; Combination of metformin plus a SGLT-2 inhibitor favored)

Figure 38 Pooled mean between-group difference in heart rate comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

bpm = beats per minute; CI = confidence interval; ES = effect size (mean between-group difference in the change from baseline); Met = metformin; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled mean between-group difference in heart rate comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two RCTs compared metformin plus a sulfonylurea with metformin plus a GLP-1 receptor agonist, with conflicting results.53, 141 One RCT, with 75 percent losses to followup, reported that mean heart rate increased by 1.2 bpm (P = 0.024) with metformin plus exenatide but not with metformin plus glimepiride (0.6 bpm; P = 0.28), with no differences between groups at any time.53 One 104-week RCT, with 30 percent loss to followup, compared metformin plus glimepiride with metformin plus albiglutide and showed a between-group difference of 1.8 bpm (95% CI, 0.2 bpm to 3.4 bpm), favoring the metformin with glimepiride treatment.141 The sulfonylurea combination decreased mean heart rate by 0.5 bpm, and the GLP-1 receptor agonist combination increased mean heart rate by 1.3 bpm. (SOE: Insufficient)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Two RCTs compared metformin plus a DPP-4 inhibitor to metformin plus a SGLT-2 inhibitor and showed no clear differences between groups in heart rate.90, 156 One 12-week RCT compared metformin plus sitagliptin with three dose strengths of metformin plus canagliflozin. The RCT showed a non-significant between-group difference in heart rate of 1.5 bpm (95% CI, 1.2 bpm to 1.8 bpm) with 100 mg of canagliflozin, 2.3 bpm (95% CI, 2.0 bpm to 2.6 bpm) with 200 mg of canagliflozin, and 0.0 bpm (95% CI, -0.4 bpm to 0.4 bpm) with 300 mg of canagliflozin.156 The DPP-4 inhibitor with metformin decreased mean heart rate by 1.7 bpm; 100 mg of canagliflozin with metformin decreased mean heart rate by 0.2 bpm, 200 mg increased mean heart rate by 0.6 bpm, and 300 mg decreased mean heart rate by 1.7 bpm. One 90-week RCT compared metformin plus sitagliptin to metformin plus empagliflozin and found no increase in heart rate accompanying blood pressure reduction.90 (SOE: Low; Neither combination favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three RCTs compared metformin plus a DPP-4 inhibitor with metformin plus a GLP-1 receptor agonist.141, 159, 210 These studies were not combined in a meta-analysis due to differences in study duration.

The two short studies significantly favored the combination of metformin plus a DPP-4 inhibitor. One 26-week RCT compared metformin plus sitagliptin with metformin plus liraglutide and showed a between-group difference in heart rate of 3.0 bpm (95% CI, 1.4 bpm to 4.5 bpm) with 1.2 mg of liraglutide and 4.6 bpm (95% CI, 3.0 bpm to 6.1 bpm) with 1.8 mg of liraglutide. The DPP-4 inhibitor combination decreased mean heart rate by 0.64 bpm, and the GLP-1 combinations increased mean heart rate by 2.3 bpm and 3.9 bpm.210 A 52-week RCT, with over 60 percent loss to followup, compared metformin plus sitagliptin to metformin plus dulaglutide, showing a between-group difference in heart rate of 2.4 bpm (95% CI, 1.0 bpm to 3.8 bpm) with 0.75 mg of dulaglutide weekly and 2.7 bpm (95% CI, 1.3 bpm to 4.1 bpm) with 1.5 mg of dulaglutide weekly. The DPP-4 inhibitor combination decreased mean heart rate by 0.3 bpm, and the GLP-1 combinations increased mean heart rate by 2.1 and 2.4 bpm.159

The 104-week RCT, with over 30% loss to followup, compared metformin plus sitagliptin to metformin plus albiglutide and showed a non-significant between-group difference in heart rate of 0.5 bpm (95% CI, -1.2 bpm to 2.2 bpm). Both arms increased mean heart rate slightly.141 (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored)

#### Strength of Evidence for Heart Rate

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 16, Table 17, and Table 18 and summarized in the Key Points. All studies were RCTs. Study limitations for all comparisons were low or medium. Where quality influenced the study results, we describe that under the appropriate comparisons. In general, we did not find strong differences in outcomes in the lower-quality versus higher-quality studies. We were unable to assess publication bias given the limited number of studies for each comparison for heart rate. We also did not find any evidence of publication bias or reporting bias in the grey literature review. We considered this outcome indirect, since there is limited evidence directly linking heart rate to mortality or other clinical outcomes, including among adults with diabetes.

Table 16 Strength of evidence domains for monotherapy comparisons in terms of heart rate among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SGLT-2 inhibitors | 2 (1048) | Medium | Consistent | Indirect | Imprecise | Undetected | Low | Neither drug favored
Metformin vs. GLP-1 receptor agonists | 2 (820) | Low | Consistent | Indirect | Precise | Undetected | Moderate | Neither drug favored
TZD vs. GLP-1 receptor agonists | 1 (820) | Low | Unknown | Indirect | Precise | Undetected | Low | TZD favored
SU vs. GLP-1 receptor agonists | 1 (746) | Medium | Unknown | Indirect | Precise | Undetected | Low | Neither drug favored
DPP-4 inhibitors vs. SGLT-2 inhibitors | 1 (899) | Low | Unknown | Indirect | Precise | Undetected | Low | Neither drug favored
DPP-4 inhibitors vs. GLP-1 receptor agonists | 1 (820) | Low | Unknown | Indirect | Precise | Undetected | Low | Neither drug favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

Table 17 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of heart rate among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + SGLT-2 inhibitors | 3 (912) | Low | Inconsistent | Indirect | Imprecise | Undetected | Low | Neither drug favored
Metformin vs. metformin + GLP-1 receptor agonists | 3 (2473) | Low | Inconsistent | Indirect | Imprecise | Undetected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

Table 18 Strength of evidence domains for metformin-based combination comparisons in terms of heart rate among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + SU vs. metformin +SGLT-2 inhibitors (longer duration studies) | 3 (3815) | Low | Consistent | Indirect | Precise | Undetected | Moderate | Metformin + SGLT-2 inhibitor favored; mean between-group difference, 1.5 bpm (95% CI, 0.6 to 2.3 bpm)
Metformin + SU vs. metformin +GLP-1 receptor agonists | 2 (2078) | Medium | Inconsistent | Indirect | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 2 (1110) | Medium | Consistent | Indirect | Imprecise | Undetected | Low | Neither combination favored
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | 3 (2808) | Medium | Inconsistent | Indirect | Precise | Undetected | Low | Metformin + DPP-4 inhibitor favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled mean between-group differences (95 percent confidence intervals). We only include estimates for comparisons with high or moderate strength of evidence.

## Key Questions 2a and 2b All-Cause Mortality and Macrovascular and Microvascular Outcomes

### Study Design and Population Characteristics

One hundred and eighteen studies (in 141 publications) reported on the comparative effectiveness of oral diabetes medications on long-term outcomes of interest (Appendix D, Tables D5 to D9). Twenty studies occurred in North America, 19 studies occurred in Europe, 13 studies occurred in Asia; all others were multi-continent studies.

Ninety-six studies were RCTs, with durations from 12 weeks to 5.5 years. Thirty-four of the RCTs lasted for at least one year. All studies specified intermediate, not long-term, outcomes as their primary outcome (see Key Question 1) but then also reported the incidence of one or more long-term outcomes (e.g., mortality), usually as an adverse event. Two studies used a cross-over design.223, 224 Eighty-two RCTs reported support from a pharmaceutical company. Eighteen of the 62 (29%) RCTs identified in this update did not report on rescue therapy; rescue therapy was allowed in 25 studies (40%) and was not allowed in 15 studies (24%).

We also included 21 retrospective cohort studies and one case-control study; duration of followup ranged from 6 months to over 5 years (eight lasted less than 2 years, 12 lasted 2 years or longer, and one lasted at least 12 months but did not specify the mean followup). These studies analyzed data from 12 unique cohorts, including five studies from Danish national databases225-229 and one from the Saskatchewan Health Database.230 Seven of the observational studies were designed to explicitly evaluate cardiovascular outcomes.151, 225-229, 231 Six observational studies reported support from a pharmaceutical company.

The mean age of participants ranged from 48 years to 75 years, with the majority of studies reporting a mean age in the upper 50s. About 50 percent of participants were female. Forty-seven studies did not report race or ethnicity. In the studies that reported race, the majority of the participants were Caucasians. Two RCTs reported greater than 25 percent African American participants,118, 232 and two studies reported 70 to 80 percent Hispanic participants.121, 186 Most trials excluded people with coexisting illness, such as renal, cardiovascular, or liver disease.

### Risk of Bias

Ninety-six RCTs were included in this section, all of which were described as randomized. Fifty-eight percent of the trials described their randomization scheme and another 74 percent of the trials were described as being double-blinded. Forty-five percent of all double-blinded RCTs also described the steps taken to ensure blinding. The majority of the trials (87 percent) described the withdrawals and dropouts. Of the 11 RCTs with at least 2 years of followup, ten had over 20 percent losses to followup.

Of the 21 observational studies included in this section, 100 percent reported characteristics of subjects and tests of interest, 95 percent reported actual P values, and 85 percent described the measurement of outcomes of interest. All studies described and adjusted for confounding factors and conducted statistical analyses. All of the observational studies described the number of participants who were lost to followup after the start of the period of observation.

### Key Points and Evidence Grades

#### All-Cause Mortality

- All evidence on all-cause mortality was of low strength or insufficient.

#### Cardiovascular Mortality

- Sulfonylurea monotherapy was associated with increased cardiovascular mortality compared with metformin monotherapy (relative risk range 1.5 to 1.7 from individual RCTs; range in risk differences, 0.1 to 2.9%; range in duration of follow up, 2.8 to 4.0 years). (SOE: Moderate)
- To date, there has been uncertainty about the cardiovascular benefits of diabetes medications as evidenced by the FDA labeling stating a lack of known lower macrovascular risk for any diabetes medications; still, all evidence on the comparative effectiveness of the included diabetes medications on cardiovascular mortality was of low strength or insufficient.

#### Cardiovascular and Cerebrovascular Disease Morbidity

- To date, there has been uncertainty about the cardiovascular benefits of diabetes medications as evidenced by the FDA labeling stating a lack of known lower macrovascular risk for any diabetes medications; still, all evidence on the comparative effectiveness of the included diabetes medications on cardiovascular morbidity was of low strength or insufficient.

#### Retinopathy, Nephropathy, and Neuropathy

- The evidence was low or insufficient for all comparisons, and almost all RCTs were short-term.

### Evidence for All-Cause Mortality

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

###### Randomized Controlled Trials

Four RCTs, each lasting 24 to 52 weeks, compared the effects of metformin with pioglitazone and found similar risks of all-cause mortality in the metformin and pioglitazone arms with seven deaths across the studies (pooled OR for metformin versus pioglitazone, 0.91; 95% CI, 0.22 to 3.72) (Figure 39).62, 63, 73, 76 We found no evidence of statistical heterogeneity. Omission of any single study did not change the conclusions. Deaths were not described in the pioglitazone arm of one study, so we imputed “0” events in this arm for the meta-analysis.76 The pooled between-group difference in mortality for metformin versus placebo was 0.0% (95% CI, -0.6 to 0.6%).

Figure 39 Pooled odds ratio of short-term all-cause mortality comparing metformin with pioglitazone

CI = confidence interval; Group 1 = metformin; Group 2 = thiazolidinediones; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of short-term all-cause mortality comparing metformin with pioglitazone.

Two RCTs compared the effects of metformin with rosiglitazone on all-cause mortality.50, 59 The A Diabetes Outcome Progression Trial (ADOPT) randomized participants with recently-diagnosed, untreated type 2 diabetes from 488 different centers in the United States, Canada, and Europe to rosiglitazone, metformin, or glyburide and had long-term follow up.50 Mortality was slightly lower in the metformin (31/1454; 2.1%) versus rosiglitazone (34/1456; 2.3%) arm with median followup of 4.0 years.50 The actual number of participants for which ADOPT ascertained mortality is unclear, and withdrawals were high across the arms: 37 percent (rosiglitazone) and 38 percent (metformin).50 The second trial was 32 weeks in duration and reported no deaths in the metformin or rosiglitazone arms.59

###### Observational Studies

Two retrospective cohort studies compared the effects of initiating thiazolidinediones and metformin (Table 19).233, 234 One study found no significant difference in all-cause mortality for metformin and thiazolidinediones.233 The second study found a significantly increased risk of all-cause mortality among women but not among men for rosiglitazone versus metformin.234

Table 19 Observational studies comparing metformin with thiazolidinediones on all-cause mortality

Author, Year | Population | Mean Followup | Results
Pantalone, 2009^233^ | Cleveland Clinic electronic health record system N not reported | Not reported | HR for rosiglitazone, 1.33, 95% CI, 0.93 to 1.91
Pantalone, 2009^233^ | Cleveland Clinic electronic health record system N not reported | Not reported | HR for pioglitazone, 1.08, 95% CI, 0.78 to 1.51
Pantalone, 2009^233^ | Cleveland Clinic electronic health record system N not reported | Not reported | Reference = metformin
Wheeler, 2013^234^ | Veterans Health Administration 2004-2009 | 1.7 years (metformin) | HR for 185,360 men, 1.19; 95% CI, 0.95 to 1.49
Wheeler, 2013^234^ | n=132,306 (metformin) n=3753 (rosiglitazone) | 1.4 years (rosiglitazone) | HR for 7,812 women, 4.36; 95% CI, 1.34 to 14.20
Wheeler, 2013^234^ | n=132,306 (metformin) n=3753 (rosiglitazone) | 1.4 years (rosiglitazone) | Reference = metformin
Wheeler, 2013^234^ | n=132,306 (metformin) n=3753 (rosiglitazone) | 1.4 years (rosiglitazone) | P interaction for gender = 0.034

CI = confidence interval; HR = hazard ratio

[SOE: Low for pioglitazone (short-term mortality); Neither metformin nor pioglitazone favored] (SOE: Low for rosiglitazone; Metformin favored compared with rosiglitazone)

##### Metformin Versus Sulfonylureas

###### Randomized Controlled Trials

Six RCTs compared the effects of metformin and a sulfonylurea on all-cause mortality (Table 20).50, 129, 130, 137, 138, 231

Table 20 Randomized controlled trials comparing metformin with sulfonylureas on all-cause mortality

Author, Year | Mean Followup | Number of Deaths (%): Metformin Versus Sulfonylurea | Estimate of the Measure of Association (95% CI) (Metformin as Reference Group)
Hong, 2013^231^ | 2.8 years | 7/156 (4.5) versus 14/148 (9.5) | RR, 2.1^*^ (0.9 to 5.1) OR, 2.2^*^ (0.8 to 6.7) RD, 5%^*^ (-0.8% to 10.7%)
Kahn, 2006^50^ | 4.1 years (median) | 31/1454 (2.1) versus 31/1441 (2.2) | RR, 1.0^*^ (0.6 to 1.7) OR, 1.0^*^ (0.6 to 1.7) RD, 0.02%^*^ (-1.0% to 1.1%)
Chien, 2007^138^ | 16 weeks | 0/17 (0.0) versus 0/17 (0.0) | NR
Garber, 2003^129^ | 16 weeks | 0/164 (0.0) versus 0/151 (0.0) | NR
Goldstein, 2003^130^ | 18 weeks | 0/76 (0.0) versus 0/84 (0.0) | NR
DeFronzo, 1995^137^ | 29 weeks | 1/210 (0.5) versus 0/209 (0.0) | NR

CI = confidence interval; NR= not reported; OR = odds ratio; RD = absolute risk difference; RR = relative risk

* Calculated for this report from values published in the study.

Two of these RCTs had long-term followup and were of medium quality: The smaller of these two RCTs was conducted in China and had 2.8 years of followup. All participants were required to have documented coronary heart disease. The authors reported more than double the risk of death for the glipizide (mean dose 28.3 mg) arm versus metformin (mean dose 1,400 mg) arm.231 Losses to followup were 21 percent in both arms of this study.231 In the other long-term RCT, ADOPT (described above), the absolute difference in mortality was 0.1 percent higher for the sulfonylurea (maximum dose 15 mg; mean dose not reported) arm versus the metformin (maximum dose 2,000 mg; mean dose not reported) arm. As noted, there were high withdrawal rates in this study: 38 percent (metformin) and 44 percent (glyburide). Median followup was less for the sulfonylurea (3.3 years) versus metformin (4.0 years) arm.50

The other four RCTs, judged to be at low risk of bias, lasted less than 30 weeks.129, 130, 137, 138 Three of these studies reported no deaths in either arm;129, 130, 138 the fourth study reported one death in the metformin arm and none in the sulfonylurea arm.137

###### Observational Studies

We identified eight relevant retrospective cohort studies based on four cohorts (Veterans Health Administration, n=3;^234-236^ Cleveland Clinic electronic health record, n=2;^233, 237^ Danish National Patient Health Registry, n=2;^225, 229^ and the Health Service Database of Lombardy, n=1^238^). All studies reported an increased risk of death for a sulfonylurea versus metformin (Table 21).

Table 21 Observational studies comparing metformin with sulfonylureas on all-cause mortality

Author, Year | Population | Followup | Number of Deaths (%): Metformin Versus Sulfonylurea | Adjusted Results
Kahler, 2007^235^ | Veterans' Health Administration Diabetes Epidemiology Cohort | 3 years | 82 / 2988 (2.7%) versus 1005 / 19,053 (5.3%) | OR, 0.87; 95% CI, 0.68 to 1.10 Reference = sulfonylurea
Wheeler, 2013^234^ | Veterans' Health Administration | 222,258 p-years (metformin) 47,604 p-years (glipizide) 48,238 p-years (glibenclamide) | 2107 / 132,306 versus 1121 / 28,957 (glipizide) and 912 / 28,156 (glibenclamide) | HR for glipizide, 1.55; 95% CI, 1.43 to 1.67 HR for glibenclamide, 1.38; 95% CI, 1.27 to 1.5 Reference = metformin
Wang, 2014^236^ | Veterans' Health Administration – Respondents to Veterans Large Health Survey 1999 | 5.3 years | NR | HR 0.69; 95% CI, 0.6 to 0.79 Reference = sulfonylurea
Pantalone, 2009^233^ | Cleveland Clinic EHR | 8 years | NR | HR, 0.54; 95% CI, 0.46 to 0.64 Reference = sulfonylurea
Pantalone, 2012^237,*^ | Cleveland Clinic EHR | 2.2 years (median) | NR / 12,774 (metformin) NR / 4,325 (glipizide) NR / 4,279 (glyburide) NR / 2,537 (glibenclamide) | HR for glipizide, 1.64; 95% CI, 1.39 to 1.94 HR for glyburide, 1.59; 95% CI, 1.35 to 1.88 HR for glibenclamide, 1.68; 95% CI, 1.37 to 2.06 Reference = metformin
Schramm, 2011^229^ | National Patient Registry (Denmark) Previous MI | 3.3 years (median) | 213 / 2906 versus 141 / 660 (glipizide) 737 / 3894 (glimepiride) 265 / 1168 (glibenclamide) | HR for glipizide, 1.53; 95% CI, 1.23 to 1.89 HR for glimepiride, 1.3; 95% CI, 1.11 to 1.51 HR for glibenclamide, 1.47; 95% CI, 1.22 to 1.76 Reference = metformin
Schramm, 2011^229^ | National Patient Registry (Denmark) No previous MI | 91.5 weeks | 1548 / 43,340 versus 947 / 6965 (glipizide) 4081 / 36,313 (glimepiride) 1546 / 12,495 (glibenclamide) | HR for glipizide, 1.27; 95% CI,1.17 to 1.38 HR for glimepiride, 1.32; 95% CI, 1.24 to 1.4 HR for glibenclamide, 1.19; 95% CI, 1.11 to 1.28 Reference = metformin
Andersson, 2010^225^ | National Patient Registry (Denmark) – patients with admission for heart failure (1997-2006) | 844 days | 239 / 688 (35%) versus 2344 / 3615 (65%) | HR, 0.85; 95% CI, 0.75 to 0.98; P = 0.02) Reference = sulfonylurea
Corrao, 2011^238^ | Health Services Database of Lombardy | Mean followup 4.8 to 5.1 years | NR / 21,810 versus NR / 48,627 | HR, 1.37; 95% CI, 1.26 to 1.49 Reference = metformin

CI = confidence interval; EHR = electronic health record; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OR = odds ratio

* This study population may overlap with Pantalone, 2009.^233^

(SOE: Low; Metformin favored for long-term mortality; Neither favored for short-term mortality)

##### Metformin Versus DPP-4 Inhibitors

Five RCTs compared the effects of metformin with sitagliptin on all-cause mortality. Meta-analysis of the four RCTs with the most similar durations (24 to 76 weeks) showed no difference in all-cause mortality for DPP-4 inhibitors compared with metformin, based on 10 deaths across the studies (pooled OR, 0.53; 95% CI, 0.16 to 1.82) (Figure 40).73, 82, 86, 87 We did not find evidence of statistical heterogeneity. One of these RCTs did not report on deaths in the DPP-4 inhibitor arm, and we imputed “0” for this arm.73 The pooled risk difference for DPP-4 inhibitors versus metformin was -0.1% (95% CI, -0.6 to 0.4%). The fifth RCT compared three metformin arms with sitagliptin 100 mg over 104 weeks. Two deaths were reported in the patients that started on placebo and were switched to metformin at 24 weeks; one death was reported in the metformin arm using 1000 mg as its maximum dose; and no deaths were reported in the metformin arm using 2000 mg as its maximum dose; no deaths occurred in the sitagliptin arm.85

Figure 40 Pooled odds ratio of short-term all-cause mortality comparing metformin with DPP-4 inhibitors

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = dipeptidyl peptidase-4 inhibitors; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of short-term all-cause mortality comparing metformin with DPP-4 inhibitors.

A single retrospective cohort study from the Danish National Patient Registry reported on mortality for metformin (3,024/83,528) and sitagliptin (49/1,228) with mean followup of 0.9 to 1.8 years. The adjusted risk ratio (RR) for metformin versus sitagliptin was 1.25 (95% CI, 0.92 to 1.71; P = 0.15).228 (SOE for short-term mortality: Low; Neither treatment favored)

##### Metformin Versus SGLT-2 Inhibitors

Four short-term RCTs (12 to 24 weeks in duration, reported in 3 articles) compared the effects of metformin to SGLT-2 inhibitors on all-cause mortality and found no difference for SGLT-2 inhibitors versus metformin (pooled OR, 0.97; 95% CI, 0.10 to 9.36) (Figure 41).88, 89, 239 Only two deaths were reported in the studies (one in a metformin arm88 and one in a SGLT-2 arm88). We did not observe significant statistical heterogeneity. Removal of any one study did not change the inference. The pooled risk difference for SGLT-2 inhibitors versus metformin was -0.0% (95% CI, -0.9 to 0.8%) (SOE: Low; Neither favored)

Figure 41 Pooled odds ratio for short-term all-cause mortality comparing metformin with SGLT-2 inhibitors

CI = confidence interval; Group 1 = metformin; Group 2 = sodium-glucose co-transporter-2 inhibitors; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio for short-term all-caus mortality comparing metformin with SGLT-2 inhibitors.

##### Metformin Versus GLP-1 Receptor Agonists

Two RCTs compared all-cause mortality between metformin and GLP-1 receptor agonists.73, 91 In one, lasting 52 weeks, there were no deaths in the metformin or dulaglutide arms.91 In the other, lasting 36 weeks, one death was reported in the metformin arm (1/246, 0.4%), and deaths were not described in the exenatide once weekly arm.73 (SOE for short-term mortality: Low; Neither favored)

##### Thiazolidinediones Versus Sulfonylureas

###### Randomized Controlled Trials

Three RCTs compared thiazolidinediones with sulfonylureas and reported on mortality. The ADOPT trial reported slightly more deaths in the rosiglitazone arm than in the glyburide arm (2.3% versus 2.2%, respectively; risk difference of 0.1% for rosiglitazone compared with metformin) with differential followup time (median 3.3 years for sulfonylurea and 4.0 years for rosiglitazone) and withdrawals (44% for sulfonylurea and 37% for rosiglitazone).50 Two short-term trials reported few deaths in either the thiazolidinedione or sulfonylurea arms: One RCT (N=598) reported no deaths in either the rosiglitazone (4 mg and 8 mg) or sulfonylurea arms at 52 weeks.94 A 56-week trial reported two deaths in the glyburide arm (2/251; 0.8%) and no deaths in the pioglitazone arm (0/251, 0%).95

###### Observational Studies

Two retrospective cohort studies compared the effects of thiazolidinediones with sulfonylureas on all-cause mortality.233, 234 In the cohort from the Cleveland Clinic (N=20,450), individuals initiating pioglitazone had a statistically significant lower risk of death compared with those initiating a sulfonylurea (adjusted HR, 0.59; 95% CI, 0.43 to 0.81). Those initiating rosiglitazone did not have a statistically significant lower risk of death compared with those initiating a sulfonylurea (adjusted HR, 0.73; 95% CI, 0.51 to 1.02). Followup time was not specified.233 In the Veterans Health Administration cohort, glipizide and glibenclamide were each compared separately with rosiglitazone.234 Compared with rosiglitazone, the adjusted RR of death for glipizide users was 1.26 (95% CI, 1.00 to 1.58), and the adjusted RR for glibenclamide users was 1.09 (95% CI, 0.87 to 1.38).234

(SOE: Insufficient for comparison of sulfonylurea and pioglitazone) (SOE: Insufficient for comparison of sulfonylurea and rosiglitazone)

##### Thiazolidinediones Versus DPP-4 Inhibitors

Two RCTs compared pioglitazone with sitagliptin and reported on mortality.48, 73 The 12-week RCT (N=106) reported no deaths in either arm.48 The 36-week RCT (N=326) did not report on deaths in the pioglitazone or sitagliptin arms, although it did report on deaths in other study arms.73 Of note, Russell-Jones 2012, et al. did not use an intention-to-treat approach and had greater than 13 to 18 percent losses to followup across arms.73 (SOE: Low; Neither favored for short-term mortality)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

A single RCT, with 36 weeks of followup, did not report on deaths in the pioglitazone (n=163) or exenatide once weekly (n=248) arms although it did report on deaths in other study arms.73 (Not graded)

##### Sulfonylureas Versus DPP-4 Inhibitors

A single RCT reported seven and three deaths over 58 weeks in the glipizide (7/212, 3.3%) and sitagliptin (3/210, 1.4%) arms, respectively.107 The authors did not use an intention-to-treat approach for mortality, and losses to followup were greater than 19 percent for both arms.107 (SOE: Low; DPP-4 inhibitors favored for short-term mortality)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Two RCTs compared sulfonylureas with liraglutide and reported on all-cause mortality.110, 113 Liraglutide doses varied across the trials, and death rates were low in both trials (Table 22).110, 113 In the longer study (104 weeks), mortality was higher in the sulfonylurea arm compared with the low-dose liraglutide arm (0.4% vs. 0.0%) but similar to that in the high-dose liraglutide arm (0.4%).113 (SOE: Insufficient)

Table 22 Randomized controlled trials comparing sulfonylureas with GLP-1 receptor agonists on all-cause mortality

Author, Year | Followup (Weeks) | Sulfonylurea (Dose^*^) | Liraglutide (Dose^*^) | Number of Deaths / N (%) in the Sulfonylurea Arm | Number of Deaths / N (%) in the Liraglutide Arm
Kaku, 2011^110^ | 52 | Glibenclamide (fixed at 1.25 to 2.5 mg) | Liraglutide (max 0.9 mg) | NR/132 | 1/268 (0.4)
Garber, 2011^113^ | 104 | Glimepiride (max 8 mg) | Liraglutide (max 1.2 mg) | 1/248 (0.4) | 0/251 (0)
Garber, 2011^113^ | 104 | Glimepiride (max 8 mg) | Liraglutide (max 1.8 mg) | 1/248 (0.4) | 1/247 (0.4)

GLP-1 = glucagon-like peptide-1; max = maximum; mg = milligrams

* All doses were titrated, unless otherwise stated.

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

Two RCTs compared sitagliptin with a SGLT-2 inhibitor (followup 24 to 26 weeks).114, 240 No deaths occurred in one study (N=670),114 and one death was reported in the sitagliptin arm (1/155, <1%) of the other study (no deaths in the SGLT-2 inhibitor arms; N=495).240 Neither study used an intention-to-treat approach for mortality, and losses to followup ranged from 3 to 13 percent across the arms of the trials.114, 240 (SOE: Insufficient)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

A single RCT compared sitagliptin (n=163) with exenatide (n=248) and did not report on deaths in either arm, although it did report on deaths in other study arms.73 (SOE: Insufficient)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

Six articles reported the results from seven RCTs (durations ranging from 24 to 80 weeks) on the effects of metformin versus metformin plus rosiglitazone on all-cause mortality.59, 119, 120, 123, 127, 241 The combined OR comparing metformin plus rosiglitazone with metformin was 2.51 (95% CI, 0.66 to 9.52; I^2^ = 0.0%) (Figure 42), showing a non-significant increased risk of death with metformin plus rosiglitazone (six deaths) compared with metformin monotherapy (one death). Removal of any one study did not impact substantially the effect size or confidence interval of the combined estimate. The pooled risk difference for the combination of metformin plus rosiglitazone versus metformin monotherapy was 0.3% (95% CI, -0.1 to 0.8%). (SOE for short-term mortality: Low; Metformin monotherapy favored over combination of metformin plus rosiglitazone)

Figure 42 Pooled odds ratio of short-term all-cause mortality comparing metformin with a combination of metformin plus rosiglitazone

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus rosiglitazone; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of short-term all-cause mortality comparing metformin with a combination of metformin plus rosiglitazone.

A single 24-week RCT compared the effects of metformin (n=103) to metformin plus pioglitazone (n=110) reported on all-cause mortality; no deaths occurred in either arm.125 (SOE: Insufficient for combination of metformin plus pioglitazone)

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

Five RCTs, each ranging from 16 to 104 weeks, compared the effects of metformin with the combination of metformin plus a sulfonylurea on all-cause mortality.129, 130, 137, 138, 141 In the one long-term study, all-cause mortality was similar in the metformin (1/101, 1%) and metformin plus sulfonylurea (3/307, 1%) arms at 104 weeks; losses to followup were >30% in these arms.141

For the four short-term studies (16 to 29 weeks of followup), there were only three deaths and no significant difference for metformin plus a sulfonylurea versus metformin (pooled OR, 1.32; 95% CI, 0.09 to 18.56; I^2^ = 30.1%) (Figure 43). Although removal of one study did change the direction of the combined estimate (pooled OR, 0.33),129 removal of a single study did not substantially change the width of the confidence interval. The pooled risk difference for the combination of metformin plus a sulfonylurea compared with metformin monotherapy was 0.0% (95% CI, -1.0 to 1.0%). (SOE: Low; Neither treatment favored)

Figure 43 Pooled odds ratio of short-term all-cause mortality comparing metformin with a combination of metformin plus a sulfonylurea

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a sulfonylurea; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of short-term all-cause mortality comparing metformin with a combination of metformin plus a sulfonylurea.

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Seventeen RCTs (published in 18 articles) comparing metformin plus a DPP-4 inhibitor to metformin monotherapy reported on all-cause mortality.84-87, 141, 142, 145, 146, 148, 149, 151-154, 158, 159, 161, 164

Three RCTs longer than one year (78 to 104 weeks) were not meta-analyzed because of differences in dosing of metformin in the maximally-dosed DPP-4 inhibitor arms.85, 87, 141 Mortality rates were low and did not differ by more than ∼0.5 absolute percentage points between metformin and metformin plus DPP-4 inhibitor arms; the dose of medication did not appear to significantly affect results (Table 23).85, 87, 141 Losses to followup ranged from 20 to 48 percent across the arms of these studies.

Table 23 Randomized controlled trials or arms of randomized controlled trials excluded from the meta-analysis comparing metformin with a combination of metformin plus a DPP-4 inhibitor on all-cause mortality

Author, Year | Followup (Weeks) | Metformin Dose in Monotherapy Arm | Metformin Dose in Combination Arm | DPP-4 Inhibitor Dose in Combination Arm | Number of Deaths / N (%) in Metformin Arm | Number of Deaths / N (%) in Metformin + DPP-4 Inhibitor Arm
Kadowaki, 2013^149^ | 12 | 96% of participants on ≤750mg | 94% of participants on ≤750mg | Sitagliptin 50 mg | 0/72 (0) | 0/77 (0)
Pratley, 2014^84^ | 26 | 1000 mg | 1000 mg | Alogliptin 25 mg | 0/109 (0) | 0/106 (0)
Pratley, 2014^84^ | 26 | 1000 mg | 2000 mg | Alogliptin 25 mg | 0/109 (0) | 0/114 (0)
Pratley, 2014^84^ | 26 | 2000 mg | 1000 mg | Alogliptin 25 mg | 0/111 (0) | 0/106 (0)
Pratley, 2014^84^ | 26 | 2000 mg^*^ | 2000 mg | Alogliptin 25 mg | 0/111 (0) | 0/114 (0)
Haak, 2013^164^ | 52 | 2000 mg | 1000 mg | Linagliptin 5 mg | 1/170 (0.6) | 2/225 (0.9)
Haak, 2013^164^ | 52 | 2000 mg^*^ | 2000 mg | Linagliptin 5 mg | 1/170 (0.6) | 1/171 (0.6)
Haak, 2012^86^ | 24 | 1000 mg | 1000 mg | Linagliptin 5 mg | 0/144 (0) | 0/143 (0)
Haak, 2012^86^ | 24 | 1000 mg | 2000 mg | Linagliptin 5 mg | 0/144 (0) | 0/143 (0)
Haak, 2012^86^ | 24 | 2000 mg | 1000 mg | Linagliptin 5 mg | 1/147 (0.7) | 0/143 (0)
Haak, 2012^86^ | 24 | 2000 mg | 2000 mg | Linagliptin 5 mg | 1/147 (0.7) | 0/143 (0)
Nauck, 2009^154^ | 26 | Mean 1868 mg | Mean 1837 mg | Alogliptin 12.5 mg | 0/104 (0) | 1/213 (0.5)
Nauck, 2009^154^ | 26 | Mean 1868 mg^*^ | Mean 1846 mg | Alogliptin 25 mg | 0/104 (0) | 0/210 (0)
Pfutzner, 2011^87^ | 76 | 2000 mg | 2000 mg | Saxagliptin 5 mg | 5/328 (1.5) | 1/320 (0.3)
Pfutzner, 2011^87^ | 76 | 2000 mg | 2000 mg | Saxagliptin 10 mg | 5/328 (1.5) | 2/323 (0.6)
Williams-Herman, 2010^85^ | 104 | 2000 mg | 1000 mg | Sitagliptin 100 mg | 2/176 (1.1) | 1/190 (0.6)
Williams-Herman, 2010^85^ | 104 | 1000 mg | 1000 mg | Sitagliptin 100 mg | 1/182 (0.5) | 1/190 (0.6)
Williams-Herman, 2010^85^ | 104 | 1000 mg | 2000 mg | Sitagliptin 100 mg | 1/182 (0.5) | 1/182 (0.5)
Williams-Herman, 2010^85^ | 104 | 2000 mg | 1000 mg | Sitagliptin 100 mg | 0/182 (0) | 1/190 (0.6)
Williams-Herman, 2010^85^ | 104 | 2000 mg | 2000 mg | Sitagliptin 100 mg | 0/182 (0) | 1/182 (0.5)
Ahren, 2014^141^ | 104 | ≥1500 mg | ≥1500 mg | Sitagliptin 100 mg | 1/101 (1) | 1/302 (0.3)

DPP-4 = dipeptidyl peptidase-4; mg = milligrams

* arm included in the meta-analysis

For studies 52 weeks or less, the pooled OR indicated no difference in mortality rates for metformin plus DPP-4 inhibitor versus metformin (pooled OR, 0.89; 95% CI, 0.28 to 2.86) (Figure 44).84, 86, 142, 145, 146, 148, 151-154, 158, 159, 161, 164 We did not find statistical heterogeneity (I^2^ = 0.0%). Removal of any one study did not change the direction of effect or inference, and there was no evidence of publication bias statistically (P = 0.80) using Harbord's modified test. Three studies did not report on event rates in the metformin arm, and we imputed “0” events for these studies.146, 158, 159 The pooled risk difference for the combination of metformin plus a DPP-4 inhibitor compared with metformin monotherapy for short-term mortality was -0.0% (95% CI, -0.3 to 0.3%).

Figure 44 Pooled odds ratio for short-term all-cause mortality comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio for short-term all-cause mortality comparing metformin with a combination of meformin plus a DPP-4 inhibitor.

Four RCTs included additional arms, with lower doses than the arms included in the meta-analysis. Results from these arms did not differ from those of the meta-analysis (Table 23).84, 86, 154, 164 We excluded one of the short-term RCTs from the meta-analysis because it underdosed the study drugs substantially; that 12-week study reported no deaths in either arm (Table 23).149 (SOE: Low; Neither favored for short-term mortality)

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Nine RCTs (in eight articles) compared metformin monotherapy with metformin plus an SGLT-2 inhibitor and reported on mortality (five deaths).88, 153, 158, 165, 166, 168-170

Two of the RCTs were long-term (102 weeks) and reported low rates of mortality across arms (one death in metformin arm in one study and one death in metformin plus SGLT-2 inhibitor arm in the other).169, 170 Losses to follow up were >20% across the arms of these studies.169, 170

Six of these studies were short (duration range, 12 to 24 weeks), including two trials described by Henry, et al;88 there was no difference in mortality between arms. The combined OR for all-cause mortality for metformin plus SGLT-2 inhibitor versus metformin was 1.14 (95% CI, 0.18 to 7.27) (Figure 45).88, 153, 158, 165, 166, 168 We did not find statistical heterogeneity (I^2^ = 0.0%). Removal of any one study did not change the overall inference. Two of these RCTs did not report on events in the metformin arm, and we imputed “0” events in these arms.165, 166 The pooled risk difference for the combination of metformin plus a SGLT-2 inhibitor compared with metformin monotherapy for short-term mortality was 0.0% (95% CI, -0.5 to 0.5%).

Figure 45 Pooled odds ratio for short-term all-cause mortality comparing metformin with a combination of metformin plus an SGLT-2 inhibitor, stratified by study duration

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio for short-term all-cause mortality comparing metformin with a combination of metformin plus a SGLT-2 inhibitor, stratified by study duration.

Six of the nine RCTs comparing metformin with metformin plus a SGLT-2 inhibitor had multiple different dosing arms; event rates were low and did not appear to vary by dose.153, 158, 165, 166, 168, 170 (SOE: Low: Neither favored for short-term mortality; SOE: Low: Neither favored for long-term mortality)

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two RCTs compared metformin with the combination of metformin plus a GLP-1 receptor agonist. In the 52-week study, no deaths were reported in the metformin monotherapy arm (0/177, 0%); one death was reported in the metformin plus dulaglutide 1.5 mg weekly arm (1/304, 0.3%); and no deaths were observed in the dulaglutide 0.75 mg weekly arm (0/302, 0%) over 52 weeks.159 In a longer RCT, with 104 weeks of followup, one death in the metformin arm (1/101, 1%), and three deaths (3/302, 1%) in the metformin plus albiglutide arm were reported.141 (SOE: Low; Neither treatment favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Two multinational RCTs175, 177 directly compared the effect of the combination of metformin plus rosiglitazone with the combination of metformin plus a sulfonylurea. One study (N=596) reported two deaths in each arm (2/294, 0.7% in the rosiglitazone arm and 2/301, 0.7% in the sulfonylurea arm) over 52 weeks of treatment,175 and the other reported a fatal myocardial infarction in the metformin plus rosiglitazone arm (1/204, 0.5%) and no deaths in the metformin plus sulfonylurea arm (N=514) at 32 weeks.177

A single retrospective observational study of 80,936 patients with both Veterans Health Administration and Medicare coverage between 2000 and 2009 (minimum follow up, 12 month; mean followup, not reported) reported an increased mortality risk for patients taking the combination of metformin plus a sulfonylurea for at least 1 year compared with those on the combination of metformin plus a thiazolidinedione: adjusted HR, 1.5; 95% CI, 1.09 to 2.09; p=0.014.^242^ (SOE: Low; Neither metformin plus rosiglitazone nor metformin plus a sulfonylurea favored for short-term mortality)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

A single RCT compared the combination of metformin plus pioglitazone with the combination of metformin plus sitagliptin and reported one death in the metformin plus sitagliptin arm (1/172, 0.6%) and did not report on deaths in the metformin plus pioglitazone arm (n=172) at 26 weeks.188 (SOE: Insufficient)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single RCT compared the combination of metformin plus pioglitazone (n=172) with the combination of metformin plus weekly exenatide (n=170) at 26 weeks but only provided data on deaths in a third arm (metformin plus sitagliptin).188 Given the reporting in the metformin plus sitagliptin arm, we may infer that there were no deaths in the metformin plus pioglitazone and metformin plus exenatide arms, but this information was not reported.188 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Five RCTs compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor and reported on mortality at 104 weeks.194-197 The pooled OR for metformin plus a DPP-4 inhibitor versus metformin plus a sulfonylurea at 2 years was 0.64 (95% CI, 0.27 to 1.51) (Figure 46).141, 194-197 We did not find evidence of substantial statistical heterogeneity (I^2^ = 21%). The pooled risk difference for the combination of metformin plus a DPP-4 inhibitor compared with the combination of metformin plus a sulfonylurea was -0.3% (95% CI, -0.8 to 0.2%).

Figure 46 Pooled odds ratio for long-term all-cause mortality comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; Met = metformin; OR = odds ratio; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio for long-term all-cause mortality comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor.

Two additional RCTs evaluated this comparison but were not included in the meta-analysis because of their shorter durations.190, 193 One trial with 52 weeks of followup conducted among persons (predominantly men) greater than 65 years of age reported one death in each arm (1/360 (0.3%) in the metformin plus sulfonylurea arm; 1/360 (0.3%) in the metformin plus saxagliptin arm).193 The other trial had 30 weeks of followup and reported one death in the metformin plus sulfonylurea arm (1/519, 0.2%) and no deaths in the metformin plus sitagliptin arm (0/516, 0%).190

A single retrospective cohort study in the Danish National Registry reported a significantly decreased risk of death among metformin plus DPP-4 inhibitor users (n=11,138) versus metformin plus sulfonylurea users (n=25,092) with median follow up of 2.1 years (adjusted rate ratio, 0.65; 95% CI, 0.54 to 0.8).227 (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored for long-term mortality; SOE: Insufficient for short-term mortality)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three long-term RCTs (reported in four publications), each with a duration of 104 to 208 weeks, reported on all-cause mortality for this comparison.54, 199-201 Mortality rates were low across the studies.

An extension of Nauck 2011, with extremely high losses to followup, reported a higher rate of mortality in the metformin plus sulfonylurea (5/408, 1.2%) versus metformin plus SGLT-2 inhibitor (2/406, 0.5%) arm at 208 weeks.54

Meta-analysis of the data from these trials at 104 weeks suggested that long-term all-cause mortality [which was low (<1%) across studies] was similar for metformin plus SGLT-2 inhibitors and metformin plus sulfonylurea (pooled OR, 0.86; 95% CI, 0.29 to 2.55) (Figure 47).199-201 We did not find statistical heterogeneity (I^2^ = 14%), and removal of any one study did not change the inference of no difference between arms. The pooled risk difference for the combination of metformin plus an SGLT-2 inhibitor compared with metformin plus a sulfonylurea was -0.2% (95% CI, -0.8 to 0.5%). One of the RCTs evaluated metformin plus canagliflozin at 100 mg daily (versus 300 mg daily, which was included in the meta-analysis); mortality was the same as in the 300 mg arm (3/483, 0.6%).201 Of note, two200, 201 of three studies did not use an intention-to-treat approach and had large losses to followup across arms. (SOE: Low; Neither favored for long-term mortality)

Figure 47 Pooled odds ratio for long-term all-cause mortality comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = metformin plus a sodium-glucose co-transporter-2 inhibitor; Met = metformin; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio for long-term all-cause mortality comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLt-2 inhibitor.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two RCTs with more than two years of followup reported similar mortality rates for the combination of metformin plus a sulfonylurea compared to metformin plus a GLP-1 receptor agonist (Table 24).53, 141

Table 24 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a GLP-1 receptor agonist on all-cause mortality

Author, Year | Followup | Number of Deaths/N (%) in the Metformin + Sulfonylurea Arm | Number of Deaths/N (%) in the Metformin + GLP-1 Receptor Agonist Arm
Ahren, 2014^141^ | 104 weeks | Glimepiride 3.1 mg: 3/307 (1.0) | Albiglutide 40.5 mg: 3/302 (1.0)
Gallwitz, 2012^53^ | 48 months (assumed) | Glimepiride 2.0mg: 5/508 (1.0) | Exenatide 17.4 mg: 5/510 (1.0)

GLP-1 = glucagon-like peptide-1; mg = milligrams; mean daily dose shown for glimepiride and exenatide; mean weekly dose shown for albiglutide

A single retrospective cohort study in the Danish National Registry did not find a significantly decreased risk of death among metformin plus GLP-1 receptor agonist users (n=4,345) versus metformin plus sulfonylurea users (n=25,092) over a median follow up of 2.1 years (adjusted rate ratio, 0.77; 95% CI, 0.51 to 1.17).227 (SOE: Low; Neither favored for long-term mortality)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Basal Insulin

A single retrospective cohort study in the Danish National Registry found a significantly increased risk of death among metformin plus basal insulin users (n=6,858) versus metformin plus sulfonylurea users (n=25,092) over median follow up of 2.1 years (adjusted rate ratio, 1.95; 95% CI, 1.7 to 2.25).227 (Not graded)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Premixed Insulin

Two multinational RCTs (N=938) compared the effect of the combination of metformin plus a sulfonylurea with the combination of metformin plus a premixed insulin (insulin aspart 70/30 in one study and insulin lispro 75/25 in the other). Each trial reported one death in the metformin plus premixed insulin arms (1/108 (1%) in one study208 and 1/296 (0.3%) in the second study207) and no deaths in the metformin plus sulfonylurea arms at 16 weeks.207, 208 (SOE: Low; Combination of metformin plus a sulfonylurea favored for short-term mortality)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Two RCTs compared metformin plus sitagliptin with metformin plus a SGLT-2 inhibitor and reported on mortality.153, 158 A small (N=212) 12-week trial reported no deaths in any arm (metformin plus sitagliptin, metformin plus empagliflozin 10 mg, and metformin plus empagliflozin 25 mg).153 A second trial with 52 weeks of followup reported one death in the metformin plus sitagliptin arm (1/366, 0.3%), one death in the metformin plus canagliflozin 300 mg arm (1/367, 0.3%), and no deaths in the metformin plus canagliflozin 100 mg arm (0/368, 0%).158 (SOE: Low; Neither favored for short-term mortality)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three RCTs compared the combination of metformin plus sitagliptin with metformin plus a GLP-1 receptor agonist (Table 25). In the study with the longest followup (104 weeks), mortality was higher in the metformin plus GLP-1 receptor agonist arm;141 however, the shorter study (52 weeks) reporting on mortality in both arms reported a higher death rate in the metformin plus DPP-4 inhibitor arm.159 (SOE: Insufficient)

Table 25 Randomized controlled trials comparing a combination of metformin plus sitagliptin with a combination of metformin plus a GLP-1 receptor agonist on all-cause mortality

Author, Year | Followup | Number of Deaths/N (%) in the Metformin + Sitagliptin Arm | Number of Deaths/N (%) in the Metformin + GLP-1 Receptor Agonist Arm
Ahren, 2014^141^ | 104 weeks | 1/302 (0.3) | 3/302 (1.0)
Nauck, 2014^159^ | 26 weeks | 0/315 (0) | Dulaglutide 0.75 mg: 0/302 (0) Dulaglutide 1.5 mg: 0/304 (0)
Nauck, 2014^159^ | 52 weeks | 2/315 (0.6) | Dulaglutide 0.75 mg: 0/302 (0) Dulaglutide 1.5 mg: 1/304 (0.3)
Bergenstal, 2010^188^ | 26 weeks | 1/172 (0.6) | Exenatide 2 mg weekly: NR/170

GLP-1 = glucagon-like peptide-1; mg = milligrams; NR = not reported

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Basal Insulin

A single RCT (N=321) compared metformin plus exenatide with metformin plus insulin glargine and reported no deaths in either arm at 26 weeks.212 (SOE: Insufficient)

#### Strength of Evidence for All-Cause Mortality

We found low or insufficient strength of evidence for all comparisons evaluating all-cause mortality (see Key Points, Table 26, Table 27, and Table 28).

Table 26 Strength of evidence domains for monotherapy comparisons in terms of all-cause mortality among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. pioglitazone | RCTs: 4 (1755) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for short-term mortality
Metformin vs. pioglitazone | Obs: 1 (NR) | Medium | Unknown | Direct | N/A | N/A | Low | Neither treatment favored for short-term mortality
Metformin vs. rosiglitazone | RCTs: 2 (3224) | High | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin vs. rosiglitazone | Obs: 2 (193,172) | Medium | Consistent | Direct | Precise | N/A | Low | Metformin favored
Metformin vs. SU (shorter duration studies) | RCTs: 4 (928) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored for short-term mortality
Metformin vs. SU (shorter duration studies) | | | | Direct | Imprecise | N/A | Low | Neither favored for short-term mortality
Metformin vs. SU (longer duration studies) | RCTs: 2 (3199) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin favored for long-term mortality
Metformin vs. SU (longer duration studies) | Obs: 7 (398,227) | Medium | Consistent | Direct | Precise | N/A | Low | Metformin favored for long-term mortality
Metformin vs. DPP-4 inhibitors | RCTs: 5 (4,792) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for short-term mortality
Metformin vs. DPP-4 inhibitors | Obs: 1 (84,756) | Medium | Unknown | Direct | Imprecise | N/A | Low | Neither treatment favored for short-term mortality
Metformin vs. SGLT-2 inhibitors | RCTs: 4 (2,041) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. GLP-1 receptor agonists | RCTs: 2 (820) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored Incomplete reporting on death
Rosiglitazone vs. SU | RCTs: 2 (3,484) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Rosiglitazone vs. SU | Obs: 2 (79,681) | Medium | Consistent | Direct | Precise | N/A | Insufficient | Unable to determine
Pioglitazone vs. SU | RCT: 1 (502) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Pioglitazone vs. SU | Obs: 1 (20,450) | Medium | Unknown | Direct | Precise | N/A | Insufficient | Unable to determine
Pioglitazone vs. DPP-4 inhibitors | RCTs: 2 (1031) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
SU vs. DPP-4 inhibitors | RCT: 1 (426) | Medium | Unknown | Direct | Imprecise | Undetected | Low | DPP-4 inhibitors favored for short-term mortality
SU vs. GLP-1 receptor agonists | RCTs: 2 (1157) | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine Insufficient reporting of events
DPP-4 inhibitors vs. SGLT-2 inhibitors | RCTs: 2 (1486) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
DPP-4 inhibitors vs. GLP-1 receptor agonists | RCT: 1 (820) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; Met = metformin; Obs = observational; RCT = randomized controlled trial; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 27 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of all-cause mortality among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + pio | RCT: 1 (213) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. metformin + rosiglitazone | RCTs: 7 (3242) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin monotherapy favored
Metformin vs. metformin + SU | RCTs: 5 (1983) | Medium | Consistent | Direct | Imprecise | Suspected^‡^ | Low | Neither treatment favored for short-term mortality
Metformin vs. metformin + DPP-4 inhibitors (<2 years) | RCTs: 18 (12,446) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for short-term mortality
Metformin vs. metformin + DPP-4 inhibitors (long duration studies) | RCTs: 2 (2140) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. metformin + SGLT-2 inhibitors (short duration studies) | RCTs: 7 (4340) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for short-term mortality
Metformin vs. metformin + SGLT-2 inhibitors (long duration studies) | RCTs: 2 (728) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. metformin + GLP-1 receptor agonists | RCT: 2 (2110) | Medium | Consistent | Direct | Imprecise | Suspected | Low | Neither treatment favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; pio = pioglitazone; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

‡ We identified one long-term study showing five deaths in the sulfonylurea arm and one death in the metformin arm at 156 weeks.

Table 28 Strength of evidence domains for metformin-based combination comparisons in terms of all-cause mortality among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + rosiglitazone vs. metformin + SU | RCTs: 2 (1110) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for short-term mortality
Metformin + rosiglitazone vs. metformin + SU | Obs: 1 (80,936) | Medium | Unknown | Direct | Precise | N/A | Low | Neither treatment favored for short-term mortality
Metformin + pioglitazone vs. metformin + DPP-4 inhibitors | RCT: 1 (514) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + pioglitazone vs. metformin + GLP-1 receptor agonists | RCT: 1 (514) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + DPP-4 inhibitors (longer duration studies) | RCTs: 5 (6693) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin + DPP-4 inhibitors favored for long-term mortality
Metformin + SU vs. metformin + DPP-4 inhibitors (longer duration studies) | Obs: 1 (47,433) | Medium | Unknown | Direct | Precise | N/A | Low | Metformin + DPP-4 inhibitors favored for long-term mortality
Metformin + SU vs. metformin + DPP-4 inhibitors (shorter duration studies) | RCTs: 2 (1755) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer duration studies) | RCTs: 3 (3815) | High | Inconsistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for long-term mortality
Metformin + SU vs. metformin + GLP-1 receptor agonists | RCT: 2 (1678) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for long-term mortality
Metformin + SU vs. metformin + GLP-1 receptor agonists | Obs: 1 (29,437) | Medium | Unknown | Direct | Precise | N/A | Low | Neither treatment favored for long-term mortality
Metformin + SU vs. metformin + premixed insulin | RCTs: 2 (938) | High | Consistent | Direct | Imprecise | Undetected | Low | Metformin + SU favored for short-term mortality
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | RCTs: 2 (1779) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored for short-term mortality
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | RCTs: 3 (2216) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine Insufficient reporting of events in all arms
Metformin + GLP-1 receptor agonists vs. metformin + basal insulin | RCT: 1 (321) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; Met = metformin; Obs = observational; pio = pioglitazone; RCT = randomized controlled trial; RD = absolute risk difference; rosi = rosiglitazone; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) due to the few longer duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Most evidence on this outcome came from RCTs lasting less than 2 years that we found to be at low or medium risk of bias. None of the RCTs were designed to evaluate all-cause mortality. Observational studies had medium risk of bias and tended to support RCT findings. Evidence was more consistent across monotherapy comparisons, with less consistency for combination therapy comparisons, in part because of the smaller number of studies for these comparisons. The RCT evidence on mortality was substantially underpowered and imprecise because of few studies and small sample sizes with few events. As a result, we could not exclude short-term harm for any comparison with moderate strength of evidence.

Our evaluation of publication bias was generally limited by the small number of studies. We found unpublished studies that may have affected our grading of the evidence. Published studies suggested a decrease in long-term mortality for metformin plus a DPP-4 inhibitor versus metformin plus a sulfonylurea; one unpublished study was consistent with these conclusions. The single published RCT suggested increased short-term mortality for sulfonylureas versus DPP-4 inhibitors; two unpublished RCTs confirmed those findings. For the comparison of metformin versus metformin plus a sulfonylurea, we only identified one poor-quality, long-term study which showed similar mortality at 104 weeks across arms; however, an unpublished study suggested an increased risk of long-term all-cause mortality for metformin plus a sulfonylurea. For the comparison of metformin versus metformin plus a GLP-1 receptor agonist, we also only identified a single long-term study which suggested similar mortality rates at 104 weeks; however, an unpublished trial found more deaths in the metformin plus GLP-1 receptor agonist arm compared with the metformin monotherapy arm.

### Evidence for Cardiovascular Mortality

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

Three RCTs compared metformin with thiazolidinediones and did not find differences in cardiovascular mortality.50, 63, 70 Two of the RCTs were small, lasted less than one year, and did not report any cardiovascular deaths (Table 29).63, 70 Studies were not combined because of different lengths of followup and different thiazolidinediones under study. ADOPT was the single long-term RCT (median followup of 4.0 years): the actual number of participants for which ADOPT ascertained CVD mortality is unclear and withdrawals were high across the arms [37% (rosiglitazone) and 38% (metformin)].50 (SOE: Low; Neither favored)

Table 29 Randomized controlled trials comparing metformin with thiazolidinediones on cardiovascular mortality

Author, Year | Followup | Number of Events/N (%) in the Metformin Arm | Number of Events/N (%) in the Thiazolidinedione Arm
Lawrence, 2004^63^ | 24 weeks | 0/20 (0%) | 0/20 (pioglitazone) (0%)
Erem, 2014^70^ | 48 weeks | 0/19 (0%) | 0/19 (pioglitazone) (0%)
Kahn, 2006^50^ | 4 years (median) | 2/1454 (0.1%) | 1/1456 (0.1%) (rosiglitazone)

##### Metformin Versus Sulfonylureas

Two high-quality RCTs compared metformin with sulfonylureas and reported on cardiovascular mortality.50, 231 ADOPT, conducted among patients with newly diagnosed and untreated diabetes (N=2895), reported a slightly higher incidence of fatal MI in the glyburide (3/1441, 0.2%) versus the metformin (2/1454, 0.1%) arm (glyburide vs. metformin: calculated RR, 1.5 (95% CI, 0.3 to 9.0); calculated between-group difference, 0.1%). Median followup was 4.0 years for the metformin (maximum dose 2,000 mg; mean dose not reported) arm and 3.3 years for the glyburide (maximum dose 15 mg; mean dose not reported) arm, and losses to followup were also differential for the metformin (38%) arm vs. the glyburide (44%) arm.50 The smaller RCT was conducted in China among patients with known coronary heart disease (clinical evidence of acute MI or coronary stenosis >50% on angiogram) and also reported a higher risk of cardiovascular mortality in the sulfonylurea (glipizide, mean dose 28.3 mg) arm (11/148, 7.4%) compared with the metformin (mean dose 1,400 mg) arm (7/156, 4.5%) over 2.8 years.231 We calculated the RR of cardiovascular mortality comparing sulfonylurea with metformin to be 1.66 (95% CI, 0.66 to 4.16) and the between-group difference to be 2.9 percent. Losses to followup were 21 percent for each arm of this trial.231 Losses to follow up were the same (20%) across arms in Hong et al.,231 decreasing the risk of non-conservative bias due to losses of follow up across arms. In ADOPT, given differential losses to followup and followup duration across arms, study results were likely biased to the null, lending further support to the inference that metformin was favored over sulfonylurea monotherapy.

Three retrospective cohort studies, analyzing two cohorts compared metformin with a sulfonylurea, and all found a higher risk of cardiovascular mortality for sulfonylurea users versus metformin users (Table 30).225, 229, 230 To account for confounding, two of these studies used propensity score matching,225, 229 and one used multivariate regression.230 (SOE: Moderate; Metformin favored for long-term CVD mortality)

Table 30 Observational studies comparing metformin with sulfonylureas on cardiovascular mortality

Author, Year | Cohort | Metformin, N | Sulfonylurea, N | Median Followup | Adjusted HR (95% CI) for Cardiovascular Mortality
Johnson, 2005^230^ | Saskatchewan Health database | 923 | 2138 | 4.6 to 5.6 years | 0.76 (0.58 to 1.00) Reference: sulfonylurea
Schramm, 2011^229^ | Danish National Patient Register | [underlined: Prior MI] 2,906 [underlined: No prior MI] 43,340 | [underlined: Prior MI] Glibenclamide: 1,168 Glipizide: 660 Glimepiride: 3,894 [underlined: No prior MI] Glibenclamide: 12,495 Glipizide: 6,965 Glimepiride: 36,313 | 3.3 years | [underlined: Prior MI] Glibenclamide: 1.5 (1.22 to 1.84) Glipizide: 1.63 (1.28 to 2.07) Glimepiride: 1.32 (1.11 to 1.57) [underlined: No prior MI] Glibenclamide: 1.14 (1.03 to 1.25) Glipizide: 1.25 (1.12 to 1.4) Glimepiride: 1.28 (1.18 to 1.38) Reference: metformin
Andersson, 2010^225^ | Danish National Patient Register – Incident admission for heart failure^*^ | 688 | 3615 | 844 days | 0.79 (0.65 to 0.96) Reference: sulfonylurea

CI = confidence interval; HR = hazard ratio; MI = myocardial infarction

* Unclear if this population was included in Schramm, 2011^229^

##### Metformin Versus DPP-4 Inhibitors

Three RCTs compared metformin with DPP-4 inhibitors and reported on cardiovascular mortality (Table 31). These studies varied in duration and did not use similar definitions for cardiovascular events. Therefore, we did not combine them in a meta-analysis. Cardiovascular mortality was rare and appeared to be more frequent in the metformin than DPP-4 inhibitor arms, when reported.85-87 The longest study reported no cardiovascular mortality in either arm.85 (SOE: Low; DPP-4 inhibitors favored)

Table 31 Randomized controlled trials comparing metformin with DPP-4 inhibitors on cardiovascular mortality

Author, Year | Outcome | Followup (Weeks) | Metformin Dose: Number of Events/N (%) | DPP-4 Inhibitor Dose: Number of Events/N (%)
Haak, 2012^86^ | Fatal MI | 24 | 1000 mg: 0/142 (0.0%) 2000 mg: 1/147 (0.7%) | Linagliptin 5 mg: 0/142 (0.0%)
Pfutzner, 2011^87^ | Sudden death, cardiac arrest, coronary arteriosclerosis, cardiac failure, acute MI | 76 | 2000 mg: 3/328 (0.9%) | Saxagliptin 10 mg: 1/335 (0.3%)
Williams-Herman, 2010^85^ | Sudden cardiac death or worsening CHD | 104 | 1000 mg: 0/182 2000 mg: 0/182 | Sitagliptin 100 mg: 0/179

CHD = coronary heart disease; DPP-4 = dipeptidyl peptidase-4; mg = milligrams; MI = myocardial infarction

##### Thiazolidinediones Versus Sulfonylureas

The ADOPT trial compared rosiglitazone with glyburide and reported two fatal myocardial infarctions in the rosiglitazone arm (2/1446, 0.1%) and three fatal myocardial infarctions in the glyburide arm (3/1441, 0.2%) resulting in a calculated risk ratio of 0.66 (95% CI, 0.11 to 3.97) and between-group difference of -0.1% for rosiglitazone versus glyburide. Notably, losses to followup and followup duration were differential across the arms; losses to followup were higher (44% vs. 37%) for the sulfonylurea versus rosiglitazone arm and median followup was shorter (3.3 years vs. 4.0 years) for the sulfonylurea versus rosiglitazone arm.50 (SOE: Low; Rosiglitazone favored for long-term CVD mortality)

##### Sulfonylureas Versus DPP-4 Inhibitors

Two small RCTs compared a sulfonylurea with a DPP-4 inhibitor (duration 52 to 58 weeks) and reported mixed results on fatal myocardial infarction.106, 107 The high-quality study reported one fatal myocardial infarction in the linagliptin arm (1/151, 0.7%) and none in the sulfonylurea arm (0/151, 0%),106 and the other study reported two events in the sulfonylurea arm (2/212, 0.9%) and did not report on fatal myocardial infarctions in the sitagliptin arm (n=211).107 The lower-quality study did not use an intention-to-treat analysis for fatal myocardial infarction and had large losses to followup (19.8% and 22.3% in the sulfonylurea and DPP-4 inhibitor arms, respectively).107 (SOE: Insufficient)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

Five RCTs reported in four articles120, 123, 127, 241 compared metformin with metformin plus rosiglitazone and found non-significantly increased odds of short-term cardiovascular mortality for the combination of metformin plus rosiglitazone versus metformin monotherapy (pooled OR, 2.68; 95% CI, 0.42 to 17.08) (Figure 48). Three of the studies reported a single cardiovascular death in the metformin plus rosiglitazone arm, and all studies reported no cardiovascular deaths in the metformin monotherapy arms. The results of the 80-week study127 did not differ from those of the shorter studies.120, 123, 241 We did not find statistical heterogeneity (I^2^ = 0.0%), and removal of any one study from the meta-analysis did not change the inference. The pooled between-group difference for short-term cardiovascular mortality for metformin plus rosiglitazone versus metformin monotherapy was 0.3% (95% CI, -0.2 to 0.9%).

Figure 48 Pooled odds ratio for short-term cardiovascular mortality comparing metformin with a combination of metformin plus rosiglitazone

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus rosiglitazone; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio for short-term cardiovascular mortality comparing metformin with a combination of metformin plus rosiglitazone.

A single 26-week RCT compared metformin monotherapy with metformin plus pioglitazone (15, 30, and 45 mg arms) and reported one sudden cardiac death in the metformin plus pioglitazone 45 mg arm (1/130, 1%). The study did not report on sudden cardiac death for the other arms.126

Of note, two of the RCTs had substantial losses to followup (38% to 45% in one study127 and 12% to 18% in the other126). This, along with a lack of reporting on the intention-to-treat population, limits our conclusions. (SOE: Low; Metformin monotherapy favored over combination of metformin plus rosiglitazone for short-term CVD mortality) (SOE: Insufficient for combination of metformin plus pioglitazone)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Six RCTs comparing metformin with the combination of metformin plus a DPP-4 inhibitor showed a non-significant decreased risk of short-term cardiovascular mortality for the metformin plus DPP-4 inhibitor arms versus metformin, based on 10 deaths across the trials (pooled OR, 0.51; 95% CI, 0.15 to 1.73) (Figure 49). We did not find statistical heterogeneity, and removal of any one study did not change the inference from the meta-analysis.86, 87, 142, 145, 152, 159 Cardiovascular deaths were not described in the metformin plus saxagliptin arm in Pfutzner 2011, et al, and we assumed that no events occurred in that arm for the meta-analysis.87 Three of the RCTs included in the meta-analysis also had additional arms with lower dosages and did not report on events in those arms.86, 87, 126 The pooled between-group difference in short-term cardiovascular mortality was -0.1% (95% CI, -0.4 to 0.3%) for the combination of metformin plus a DPP-4 inhibitor compared with metformin.

Figure 49 Pooled odds ratio for short-term cardiovascular mortality comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a DPP-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio for short-term cardiovascular mortality comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

An additional longer RCT (104 weeks) reported one cardiovascular death in the metformin plus sitagliptin arm and did not report on cardiovascular deaths in the metformin monotherapy arms.85 (SOE: Low; Combination of metformin plus DPP-4 inhibitors favored for short-term CVD mortality)

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

One RCT (N=546) compared metformin with the combination of metformin plus dapagliflozin at different doses (2.5, 5.0, and 10.0 mg) and reported two cardiovascular deaths in the metformin plus 2.5-mg dapagliflozin arm at 102 weeks and did not report on deaths in the other arms.170 (SOE: Insufficient)

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single 26-week RCT compared metformin with metformin plus dulaglutide at two different doses (0.5 mg and 1.5 mg per week) and reported one fatal stroke in the metformin plus dulaglutide 1.5 mg/week (1/304, 0.3%) arm and no events in the metformin (0/177, 0%) or metformin plus dulaglutide 0.75 mg/week (0/302, 0%) arm.159 (SOE: Low; Metformin favored for short-term fatal stroke)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

A single, five-arm, 26-week RCT (N=1,554) compared metformin plus pioglitazone (arms with doses of 15 mg, 30 mg, and 45 mg) with metformin plus alogliptin (12.5-mg and 25-mg arms) and reported on sudden cardiac death.126 The investigators reported one sudden cardiac death in the metformin plus pioglitazone 45 mg arm (1/129, 0.8%) and did not report on this outcome in the other arms. (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Six RCTs addressed cardiovascular/cerebrovascular mortality for this comparison. Results from four RCTs, each with 104 weeks of followup and low event rates (<1%), suggested lower rates of fatal cardiovascular events for metformin plus a DPP-4 inhibitor versus metformin plus a sulfonylurea (pooled OR, 0.57; 95% CI, 0.19 to 1.69) (Figure 50). We did not find statistical heterogeneity (I^2^ = 0.0%).194-197 Removal of any single study did not change the inference of the meta-analysis. Of note, definitions of cardiovascular mortality varied slightly across the studies included in this meta-analysis (Table 32). Losses to followup were high across these studies. The pooled between-group difference for long-term cardiovascular mortality for metformin plus a DPP-4 inhibitor compared with metformin plus a sulfonylurea was -0.2 (95% CI, -0.5 to 0.1%).

Figure 50 Pooled odds ratio for long-term cardiovascular mortality comparing combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = metformin plus a dipeptidyl peptidase-4 inhibitor; Met = metformin; OR = odds ratio; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio for long-term cardiovascular mortality combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor.

Table 32 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor on cardiovascular mortality

Author, Year | Followup (Weeks) | Definition of Fatal Cardiovascular Event | Number of Events / N (%) in the Metformin Plus Sulfonylurea Arm | Number of Events / N (%) in the Metformin Plus DPP-4 Inhibitor Arm | Included in Meta-Analysis
Seck, 2010^196,*^ | 104 | Sudden cardiac death, fatal MI | 3/548 (0.5%) | 0/588 (0) | Yes
Goke, 2010^195^ | 104 | Composite CVD mortality outcome (cardiac failure, MI) | 1/430 (0.2%) | 1/428 (0.2%) | Yes
Gallwitz, 2012^194^ | 104 | Composite CVD mortality outcome (sudden cardiac death, fatal MI, and fatal stroke) | 2/775 (0.3%) | 2/776 (0.3%) | Yes
Del Prato, 2014^197^ | 104 | Not specified | 4/869 (0.5%) | 2/873 (0.2%) (alogliptin 12.5 mg) 2/878 (0.2%) (alogliptin 25 mg) | Yes
Schernthaner, 2015^193^ | 52 | Fatal MI | NR/360 | 1/360 (0.3%) | No; short-term duration and did not report on events in both arms
Goke, 2010^195^ | 104 | Fatal stroke | 1/430 (0.2%) | NR/428 | No; did not report on events in both arms
Arechavaleta, 2011^190^ | 30 | Fatal stroke | 1/519 (0.2%) | NR/516 | No; short-term duration and did not report on events in both arms

CVD = cardiovascular disease; DPP-4 = dipeptidyl peptidase-4; MI = myocardial infarction

* 104-week followup of Nauck 2007, et al192

One RCT with 52 weeks of followup conducted among persons (predominantly men) older than 65 years of age reported one fatal myocardial infarction in the metformin plus saxagliptin arm and did not report on this outcome explicitly for the metformin plus sulfonylurea arm.193

Two RCTs (N=1,893; durations, 30 weeks and 104 weeks) addressed fatal stroke specifically for this comparison; these reported one event in the metformin plus sulfonylurea arms and did not report on this outcome for the metformin plus DPP-4 inhibitor arms.190, 195

A single retrospective cohort study (N=36,230) from the Danish Patient Register reported a significantly lower risk of cardiovascular mortality, with a median of 2.1 years of followup, for metformin plus DPP-4 inhibitor users versus metformin plus sulfonylurea users (adjusted rate ratio, 0.57; 95% CI, 0.4 to 0.8).227 (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored for long-term (2-5 years) CVD mortality; SOE: Insufficient for short-term CVD mortality)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Two long-term RCTs (104 weeks of followup) each reported one cardiovascular death in the metformin plus sulfonylurea arm (1/408, 0.2%^199^ and 1/482, 0.2%^201^) and no cardiovascular deaths in the metformin plus SGLT-2 inhibitor arms.199, 201 Therefore, the between-group difference in long-term cardiovascular mortality across trials was 0.2% for the combination of metformin plus a sulfonylurea compared with the combination of metformin plus an SGLT-2 inhibitor. (SOE: Low; Combination of metformin plus a SGLT-2 inhibitor favored for long-term CVD mortality)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single retrospective cohort study (N=29,437) from the Danish Patient Register reported a non-significantly lower risk of cardiovascular mortality, with a median of 2.1 years of followup, for metformin plus GLP-1 receptor agonist users versus metformin plus sulfonylurea users (adjusted rate ratio, 0.89; 95% CI, 0.47 to 1.68).227 (Not graded)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Basal Insulin

A single retrospective cohort study (N=29,437) from the Danish Patient Register reported a significantly increased risk of cardiovascular mortality, with a median of 2.1 years of followup, for metformin plus basal insulin users versus metformin plus sulfonylurea users (adjusted rate ratio, 1.57; 95% CI, 1.23 to 2.01).227 (Not graded)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Premixed Insulin

A single 16-week, open-label RCT (N=341) randomized participants with poorly controlled diabetes on metformin alone to the addition of glibenclamide or twice daily insulin aspart 70/30 and reported no deaths in the metformin plus glibenclamide arm and one fatal myocardial infarction in the metformin plus premixed insulin arm.208 (SOE: Low; Combination of metformin plus sulfonylurea favored for short-term CVD mortality)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single 26-week, open-label RCT (N=665) randomized participants with poorly controlled diabetes on metformin alone to the addition of oral sitagliptin (100 mg) or one of two doses of daily subcutaneous injections of liraglutide (1.2 mg or 1.8 mg) and reported one fatal cardiac arrest in the metformin plus sitagliptin arm (1/219, 0.5%) and none in the metformin plus liraglutide arms (liraglutide 1.2 mg: 0/221, 0% and liraglutide 1.8 mg: 0/218, 0%).210

A single 26-week RCT (N=921) reported on fatal stroke for metformin plus sitagliptin versus metformin plus dulaglutide at two doses (0.75 mg/week and 1.5 mg/week). The investigators reported one fatal stroke in the metformin plus dulaglutide 1.5-mg/week arm (1/304, 0.3%) and no events in the other arms (dulaglutide 0.75 mg: 0/302, 0% and sitagliptin: 0/315, 0%).159 (SOE: Insufficient)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

A single 32-week, open-label, cross-over study (N=597) randomized participants to metformin plus insulin glargine or metformin plus insulin lispro 75/25 twice daily and reported one fatal myocardial infarction in the metformin plus insulin lispro 75/25 arm and no events in the metformin plus glargine arm.224 (SOE: Insufficient)

#### Strength of Evidence for Cardiovascular Mortality

Although we identified one comparison for which there was moderate strength of evidence on long-term cardiovascular mortality, evidence was generally of low strength or insufficient for cardiovascular mortality (see Key Points, Table 33, Table 34, and Table 35). Most of the evidence was on short-term cardiovascular mortality, and none of the RCTs were designed to evaluate cardiovascular mortality. We identified observational studies which strengthened the evidence for a few comparisons (metformin versus sulfonylurea and metformin plus a sulfonylurea versus metformin plus DPP-4 inhibitors). Almost all of the evidence on cardiovascular mortality was of medium or high risk of bias. When data were available from more than one study for a given comparison, the evidence tended to be consistent. However, we only identified a single study for many comparisons making consistency indeterminate. Sample size and low event rates in the RCTs limited the power and precision of the evidence on cardiovascular mortality, and the small number of studies limited our ability to assess publication bias. We identified one unpublished study (an extension of an included study with 156 weeks of followup) which addressed several comparisons of interest. This study had few fatal cardiovascular or cerebrovascular events (none in the metformin arm or metformin plus GLP-1 receptor agonist arm; one fatal MI in the metformin plus sitagliptin arm; and one fatal cerebrovascular accident in the metformin plus sulfonylurea arm). This study's results were slightly contrary to our findings on metformin plus a sulfonylurea versus metformin plus a DPP-4 inhibitor. While we did not identify any published RCTs comparing cardiovascular mortality for metformin versus metformin plus a sulfonylurea, the unpublished RCT suggested similar long-term fatal cardiovascular mortality for metformin and metformin plus sulfonylurea, but possibly an increased risk of fatal cerebrovascular accident in the metformin plus sulfonylurea arm versus metformin. We also did not identify long-term RCTs of metformin plus a DPP-4 inhibitor versus metformin plus a GLP-1 receptor agonist; in this long-term unpublished study, metformin plus sitagliptin was favored for this comparison.

Table 33 Strength of evidence domains for monotherapy comparisons in terms of cardiovascular mortality among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. pioglitazone | RCTs: 2 (120) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. rosiglitazone | RCT: 1 (2940) | High | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. SU (longer duration studies) | RCTs: 2 (4664) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin favored; RR 1.6 to 2.0 and between group differences 0.1% to 2.9% from RCTs for SU vs. metformin
Metformin vs. SU (longer duration studies) | Observational: 3 (115,105) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin favored; RR 1.6 to 2.0 and between group differences 0.1% to 2.9% from RCTs for SU vs. metformin
Metformin vs. DPP-4 inhibitors | RCTs: 3 (3,188) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | DPP-4 inhibitors favored for short-term mortality
Rosiglitazone vs. SU (longer-duration studies) | RCT: 1 (2,987) | High | Unknown | Direct | Imprecise | Undetected | Low | Rosiglitazone favored
SU vs. DPP-4 inhibitors (shorter duration studies) | RCT: 2 (653) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine Events not reported for all arms

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 34 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of cardiovascular mortality among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + rosiglitazone | RCTs: 5 (2,167) | High | Consistent | Direct | Imprecise | Undetected | Low | Metformin favored for short-term mortality
Metformin vs. metformin + pioglitazone | RCT: 1 (1,554) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. metformin+DPP-4 inhibitor | RCTs: 7 (6,673) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin + DPP-4 inhibitors favored for short-term mortality
Metformin vs. metformin + SGLT-2 inhibitor | RCT: 1 (546) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine Events not reported on in three arms
Metformin vs. metformin + GLP-1 receptor agonist | RCT: 1 (1098) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin favored for short-term fatal stroke

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; RCT = randomized controlled trial; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) and pooled risk differences (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 35 Strength of evidence domains for metformin-based combination comparisons in terms of cardiovascular mortality among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + pioglitazone vs. metformin + DPP-4 inhibitor | RCT: 1 (1554) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine Events not reported on in four arms
Metformin + SU vs. metformin + DPP-4 inhibitors (104 weeks followup) | RCTs: 4 (6184) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin + DPP-4 inhibitors favored for long-term CVD mortality
Metformin + SU vs. metformin + DPP-4 inhibitors (104 weeks followup) | Observational: 1 (36,620) | Medium | Unknown | Direct | Precise | N/A | Low | Metformin + DPP-4 inhibitors favored for long-term CVD mortality
Metformin + SU vs. metformin + DPP-4 inhibitors (shorter duration studies) | RCTs: 2 (1755) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine Events not reported on in all arms
Metformin + SU vs. metformin + SGLT-2 inhibitor (longer duration studies) | RCT: 2 (2266) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin + SGLT-2 inhibitors favored
Metformin + SU vs. metformin + premixed insulin | RCT: 1 (341) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin + SU favored for short-term CVD mortality
Metformin + DPP-inhibitor vs. metformin + GLP-1 receptor agonist | RCTs: 2 (1,763) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + basal insulin vs. metformin + premixed insulin | RCT: 1 (597) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine

CVD = cardiovascular; DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence due to a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Cardiovascular and Cerebrovascular Morbidity

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

###### Randomized Controlled Trials

Two RCTs compared metformin with rosiglitazone and reported on different cardiovascular morbidity outcomes.50, 59 In ADOPT, at 4 years, there was a small increased risk of non-fatal MI for the rosiglitazone vs. metformin arm (between-group difference of 0.3 absolute percentage points) and an increased risk of peripheral vascular disease (between-group difference of 0.6 absolute percentage points). There was also a small increased risk of stroke in the metformin vs. rosiglitazone arm (between-group difference of 0.2 absolute percentage points).50 Total CVD event rates were higher (by 0.7%) in the rosiglitazone (77/1456, 5.3%) vs. metformin (67/1454, 4.6%) arm. The completeness of ascertainment of CVD morbidity was unclear, and losses to followup were 37% and 38% for the rosiglitazone and metformin arms, respectively.50 Event rates in the small 32-week study were the same in both arms (Table 36).59

Table 36 Randomized controlled trials comparing metformin with rosiglitazone on cardiovascular morbidity

Author, Year | Enrolled N | Followup | Outcome | Number of Events / N (%) for Metformin Vs. Rosiglitazone
Kahn^*^, 2006^50^ | 4360 | 4 years (median) | Non-fatal myocardial infarction | 21/1454 (1.4) vs. 25/1456 (1.7)
Kahn^*^, 2006^50^ | 4360 | 4 years (median) | Stroke | 19/1454 (1.3) vs. 16/1456 (1.1)
Kahn^*^, 2006^50^ | 4360 | 4 years (median) | Peripheral vascular disease | 27/1454 (1.9) vs. 36/1456 (2.5)
Rosenstock, 2006^59^ | 468 | 32 weeks | Not defined ischemic heart disease | 2/154 (1) vs. 1/159 (1)

* ADOPT Study

Three small RCTs, each shorter than a year, compared metformin with pioglitazone and reported very few events.63, 70, 71 We did not perform a meta-analysis given the absence of events in two of the three studies and lack of reporting in the third (Table 37).

Table 37 Randomized controlled trials comparing metformin with pioglitazone on cardiovascular morbidity

Author, Year | Enrolled N | Followup | Outcome | Number of Events / N (%) for Metformin Vs. Pioglitazone
Erem, 2014^70^ | 57 | 48 weeks | Nonfatal MI | 0/19 (0) vs. 0/9 (0)
Lawrence, 2004^63^ | 60 | 24 weeks | Nonfatal CVD morbidity/MI | 0/20 (0) vs. 0/20 (0)
Genovese, 2013^71^ | 58 | 16 weeks | Discontinuation due to myocardial ischemia | 1/29 (3.4) vs. NR/29

CVD = cardiovascular disease; MI = myocardial infarction; NR = not reported

###### Observational Studies

Three retrospective cohort studies233, 243, 244 compared metformin with rosiglitazone and reported mixed results (Table 38). One study reported no increased risk of ischemic heart disease for rosiglitazone versus metformin,233 and the other two studies suggested an increased risk of cardiovascular morbidity for rosiglitazone versus metformin.243, 244

Table 38 Retrospective cohort studies comparing metformin with rosiglitazone on cardiovascular morbidity

Author, Year | Population (N) | Followup | Outcome | Adjusted HR (95% CI)
Pantalone, 2009^233^ | Cleveland Clinic electronic health record system (11,515) | 8 years | Ischemic heart disease | 0.96 (0.76 to 1.21) Reference = metformin
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (48,537) | 6 years | Myocardial infarction | 2.09 (1.36 to 3.24)
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (48,537) | 6 years | Angina pectoris | 1.79 (1.39 to 2.30)
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (48,537) | 6 years | Transient ischemic attack | 2.57 (1.33 to 4.96)
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (48,537) | 6 years | Stroke | 1.61 (0.72 to 3.62)
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (48,537) | 6 years | | Reference = metformin
Brownstein, 2010^244^ | United States (34,252) | 7 years | Hospitalization for acute MI | 3.0 (2.4 to 3.7) Reference = metformin

CI = confidence interval; HR = hazard ratio; MI = myocardial infarction

(SOE: Low; Metformin favored for long-term (follow up at least 2 years) CVD morbidity)

Two of the retrospective cohort studies compared metformin with pioglitazone233, 243 and found no significant difference in cardiovascular disease risk between groups (Table 39). Of note, participants in the Taiwan National Health Insurance database study prescribed pioglitazone were more likely to have a history of cardiovascular disease than those prescribed metformin.243 (SOE: Moderate; Neither metformin nor pioglitazone favored)

Table 39 Retrospective cohort studies comparing metformin with pioglitazone on cardiovascular morbidity

Author, Year | Population (N) | Followup | Outcome | Adjusted HR (95% CI)
Pantalone, 2009^233^ | Cleveland Clinic electronic health record system (11944) | 8 years | Ischemic heart disease | 1.11 (0.91 to 1.34) Reference = metformin
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (46,939) | 6 years | Myocardial infarction | 1.0 (0.26 to 3.89)
Hsiao, 2009^243^ | Taiwan National Health Insurance – newly-diagnosed diabetes (46,939) | 6 years | Angina pectoris | 1.15 (0.6 to 2.21) Reference = metformin

CI = confidence interval; HR = hazard ratio

##### Metformin Versus Sulfonylureas

###### Randomized Controlled Trials

Three RCTs50, 134, 231 compared metformin with sulfonylureas and reported on cardiovascular morbidity (Table 40). Two of these RCTs had long-term followup. In ADOPT, the risk of nonfatal myocardial infarction and stroke were higher in the metformin versus sulfonylurea arm (between-group differences of 0.4% and 0.1% for nonfatal myocardial infarction and stroke, respectively). Notably, losses to followup and duration of followup were differential across these arms with higher losses to followup (44% versus 38%) and shorter median followup (3.3 versus 4.0 years) for sulfonylurea versus metformin.50 Cardiovascular event rates were higher for sulfonylurea versus metformin in the other long-term RCT, which was conducted in a predominantly-male, Chinese population with an established diagnosis of coronary heart disease.231 Losses to followup were the same (21%) for both arms of this trial.231 The third RCT was small and short (6 months) and found higher rates of undefined cardiovascular morbidity in the sulfonylurea than metformin arm.134

Table 40 Randomized controlled trials comparing metformin with sulfonylureas on cardiovascular morbidity

Author, Year | Followup | Outcome | Number of Events / N (%) for Metformin Vs. Sulfonylurea
Kahn, 2006^50^ | 4 years (median) | Non-fatal MI | 21/1454 (1.4) vs. 15/1441 (1.0)
Kahn, 2006^50^ | 4 years (median) | Stroke | 19/1454 (1.3) vs. 17/1441 (1.2)
Kahn, 2006^50^ | 4 years (median) | Peripheral vascular disease | 27/1454 (1.9) vs. 31/1441 (2.2)
Hong, 2013^231^ | 2.8 years | Non-fatal MI confirmed by medical records | 5/156 (3.2) vs. 6/148 (4.1)
Hong, 2013^231^ | 2.8 years | Non-fatal stroke confirmed by medical records | 10/156 (6.4) vs. 15/148 (10)
Hong, 2013^231^ | 2.8 years | Arterial revascularization by PTCA or by coronary artery bypass graft confirmed by medical records | 21/156 (14) vs. 25/148 (17)
Hong, 2013^231^ | 2.8 years | CVD morbidity composite outcome^*^ | 39/156 (25) vs. 52/148 (35)
Hong, 2013^231^ | 2.8 years | New critical cardiac arrhythmia confirmed by medical record | 30/156 (19) vs. 27/148 (18)
Hong, 2013^231^ | 2.8 years | New or worsening angina confirmed by medical record | 77/156 (49) vs. 71/148 (48)
Hong, 2013^231^ | 2.8 years | New peripheral vascular disease events confirmed by medical record | 1/156 (0.6) vs. 6/148 (4.1)
Hermann, 1994^134^ | 6 months | Unclear – CVD morbidity/CHD | 2/25 (5) vs. 3/21 (9)

CHD = coronary heart disease; CVD = cardiovascular disease; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty

* Including nonfatal myocardial infarction, nonfatal stroke, or arterial revascularization by PTCA or by coronary artery bypass graft, death from a cardiovascular cause, and death from any cause, obtained and confirmed by medical record.

###### Observational Studies

Five retrospective cohort studies229, 233, 238, 245, 246 and one case-control study226 reported on cardiovascular morbidity for metformin and sulfonylurea use (Table 41 and Table 42). All but one study233 reported a significantly increased risk of incident cardiovascular morbidity among sulfonylurea versus metformin users.226, 229, 233, 238, 245, 246 This risk extended to populations without a history of cardiovascular disease at baseline.229, 238

Table 41 Retrospective cohort studies comparing metformin with sulfonylureas on cardiovascular morbidity

Author, Year | Population (N) | Followup | Outcome | Adjusted HR (95% CI)
Pantalone, 2009^233^ | Cleveland Clinic EHR system (17863) | 8 years | Incident ischemic heart disease by ICD-9 code | 0.94 (0.85 to 1.05) Reference = sulfonylurea
Hung, 2013^245^ | Taiwan National Health Insurance Research Database (N=925) | Median 3.1 to 3.8 years | Composite cardiovascular outcome based on ICD-9 codes | 0.31 (0.24 to 0.4) Reference = sulfonylurea
Roumie, 2012^246^ | Veterans Administration database linked to Medicare files (N= 253,690) | 0.61 to 0.78 years | Hospitalization for acute MI, stroke, or death | 1.21 (1.13 to 1.29)^*^ Reference = metformin
Roumie, 2012^246^ | Veterans Administration database linked to Medicare files (N= 253,690) | 0.61 to 0.78 years | Acute MI and stroke | 1.15 (1.06 to 1.25)^*^ Reference = metformin
Schramm, 2011^229^ | Danish Patient Register (N=107,806) | Median 3.3 years | Composite of MI, stroke and cardiovascular death based on ICD-10 codes | Prior MI 1.29 (1.09 to 1.52)^†^ 1.46 (1.2 to 1.78)^‡^ 1.29 (1.12 to 1.49)^§^ No prior MI 1.12 (1.04 to 1.21)^†^ 1.17 (1.07 to 1.28) ‡ 1.21 (1.14 to 1.29)^§^ Reference = metformin
Corrao, 2011^238^ | Health Service Databases Lombardy (N=70,437) | Mean 4.8 to 5.1 years | Composite of death from any cause or first hospitalization for MI, cerebrovascular disease, or coronary artery bypass graft based on ICD-9 | 1.15 (1.08 to 1.21) Reference = metformin

CI = confidence interval; EHR = electronic health record; HR = hazard ratio; ICD = International Classification of Diseases; MI = myocardial infarction

* 33% to 39% data missing on hemoglobin A1c (covariate in model)

† glibenclamide

‡ glipizide

§ glimepiride

Table 42 Nested case-control study comparing metformin with sulfonylureas on hospitalization for incidence of myocardial infarction

Authour, Year | Population Followup | Cases | Controls | Adjusted OR (95% CI)
Horsdal, 2011^226^ | Danish National Patient Registry Median 6 months | First-time hospitalization for non-fatal MI (N=10,616) | Age- and gender-matched patients with diabetes and no history of MI (N=90,697) | 0.86 (0.78 to 0.95) Reference = sulfonylurea

CI = confidence interval; MI = myocardial infarction; OR = odds ratio

(SOE: Low; Metformin favored for long-term CVD morbidity)

##### Metformin Versus DPP-4 Inhibitors

Two RCTs compared metformin with DPP-4 inhibitor monotherapy and reported on cardiovascular morbidity. One small, 26-week RCT of low quality reported one nonfatal myocardial infarction in the alogliptin arm (1/112, 1%) and did not report on events in the metformin arms (n=109 and n=111 for the 1000-mg and 2000-mg arms, respectively). This study noted that it evaluated nonfatal stroke but did not report these outcomes.84 This study did not use an intention-to-treat approach for cardiovascular morbidity and had greater than 17 percent losses to followup in both arms.84 A second larger and longer (76 weeks) RCT of higher quality reported that 2.1 percent of participants in the metformin arm (n=328) experienced an acute cardiovascular adverse event (otherwise unspecified) and did not report on this outcome in the saxagliptin arm (n=335).87

A single retrospective cohort study from the Danish National Patient Registry (N=84,756) reported a non-significant increase in cardiovascular risk (composite outcome: all-cause mortality, acute myocardial infarction, and stroke) for sitagliptin versus metformin over mean followup of 0.9 to 1.8 years (adjusted RR, 1.22; 95% CI, 0.92 to 1.61).228 (SOE: Insufficient)

##### Metformin Versus SGLT-2 Inhibitors

A single 12-week RCT reported one episode of Prinzmetal angina in the metformin arm (1/80, 1.3%) and did not report on events in the empagliflozin 10 mg (n=81) or empagliflozin 25 mg (n=82) arms.239 This study did not use an intention-to-treat approach and did not report on withdrawals.239 (SOE: Insufficient)

##### Thiazolidinediones Versus Sulfonylureas

Two RCTs50, 217 and two retrospective cohort studies243, 244 compared the effects of sulfonylureas and rosiglitazone on cardiovascular morbidity (Table 43). In the long-term RCT, ADOPT, CVD morbidity was higher in the rosiglitazone versus sulfonylurea arm (between-group difference of 0.7% for in nonfatal MI and 0.1% for stroke); losses to followup (44% versus 37%) were higher in the sulfonylurea arm while followup duration was shorter.50 Results of the shorter RCT were consistent with ADOPT.217 CVD morbidity was non-statistically significantly higher for rosiglitazone versus a sulfonylurea in two of three observational studies.243, 244

Table 43 Studies comparing rosiglitazone with sulfonylureas on cardiovascular morbidity

Author, Year Study Design | Population (N) | Followup | Outcome | Results
Kahn, 2006^50^ RCT | ADOPT Study (4360) | 4.0 years for rosiglitazone 3.3 years for SU (median) | Nonfatal MI | Rosiglitazone: 1.7%; SU: 1.0%
Kahn, 2006^50^ RCT | ADOPT Study (4360) | 4.0 years for rosiglitazone 3.3 years for SU (median) | Stroke | Rosiglitazone: 1.3%; SU: 1.2%
Kahn, 2006^50^ RCT | ADOPT Study (4360) | 4.0 years for rosiglitazone 3.3 years for SU (median) | Peripheral vascular disease | Rosiglitazone: 2.5%; SU: 2.2%
St John Sutton, 2002^217^ RCT | N=351 | 52 weeks | Cardiac-related adverse events | Rosiglitazone: 15.4%; SU: 12.1%
Pantalone, 2009^233^ Retrospective cohort | Cleveland Clinic electronic health record system (8506) | 8 years | Incident ischemic heart disease by ICD-9 code | Adjusted HR 0.90; 95% CI, 0.71 to 1.14 Reference = sulfonylurea
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (99744) | 6 years | MI | Adjusted HR 1.49; 95% CI, 0.99 to 2.24
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (99744) | 6 years | Stroke | Adjusted HR 1.45; 95% CI, 0.69 to 3.05
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (99744) | 6 years | Transient ischemic attack | Adjusted HR 1.90; 95% CI,1.02 to 3.57
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (99744) | 6 years | Angina pectoris | Adjusted HR 1.46; 95% CI, 1.15 to 1.85
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (99744) | 6 years | | Reference = sulfonylurea
Brownstein, 2010^244^ Retrospective cohort | Research Patient Data Registry (34,252) | 7 years | Hospitalization for MI | Adjusted RR, 1.3; 95% CI, 1.0 to 1.6 Reference = sulfonylurea

ADOPT = A Diabetes Outcome Progression Trial; CI = confidence interval; HR = hazard ratio; ICD = International Classification of Diseases; MI = myocardial infarction; RCT = randomized controlled trial; RR = rate ratio

A single short-term RCT95 reported a 0.2% increase in coronary heart disease morbidity for glyburide versus pioglitazone at 56 weeks (Table 44). Long-term cohort studies compared the effects of sulfonylureas and pioglitazone and reported mixed findings.233, 243 (SOE: Low; Sulfonylureas favored over rosiglitazone) (SOE: Low; Sulfonylureas favored over rosiglitazone for long-term CVD morbidity; Low; Pioglitazone favored for short-term CVD morbidity)

Table 44 Studies comparing pioglitazone with sulfonylureas on cardiovascular morbidity

Author, Year Study Design | Population (N) | Followup | Outcome | Results
Jain, 2006^95^ RCT | N=502 | 56 weeks | CHD, MI and chest pain | Pioglitazone: 1%; glyburide: 3%
Pantalone, 2009^233^ Retrospective cohort | Cleveland Clinic electronic health record system (8935) | 8 years | Incident ischemic heart disease by ICD-9 code | Adjusted HR 1.04; 95% CI, 0.86 to 1.26
Pantalone, 2009^233^ Retrospective cohort | Cleveland Clinic electronic health record system (8935) | 8 years | | Reference = sulfonylurea
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (98146) | 6 years | MI | Adjusted HR 0.72; 95% CI, 0.19 to 2.77
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (98146) | 6 years | Stroke | Adjusted HR 0.59; 95% CI, 0.06 to 6.03
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (98146) | 6 years | Transient ischemic attack | Adjusted HR 1.28; 95% CI, 0.34 to 4.86
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (98146) | 6 years | Angina pectoris | Adjusted HR 0.91; 95% CI, 0.47 to 1.74
Hsiao, 2009^243^ Retrospective cohort | Taiwan National Health Insurance – newly-diagnosed diabetes (98146) | 6 years | | Reference=sulfonylurea

CHD = coronary heart disease; CI = confidence interval; HR = hazard ratio; ICD = International Classification of Diseases; MI = myocardial infarction; RCT = randomized controlled trial

##### Sulfonylureas Versus DPP-4 Inhibitors

Two RCTs (each 52 to 58 weeks duration) compared the effects of sulfonylureas with DPP-4 inhibitors on short-term cardiovascular morbidity.106, 107 One study reported one nonfatal myocardial infarction in one participant in the sulfonylurea arm (1/76, 1.3%) and no events in the linagliptin arm (0/151, 0.0%); the between-group risk difference was 1.3% for sulfonylurea versus linagliptin.106 The other study reported 11 vascular events in the sulfonylurea arm (11/212, 5.2%) and eight events in the sitagliptin arm (8/210, 3.8%); the between-group risk difference was 1.4% for the sulfonylurea versus sitagliptin arm.107 The dose of glimepiride was low in one study (4 mg).106 The study by Arjona Ferreira et al did not use an intention-to-treat approach and had greater than 20 percent losses to followup across arms.107 (SOE: Low; DPP-4 inhibitors favored for short-term cardiovascular morbidity)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Two RCTs compared the effects of sulfonylurea with liraglutide on cardiovascular morbidity and reported slightly higher rates of cardiovascular events in the sulfonylurea arms compared with the liraglutide arms. In the longer study (104 weeks), 14 of 248 (6%) participants experienced a cardiac disorder in the sulfonylurea arm, and eight of 251 (3%) participants and 11 of 246 (5%) participants experienced a cardiac disorder in the liraglutide 1.2 mg and 1.8 mg arms, respectively (between-group differences of 1 to 3% for sulfonylurea versus liraglutide).113 The other RCT (N=200) was 52 weeks and reported higher rates of vascular (7.6% versus 6.3%; between-group difference, 1.3%) and cardiac (10.6% versus 6.3%; between-group difference, 4.3%) disorders in the sulfonylurea arm compared with the liraglutide arm.110 Of note, Kaku et al. used low doses of glibenclamide (1.25 to 2.5 mg/day) and liraglutide (0.9 mg/day).110 (SOE: Low; GLP-1 receptor agonists favored)

#### Metformin Versus a Metformin-Based Combination Comparison

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

Six short-term (18 to 32 weeks) RCTs found a non-significant increase in cardiovascular morbidity for metformin plus rosiglitazone versus metformin (pooled OR, 1.59; 95% CI, 0.60 to 4.25) (Figure 51).59, 118-121, 247 Removal of any one study did not change the inference of the meta-analysis. The pooled risk difference for short-term CVD morbidity for metformin plus rosiglitazone versus metformin was 0.4% (95% CI, -0.2 to 1.1%).

Figure 51 Pooled odds ratio of cardiovascular morbidity comparing metformin with a combination of metformin plus rosiglitazone

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus rosiglitazone; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of cardiovascular morbidity comparing metformin with a combination of metformin plus rosiglitazone.

Another longer RCT (80 weeks of followup) reported four ischemic events (4/344, 1.7%) and five cerebrovascular events (5/344, 1.5%) in the metformin plus rosiglitazone arm compared with four ischemic events (4/334, 1.2%) and three cerebrovascular events (3/334, 0.9%) in the metformin arm.127 Of note, the text of article contradicts results in the table (reported here); the text reports five ischemic events in the metformin arm.127 (SOE: Low; Metformin favored over combination of metformin plus rosiglitazone for short-term cardiovascular morbidity)

A single 26-week RCT compared metformin to metformin plus pioglitazone (dosed at 15, 30, and 45 mg in separate arms) and reported one nonfatal stroke in the metformin arm (1/129) and did not report on this outcome for the metformin plus pioglitazone arms (n=388).126 (SOE: Insufficient)

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

One 6-month RCT,134 which was a good although older study, reported rates of 5% and 14% for unspecified cardiovascular events in the metformin versus combination metformin plus sulfonylurea arm, respectively.134 (SOE: Low; Metformin favored for short-term CVD morbidity)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Six short RCTs compared the combination of metformin plus a DPP-4 inhibitor with metformin monotherapy and found no significant difference in short-term cardiovascular morbidity based on 11 events across studies (pooled OR, 1.90; 95% CI, 0.57 to 6.36) (Figure 52).118, 142, 146, 147, 152, 160 We did not find statistical evidence of heterogeneity, and removal of any one study did not change the inference of this meta-analysis. The pooled risk difference for short-term cardiovascular morbidity for metformin plus a DPP-4 inhibitor versus metformin was 0.3% (95% CI, -0.4% to 1.1%).

Figure 52 Pooled odds ratio of short-term cardiovascular morbidity comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of short-term cardiovascular morbidity comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

We did not include one RCT (N=651) in the meta-analysis because of its longer duration (76 weeks). The investigators reported a rate of 2.1% for acute cardiovascular adverse events in the metformin arm, 0.3% in the metformin plus saxagliptin 5 mg arm, and did not report this rate in the metformin plus saxagliptin 10 mg arm.87

We did not include three additional RCTs in the meta-analysis because of a lack of reporting of events in at least one arm precluding estimation of an OR (Table 45). Cardiovascular morbidity was slightly higher in the combination therapy arms based on the limited results reported.84, 151, 164

Table 45 Randomized controlled trials comparing metformin with a combination of metformin plus a DPP-4 inhibitor on cardiovascular morbidity

Author, Year | Followup (Weeks) | Outcome | Number of Events / N (%) for Metformin Vs. Metformin + DPP-4 Inhibitor
Raz, 2008^142^ | 30 | Acute MI | Results presented in Figure 52
Yang, 2011^146^ | 24 | Acute myocardial ischemia or MI | Results presented in Figure 52
Wang, 2015^160^ | 24 | Nonfatal MI | Results presented in Figure 52
Scott, 2008^118^ | 18 | Acute CV event | Results presented in Figure 52
Fonseca, 2012^147^ | 18 | Acute CV events (myocardial ischemia or MI | Results presented in Figure 52
Ross, 2012^152^ | 12 | Acute MI | Results presented in Figure 52
Pfutzner, 2011^87^ | 76 | Acute CV events | NR/328 (2.1) Metformin + saxagliptin 5 mg: NR/320 (0.3) Metformin + saxagliptin 10 mg: NR/323 (NR)
Haak, 2013^164^ | 52 | Nonfatal MI | 1/170 (0.6) Metformin 2000 mg + linagliptin: NR /171 Metformin 1000 mg + linagliptin: 3/225 (1.3)
Haak, 2013^164^ | 52 | Unstable angina | NR/170 (0.6) Metformin 2000 mg + linagliptin: 2/171 (1.2) Metformin 1000 mg + linagliptin: 2/225 (0.9)
White, 2014^151^ | 12 | Nonfatal MI | NR/86 1/74 (1.4)
Pratley^*^, 2014^84^ | 26 | Nonfatal MI | Metformin 2000 mg: NR/111 Metformin 1000 mg: NR/109 Metformin 2000 mg + alogliptin: NR/114 Metformin 1000 mg + alogliptin: NR/106

CV = cardiovascular; DPP-4 = dipeptidyl peptidase-4; mg = milligrams; MI = myocardial infarction; NR = not reported

* included in table even though did not report on outcome for any of the arms because study did provide results for alogliptin monotherapy arm implying that there were likely no nonfatal myocardial infarctions in the other arms

Four short-term RCTs comparing metformin with metformin plus a DPP-4 inhibitor reported on nonfatal stroke but did not report on events in all arms (Table 46).84, 126, 160, 164 Nonfatal strokes were uncommon and appeared more common in the metformin monotherapy arms based on limited reporting of results on this outcome. (SOE: Insufficient for short-term cardiovascular morbidity)

Table 46 Randomized controlled trials comparing metformin with a combination of metformin plus a DPP-4 inhibitor on nonfatal stroke

Author, Year | Followup (Weeks) | Number of Events / N (%) for Metformin Vs. Metformin + DPP-4 Inhibitor
Haak, 2013^164^ | 52 | 1/170 (0.6) Metformin 2000 mg + linagliptin: NR/171 Metformin 1000 mg + linagliptin: 1/225 (0.4)
DeFronzo, 2012^126^ | 26 | 1/129 (0.8) Metformin + alogliptin 12.5 mg: NR/128 Metformin + alogliptin 25 mg: NR/129
Pratley, 2014^84^ | 26 | Metformin 2000 mg: NR/111 Metformin 1000 mg: NR/109 Metformin 2000 mg + alogliptin: NR/114 Metformin 1000 mg + alogliptin: NR/106
Wang, 2015^160^ | 24 | 1/100 (1) Metformin + linagliptin 5 mg: 0/205 (0)

DPP-4 = dipeptidyl peptidase-4; mg = milligrams; NR = not reported

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

A single 24-week RCT (N=182) compared the effects of metformin with metformin plus dapagliflozin on cardiovascular morbidity. This study reported that two participants (2/91, 2.2%) developed angina pectoris in the metformin plus dapagliflozin arm and that there were no events in the metformin arm (0%).169 The investigators also reported one transient ischemic attack in the metformin plus dapagliflozin arm (1/91, 1.1%) and did not report on this outcome in the metformin arm.169 (SOE: Low; Metformin favored for short-term cardiovascular morbidity)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Two short-term RCTs compared metformin plus pioglitazone with metformin plus a sulfonylurea and reported mixed results on cardiovascular morbidity.183, 185 One trial (N=288) with submaximally-dosed pioglitazone (30 mg/day) reported three events (coronary heart disease, carotid artery stenosis, and peripheral artery disease) among 142 participants (2%) at 24 weeks in the metformin plus sulfonylurea arm and did not report on events in the metformin plus pioglitazone arm.185 The other RCT (N=250) reported one acute myocardial infarction at 24 weeks in the metformin plus pioglitazone arm (1/103, 1%) versus no events in the metformin plus sulfonylurea arm (0%).183

A single retrospective cohort study from a Veterans Affairs population with Medicare (N=80,936) compared the combination of metformin plus a thiazolidinedione with metformin plus a sulfonylurea and found a non-significant increase in risk of stroke or myocardial infarction (composite outcome) for sulfonylurea-based versus thiazolidinedione-based therapy: adjusted HR, 1.15 (95% CI, 0.8 to 1.66; p=0.46); minimum followup was 12 months, but mean duration of followup was not reported.242 (SOE: Insufficient)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Two RCTs compared metformin plus pioglitazone with metformin plus a DPP-4 inhibitor at 26 weeks and reported on cerebrovascular events.126, 188 One reported a cerebrovascular accident in each arm (1/165, 1% in the metformin plus pioglitazone arm and 1/166, 1% in the metformin plus sitagliptin arm),188 and the other did not report on cerebrovascular events in the combination therapy arms (reported events for monotherapy as discussed above).126 Bergenstal 2010 et al., also reported three cardiovascular events (unstable angina, n=1; coronary artery occlusion, n=2) in the metformin plus pioglitazone group and no events in the metformin plus sitagliptin (0/166, 0%) group.188 This RCT did not use an intention-to-treat approach and had differential and large losses to followup (13% in the metformin plus DPP-4 inhibitor arm and 21% in the metformin plus pioglitazone arm).188 (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored over metformin plus pioglitazone for short-term cardiovascular morbidity)

Two RCTs compared metformin plus rosiglitazone with metformin plus sitagliptin (duration 16 to 18 weeks) and reported on cardiovascular and cerebrovascular morbidity.118, 186 The trial evaluating cardiovascular events reported none in the metformin plus rosiglitazone arm (0/87, 0%) and two coronary artery disease events in the metformin plus sitagliptin arm (2/94, 2.1%).118 The other trial (N=169) reported a transient ischemic attack in each arm.186 (SOE: Low; combination of metformin plus rosiglitazone favored over metformin plus DPP-4 inhibitor for short-term cardiovascular morbidity)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

One RCT (N=325) compared metformin plus pioglitazone with metformin plus exenatide at 26 weeks and reported one cerebrovascular accident (1/165, 1%) and three cardiac events (unstable angina and coronary artery occlusions; 3/165, 2%) in the metformin plus pioglitazone arms and no events in the metformin plus exenatide arm (0/160, 0%).188 (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Four RCTs reported on long-term cardiovascular morbidity for the comparison of metformin plus sulfonylurea with metformin plus a DPP-4 inhibitor (Tables 47 and 48).192, 194-197

Table 47 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor on cardiovascular morbidity

Author, Year | Followup | Outcome | Number of Events / N (%) for Metformin + Sulfonylurea Vs. Metformin + DPP-4 Inhibitor
Nauck, 2007^192, 196^ | 104 weeks | MI | 1/588 (0.2) vs. 0/584 (0)
Gallwitz, 2012^194^ | 104 weeks | Nonfatal MI | 10/775 (1.3) vs. 6/776 (0.8) Unadjusted RR, 0.6; 95% CI, 0.22 to 1.64 Reference = metformin + sulfonylurea
Gallwitz, 2012^194^ | 104 weeks | Composite: CV death, MI, stroke, or admission to hospital due to unstable angina | 26/775 (3.4) vs. 12/776 (1.5) Unadjusted RR, 0.46; 95% CI, 0.23 to 0.91 Reference = metformin + sulfonylurea
Gallwitz, 2012^194^ | 104 weeks | Admission to hospital due to unstable angina | 3/775 (0.4) vs. 3/776 (0.4) Unadjusted RR, 1.0; 95% CI, 0.2 to 4.93 Reference = metformin + sulfonylurea
Del Prato, 2014^197^ | 104 weeks | Adjudicated non-fatal MI | 4/869 (0.5) vs. 1/873 (0.1) (alogliptin 12.5 mg) 4/869 (0.5) vs. 4/878 (0.5) (alogliptin 25 mg)
Goke, 2010^195^ | 104 weeks | Not defined | Qualitative statement: “The incidences of CV AEs…were low and similar between treatment groups.”

AE = adverse event; CI = confidence interval; CV = cardiovascular; DPP-4 = dipeptidyl peptidase-4; MI = myocardial infarction; RR = risk ratio

Table 48 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor on cerebrovascular morbidity

Author, Year | Followup | Outcome | Number of Events / N (%) for Metformin + Sulfonylurea Vs. Metformin + DPP-4 Inhibitor
Gallwitz, 2012^194^ | 104 weeks | Cerebral infarction | 4/775 (0.5) vs. 0/776 (0)
Gallwitz, 2012^194^ | 104 weeks | Nonfatal stroke^*^ | 11/775 (1.4) vs. 3/776 (0.4) Unadjusted RR, 0.27; 95% CI, 0.08 to 0.97 Reference = metformin + sulfonylurea
Goke, 2010^195, 248^ | 104 weeks | Transient ischemic attack | 1/430 (0.2) vs. NR/428
Del Prato, 2014^197^ | 104 weeks | Adjudicated non-fatal stroke | 3/869 (0.3) vs. 3/873 (0.3) (alogliptin 12.5 mg) 3/869 (0.3) vs. 2/878 (0.2) (alogliptin 25 mg)

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; NR = not reported; RR = risk ratio

* This outcome appears to include stroke and transient ischemic attacks.

Three of these 104-week studies provided results on non-fatal myocardial infarction and showed a non-significant decrease in fatal myocardial infarction for the combination of metformin plus a DPP-4 inhibitor versus metformin plus a sulfonylurea (pooled OR, 0.68; 95% CI, 0.31 to 1.50) (Figure 53).192, 194, 196, 197 We did not find statistical heterogeneity (I-squared = 0%). The pooled risk difference in non-fatal myocardial infarction for metformin plus a DPP-4 inhibitor versus metformin plus a sulfonylurea was -0.2% (95% CI, -0.5 to 0.2%).

Figure 53 Pooled odds ratio of cardiovascular morbidity comparing combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin plus a sulfonylurea; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of cardiovascular morbidity comparing combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor.

Evidence on long-term cerebrovascular morbidity was mixed. One RCT reported higher rates of stroke for metformin plus a sulfonylurea compared with metformin plus a DPP-4 inhibitor;194 another found similar rates across arms,197 and a third reported a single event in the metformin plus sulfonylurea arm but did not report on this outcome in the metformin plus DPP-4 inhibitor arm (Table 48).195 Of note, sulfonylurea doses were submaximal in these RCTs. (SOE: Moderate; Combination of metformin plus a DPP-4 inhibitor favored for long-term non-fatal myocardial infarction)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

A single RCT (N=814) with 208 weeks of follow up reported no CVD events (not otherwise defined) for the combination of metformin plus glipizide or metformin plus dapagliflozin; dose of glipizide or dapagliflozin achieved was not reported.54 (SOE: Low; Neither favored for long-term CVD morbidity)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two short-term (26-week) RCTs (N=991) suggested no difference in cardiovascular morbidity for the combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist.188, 210 One study reported no cardiovascular events in either arm (defined as unstable angina or coronary artery occlusion), and the other study reported “cardiac disorders” in one participant in the metformin plus sitagliptin and the metformin plus liraglutide 1.8 mg arm.188, 210

One of these trials reported on cerebrovascular accidents and reported one event in the metformin plus sitagliptin arm and no events in the metformin plus exenatide arm.188 (SOE: Low; Neither favored for short-term cardiovascular morbidity)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a Basal Insulin

A single RCT (N=501) reported that five participants experienced cardiovascular events (carotid artery occlusion, angina pectoris, and unstable angina) in the metformin plus insulin glargine arm (5/237, 2%) and two participants experienced cardiovascular events (nonfatal acute myocardial infarction and angina pectoris) in the metformin plus sitagliptin arm (2/264, 1%) at 25 weeks.211 Of note, events had to be considered “serious” to be reported.211 This study did not use an intention-to-treat analysis and had moderate, differential losses to followup across arms (5% for sitagliptin and 9% for insulin glargine).211 (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored for short-term cardiovascular morbidity)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

In a 16-week cross-over study, 105 participants with newly-diagnosed type 2 diabetes were randomly assigned to metformin plus insulin glargine or metformin plus insulin lispro 75/25 twice daily.223 During an 8-week lead-in period, participants received neutral protamine Hagedorn (NPH) insulin at night, and the metformin dose was titrated. One participant experienced a myocardial infarction during the lead-in period and one participant experienced chest pain during treatment with premixed insulin; the investigators did not report if this event occurred before or after the crossover.223 (SOE: Insufficient)

#### Strength of Evidence for Cardiovascular and Cerebrovascular Morbidity

We did not find any high strength evidence for cardiovascular and cerebrovascular morbidity. Most evidence was low or insufficient because of a paucity of studies reporting on these outcomes (see Key Points, Table 49, Table 50, and Table 51). Notably, none of the RCTs was designed to evaluate cardiovascular outcomes, and the RCTs tended to be short (less than 12 months), and event rates were low. We identified a mixture of RCT and observational study evidence for these outcomes for the monotherapy comparisons, but only RCTs for combination comparisons. Most of the evidence was at medium or high risk of bias. Common study limitations included lack of reporting on randomization and masking procedures and lack of an intention-to-treat approach combined with substantial losses to followup. The consistency of this evidence was limited by the small number of studies and differences in definitions. While observational studies offer the opportunity for precision given their frequently large sizes, most evidence was still imprecise since we did not identify that many high-quality observational studies. Notably, the observational studies did not tend to corroborate RCT findings.

Table 49 Strength of evidence domains for monotherapy comparisons in terms of cardiovascular and cerebrovascular morbidity among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. rosiglitazone | RCTs: 2 (4828) | High | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin favored for long-term CVD morbidity
Metformin vs. rosiglitazone | | | | | | | Low | Metformin favored for long-term CVD morbidity
Metformin vs. rosiglitazone | Observational: 3 (94,304) | Medium | Inconsistent | Direct | Precise | N/A | Low | Metformin favored for long-term CVD morbidity
Metformin vs. pioglitazone | RCTs: 3 (158) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. pioglitazone | | | | | | | Low | Neither treatment favored
Metformin vs. pioglitazone | Observational: 2 (58,883) | Medium | Consistent | Direct | Precise | N/A | Low | Neither treatment favored
Metformin vs. SU | RCT: 3 (4808) | High | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin favored for long-term CVD morbidity
Metformin vs. SU | | | | | | | Low | Metformin favored for long-term CVD morbidity
Metformin vs. SU | Observational: 6 (545,686) | Medium | Consistent | Direct | Precise | N/A | Low | Metformin favored for long-term CVD morbidity
Metformin vs. DPP-4 inhibitors | RCT: 2 (2,090) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. DPP-4 inhibitors | | | | | | | Insufficient
Metformin vs. DPP-4 inhibitors | Observational: 1 (84,756) | Medium | Unknown | Direct | Precise | N/A | Insufficient | Inadequate reporting of events in all arms
Metformin vs. SGLT-2 inhibitors | RCT: 1 (408) | High | Unknown | Direct | Imprecise | N/A | Insufficient | Unable to determine
Rosiglitazone vs. SU | RCT: 2 (4711) | High | Consistent | Direct | Imprecise | Undetected | Low | SU favored for long-term CVD morbidity
Rosiglitazone vs. SU | | | | | | | Low | SU favored for long-term CVD morbidity
Rosiglitazone vs. SU | Observational: 3 (142,502) | Medium | Inconsistent | Direct | Precise | N/A | Low | SU favored for long-term CVD morbidity
Pioglitazone vs. SU | RCT: 1 (502) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Pioglitazone favored for short-term CVD morbidity
Pioglitazone vs. SU | | | | | | | Low | Pioglitazone favored for short-term CVD morbidity
Pioglitazone vs. SU | Observational: 2 (107,081) | Medium | Inconsistent | Direct | Precise | N/A | Low | Pioglitazone favored for short-term CVD morbidity
SU vs. DPP-4 inhibitors | RCTs: 2 (653) | Medium | Consistent | Direct | Imprecise | Undetected | Low | DPP-4 inhibitor favored for short-term CVD morbidity
SU vs. GLP-1 receptor agonists | RCTs: 2 (1157) | High | Consistent | Direct | Imprecise | Undetected | Low | GLP-1 receptor agonist favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 50 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of cardiovascular and cerebrovascular morbidity among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + rosiglitazone (shorter duration studies) | RCTs: 7 (3136) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin favored for short-term CVD morbidity
Metformin vs. metformin + pioglitazone | RCTs: 1 (1,554) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. metformin + SU (shorter duration study) | RCT: 1 (110) | Low | Unknown | Direct | Imprecise | Undetected | Low | Metformin favored for short-term CVD morbidity
Metformin vs. metformin + DPP-4 inhibitor (shorter duration studies) | RCTs: 11 (4351) | Low | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine Inadequate reporting of events in all arms
Metformin vs. metformin + SGLT-2 inhibitor (shorter duration study) | RCT: 1 (182) | Low | Unknown | Direct | Imprecise | Undetected | Low | Metformin favored for short-term CVD morbidity

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 51 Strength of evidence domains for combination therapy comparisons in terms of cardiovascular and cerebrovascular morbidity among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Met + TZD vs. Met + SU | RCTs: 2 (538) | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Met + TZD vs. Met + SU | Obs: 1 (80,936) | Medium | Unknown | Direct | Imprecise | N/A | Insufficient | Unable to determine
Met + pioglitazone vs. Met + DPP-4 inhibitor (shorter duration studies) | RCTs: 2 (2068) | High | Consistent | Direct | Imprecise | Undetected | Low | Met + DPP-4 inhibitor favored for short-term cardiovascular morbidity
Met + rosiglitazone vs. Met + DPP-4 inhibitor (shorter duration studies) | RCTs: 2 (350) | High | Unknown | Direct | Imprecise | Undetected | Low | Met + rosiglitazone favored for short-term CVD morbidity
Met + pioglitazone vs. Met + GLP-1 receptor agonist (shorter duration study) | RCT: 1 (325) | High | Unknown | Direct | Imprecise | Undetected | Low | Met + GLP-1 receptor agonist favored for short-term CVD morbidity
Met + SU vs. Met + DPP-4 inhibitor (long-term non-fatal MI) | RCTs: 4 (5049) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Met + DPP-4 inhibitor favored for long-term non-fatal MI^‡^
Met + SU vs. Met + SGLT-2 inhibitor (long-term) | RCT: 1 (814) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
Met + DPP-4 inhibitor vs. Met + GLP-1 receptor agonist (short-term studies) | RCTs: 2 (1179) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Met + DPP-4 inhibitor vs. Met + basal insulin (shorter duration studies) | RCTs: 1 (501) | High | Unknown | Direct | Imprecise | Undetected | Low | Met + DPP-4 inhibitor favored for short-term CVD morbidity
Met + basal insulin vs. Met + premixed insulin | RCTs: 1 (105) | Medium | Unknown | Direct | Imprecise | Suspected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; Obs = observational; OR = odds ratio; RD = absolute risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the clinical outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95% confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

‡ The evidence for long-term cerebrovascular morbidity was insufficient.

We identified unpublished studies for several comparisons. We identified one unpublished study describing the long-term followup (156 weeks) of one of the included studies141 that had not reported on CVD morbidity in its publication. This study compared metformin, metformin plus a sulfonylurea, metformin plus a DPP-4 inhibitor, and metformin plus a GLP-1 receptor agonist. Rescue therapy was highest in the metformin arm (rescue therapy rates: 59, 33, 36, and 26% for the metformin, metformin plus a sulfonylurea, metformin plus a DPP-4 inhibitor, and metformin plus a GLP-1 receptor agonist arms, respectively). Given this pattern of rescue therapy (differential use of medications across arms), these unpublished findings from comparisons of combination therapies with metformin alone were dissimilar to the published results: participants in the metformin arm experienced higher rates of CVD morbidity than those in the metformin plus a sulfonylurea and metformin plus a DPP-4 inhibitor arms. This study also provided a comparison of metformin to metformin plus a GLP-1 receptor agonist, but conclusions are limited by the high and differential use of rescue therapy in this study.

We identified two short-term, unpublished studies comparing sulfonylurea with DPP-4 inhibitors which were not completely consistent with our findings (one suggested similar myocardial infarction rates but increased cerebrovascular events for sulfonylurea, and the other suggested increased risk of unstable angina for sulfonylurea users versus DPP-4 inhibitor users).

We identified two unpublished RCTs with long-term follow up comparing the combination of metformin plus a sulfonylurea with metformin plus a DPP-4 inhibitor. Results were consistent with our finding that metformin plus a DPP-4 inhibitor was associated with lower coronary heart disease risk than metformin plus a sulfonylurea. Inclusion of these studies may have raised our strength of evidence for this comparison.

We identified one published and one unpublished study of metformin plus a basal insulin versus metformin plus a premixed insulin. The published study did not report on events in both arms whereas the unpublished study suggested an increased risk of cardiovascular morbidity (consistent with the reporting of an event in the metformin plus premixed arm in the published RCT). Therefore, the unpublished study could have led to a higher grade for the strength of this evidence which might have supported a conclusion about this comparison.

Finally, we identified unpublished studies for three comparisons for which we did not have published studies. As described above, an unpublished report of the long-term follow up of an included study141 which did not report on CVD morbidity compared metformin plus a sulfonylurea with metformin plus a GLP-1 receptor agonist and suggested that coronary heart disease risk might be higher for metformin plus a GLP-1 receptor agonist versus metformin plus a sulfonylurea. A short-term RCT comparing pioglitazone with a DPP-4 inhibitor suggested increased short-term CVD morbidity with DPP-4 inhibitor monotherapy. Another unpublished study found similar rates of cerebrovascular morbidity (cerebral infarctions) for pioglitazone and exenatide.

### Evidence for Retinopathy

#### Monotherapy Comparisons

##### Sulfonylureas Versus GLP-1 Receptor Agonists

A single RCT (N=400) compared rates of retinopathy at 52 weeks in participants randomized to submaximally dosed glibenclamide or submaximally dosed liraglutide. Nine (9/132, 6.8%) and 16 (16/268, 6%) participants were diagnosed with retinopathy as a “treatment-emergent adverse event” in the sulfonylurea and GLP-1 receptor agonist arms, respectively.110 The study did not report on baseline rates of retinopathy.110 Losses to follow up were greater than 15% in each arm, and the investigators did not use an intention-to-treat approach for this analysis.110 (SOE: Low; Neither favored)

#### Metformin Versus a Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Two RCTs (N=437) compared low-dose metformin with low-dose metformin plus a DPP-4 inhibitor at 12 weeks and reported on retinopathy.149, 157 Each trial reported one case of retinopathy in the metformin monotherapy arm. One of the RCTs reported one case of retinopathy in the metformin plus DPP-4 inhibitor arm (alogliptin 12.5 mg) and no cases in in the metformin plus alogliptin 25 mg arm.157 The other RCT reported no cases in the metformin plus sitagliptin arm.149 (SOE: Low; Neither favored short-term)

#### Strength of Evidence for Retinopathy

We identified three RCTs (and no observational studies) evaluating retinopathy, and one study was of poor quality.110 Therefore, evidence is mainly insufficient for this outcome (see Key Points and Table 52). We identified an unpublished study comparing pioglitazone with exenatide which reported similar rates of blurred vision in both arms.

Table 52 Strength of evidence domains for comparisons in terms of retinopathy among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
SU vs. GLP-1 receptor agonists Shorter duration study | RCT: 1 (411) | High | Unknown | Direct | Imprecise | Undetected | Low | Neither arm favored
Metformin vs. metformin + DPP-4 inhibitors Shorter duration studies | RCTs: 2 (437) | Low | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of evidence. Unless otherwise specified, conclusions for retinopathy are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Nephropathy

We included the following nephropathy outcomes: categorical definitions of new or progressive nephropathy, changes in urine albumin, and changes in estimated glomerular filtration rate.

Studies of comparisons including a SGLT-2 inhibitor are described in the section on renal insufficiency in this report (see Key Question 3 – renal insufficiency).

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

One RCT and two retrospective cohort studies evaluated this outcome and found mixed results.62, 249, 250 The 12-month RCT (N=1,194) reported a significant decrease in the urine albumin-to-creatinine ratio for participants randomized to the pioglitazone arm compared with the metformin arm (19% versus 1% reduction; P = 0.002).62

The smaller retrospective cohort study of 1,271 patients in the US (Baylor Health Care System, Dallas, TX and Christiana Care Health System, Newark, DE) evaluated nephropathy defined as new albuminuria or new estimated glomerular filtration rate (eGFR) rate below 60 mL/min/1.73 m^2^ and found no significant difference between metformin users and thiazolidinedione users, for either outcome (adjusted HR, 1.00 and 1.04 for thiazolidinedione versus metformin), with median followup of 2.8 to 3.2 years.250

The large, although short, retrospective cohort study from the Veterans Health Administration (N=93,577) with median followup of 0.7 to 0.9 years also found no significant difference in nephropathy for thiazolidinedione versus metformin users. The adjusted HR for the composite outcome of an eGFR event (persistent decline of 25% or greater from baseline eGFR) or end-stage renal disease (eGFR less than 15 mL/min/1.73 m^2^or first inpatient or outpatient code for dialysis or related procedures or renal transplant) was 0.92 (95% CI, 0.71 to 1.18).249 (SOE: Insufficient)

##### Metformin Versus Sulfonylureas

One small (N=51) 3-month RCT reported that microalbuminuria decreased significantly with metformin (P = 0.008) and increased non-significantly with glibenclamide (P = 0.09). eGFR was stable in the metformin arm (P = 0.46) and increased in the sulfonylurea arm (P = 0.04).251 The study did not provide statistical comparisons between groups.

Three retrospective cohort studies in the United States suggested a decreased risk of nephropathy among metformin versus sulfonylurea users (Table 53).249, 250, 252 Two of the studies were from the Veterans Health Administration and it is not clear if the study populations overlapped.249, 252 (SOE: Low; Metformin favored)

Table 53 Retrospective cohort studies comparing metformin with sulfonylureas on nephropathy

Author, Year | Population | Followup | Outcome Definition | HR (95% CI)
Hung, 2013^252^ | Veterans Health Administration VA Mid-South VISN 9 Data Warehouse (N=13,238) Incident medication users | Approximately 1 year | Composite of GFR event or ESRD^*^ | All: 0.85 (0.72 to 1.01) Urine protein measures at baseline: 0.78 (0.64 to 0.97) Reference = sulfonylurea
Hung, 2012^249^ | Veterans Health Administration N=93,577 Did not appear to exclude incident users | 0.7 to 0.9 years (median) | Composite of GFR event or ESRD^*^ | 1.2 (1.13 to 1.28) Reference = metformin
Masica, 2013^250^ | 1,271 participants from an electronic health record database in the US (Baylor Health Care System, Dallas, TX) and Christiana Care Health System, Newark, DE) | Median follow up of 2.8 to 3.2 years | Microalbuminuria or worse | Urine protein measures available: 1.27 (0.93 to 1.74) Reference = metformin
Masica, 2013^250^ | 1,271 participants from an electronic health record database in the US (Baylor Health Care System, Dallas, TX) and Christiana Care Health System, Newark, DE) | Median follow up of 2.8 to 3.2 years | eGFR ≥60 ml/min/1.73m^2^ at first measurement and an eGFR <60 ml/min/1.73m^2^ during follow-up | eGFR available: 1.41 (1.05 to 1.91) Reference = metformin

CI = confidence interval; eGFR = estimated glomerular filtration rate; ESRD = end-stage renal disease; HR = hazard ratio; ml/min/1.73m^2^ = milliliters per minute per 1.73 meters squared; VA = Veterans Affairs; VISN = Veterans Integrated Service Network

* GFR event= persistent 25% or greater decline from the baseline eGFR; ESRD: eGFR <15 mL/minute/1.73m2 or first code for dialysis or related procedure or renal transplant

##### Thiazolidinediones Versus Sulfonylureas

Five small RCTs provided mixed results on the effect of thiazolidinediones and sulfonylureas on nephropathy outcomes, and all studies reported on albuminuria as the outcome.96-98, 102, 253 Four trials found less albuminuria in patients receiving pioglitazone compared with a sulfonylurea;96, 97, 102, 253 only one reported a significant difference.96 One trial compared rosiglitazone and glyburide at 12 months and found no statistically significant difference in the urinary albumin-to-creatinine ratio; progression to microalbuminuria did not differ between groups.98

A retrospective cohort study using a small US database reported a non-significant increased risk of nephropathy (incident albuminuria) among sulfonylurea versus thiazolidinedione users who had a measure of urine protein (adjusted HR, 1.27; 95% CI, 0.93 to 1.74).250 (SOE: Low; Thiazolidinediones favored)

##### Sulfonylureas Versus DPP-4 Inhibitors

A single RCT analyzed changes in eGFR and urine albumin-to-creatinine ratio from baseline among 277 participants randomized to glipizide or sitagliptin.107 Over 54 weeks, the eGFR decreased slightly in both arms (-3.3 and -3.9 ml/min/1.73m^2^ for glipizide and sitagliptin, respectively) and urine albumin-to-creatinine ratio increased slightly in both arms (0.1 and 0.06 for glipizide and sitagliptin, respectively). Of note, approximately 20 percent of participants were lost to followup in each arm (423 participants originally randomized), and the investigators did not conduct an intention-to-treat analysis. (SOE: Low; Neither favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

A single RCT (N=745) reported similar cumulative incidences of 6 percent, 5 percent and 5 percent of “renal and urinary disorders” at 104 weeks in patients randomized to glimepiride 8 mg, liraglutide 1.2 mg, and liraglutide 1.8 mg.113 (SOE: Low; Neither favored)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

A single small RCT with 24 weeks of followup compared sub-maximal sitagliptin (50 mg) to sub-maximal liraglutide (0.9 mg daily) and reported negligible changes in eGFR and urinary albumin excretion in both arms.115 (SOE: Low; Neither favored for short-term nephropathy outcomes)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Two RCTs compared metformin plus rosiglitazone with metformin plus a sulfonylurea. Evaluation of the urine albumin-to-creatinine ratio favored the combination of metformin plus rosiglitazone.177, 182 One small RCT (N=34), with 48 weeks of followup, reported a negligible decrease in urine albumin-to-creatinine ratio in the metformin plus thiazolidinedione arm (-0.77 mg/g) and a small increase (12.2 mg/g) in the metformin plus sulfonylurea arm.182 The larger trial (N=389) reported a greater, although non-significant, reduction in the urine albumin-to-creatinine ratio with the combination of metformin plus a thiazolidinedione versus metformin plus a sulfonylurea arm, at 32 weeks.177

The smaller RCT also reported a negligible decrease in eGFR in the metformin plus thiazolidinedione arm (-1.48 ml/min/1.73m^2^) and an increase in eGFR in the metformin plus sulfonylurea group (9.97 ml/min/1.73m^2^); the study did not provide a statistical comparison of the between-group difference.182 This very small trial reported more than 20 percent losses to followup across arms and did not use an intention-to-treat analysis for nephropathy.182 (SOE: Low; Combination of metformin plus a thiazolidinedione favored)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

A single RCT (N=514) with 26 weeks of followup reported on percent change in urine albumin-to-creatinine ratio for the combination of metformin plus pioglitazone and the combination of metformin plus sitagliptin and found similar changes from baseline in both arms: -4% (95% CI, -17% to 12.1%) for metformin plus pioglitazone and -6.9% (95% CI, -20% to unclear but greater than 0%) for metformin plus sitagliptin.188 This study had 13 percent and 21 percent losses to followup in the sitagliptin- and pioglitazone-based arms, respectively, and did not use an intention-to-treat analysis for this outcome.188 (SOE: Low; Neither treatment favored)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single RCT (N=514) with 26 weeks of followup reported on percent change in urine albumin-to-creatinine ratio for the combination of metformin plus pioglitazone and the combination of metformin plus exenatide and found a reduction in urine albumin-to-creatinine from baseline for the metformin plus exenatide arm [-16% (95% CI, -28% to -2%)] and no significant reduction for the metformin plus pioglitazone arm [-4% (95% CI, -17% to 12%)].188 This study had approximately 20 percent losses to followup in both arms and did not use an intention-to-treat analysis for this outcome.188 (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A small RCT conducted in 42 participants with baseline microalbuminuria compared change in 24-hour urine albumin over 16 weeks for metformin plus sub-maximally dosed glimepiride and metformin plus exenatide. The authors reported a significant reduction in urine albumin in the metformin plus exenatide arm (-42 mg/day; P for change for baseline <0.01) compared to the metformin plus glimepiride arm (5 mg/day; P for change from baseline >0.05; calculated between group difference, -37 mg/day; P for between-group difference <0.001).202 This small study had more than 20 percent losses to followup across arms and did not use an intention-to-treat analysis.202 (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single RCT (N=514) with 26 weeks of followup reported on percent change in urine albumin-to-creatinine ratio for the combination of metformin plus sitagliptin and the combination of metformin plus exenatide.188 The trial found a statistically significant reduction in urine albumin-to-creatinine from baseline for the metformin plus exenatide arm (-16%; 95% CI, -28% to -2%) but not for the metformin plus sitagliptin arm (-6.9%; 95% CI, -20% to unclear but greater than 0%).188 This study had approximately 20 percent losses to followup in both arms and did not use an intention-to-treat analysis for this outcome.188 (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

#### Strength of Evidence for Nephropathy

We found low or insufficient strength of evidence on nephropathy outcomes for all comparisons of interest as described in the Key Points, Table 54, and Table 55.

Table 54 Strength of evidence domains for monotherapy comparisons in terms of nephropathy among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD | RCT: 1 (1194) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. TZD | Observational: 2 (94,848) | Medium | Inconsistent | Direct | Precise | N/A | Insufficient | Unable to determine
Metformin vs. SU (shorter duration studies) | RCT: 1 (51) | High | Unknown | Indirect | Imprecise | Undetected | Low | Metformin favored
Metformin vs. SU (shorter duration studies) | Observational: 3 (108,356) | Medium | Consistent | Direct | Precise | N/A | Low | Metformin favored
TZD vs. SU (mainly shorter duration studies) | RCTs: 5 (308) | High | Consistent | Direct | Imprecise | Undetected | Low | TZD favored for short-term nephropathy outcomes
TZD vs. SU (mainly shorter duration studies) | Observational: 2 (1271) | Medium | Unknown | Direct | Imprecise | N/A | Low | TZD favored for short-term nephropathy outcomes
SU vs. DPP-4 inhibitors (shorter duration study) | RCT: 1 (423) | High | Unknown | Indirect | Imprecise | Undetected | Low | Neither treatment favored
SU vs. GLP-1 receptor agonists (longer duration study) | RCT: 1 (746) | Medium | Unknown | Indirect | Imprecise | Undetected | Low | Neither treatment favored
DPP-4 inhibitors vs. GLP-1 receptor agonists (shorter duration study) | RCT: 1 (56) | High | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; N/A = not applicable; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Studies of comparisons including an SGLT-2 inhibitor are graded in the section on renal insufficiency in this report. Unless otherwise specified, conclusions for nephropathy are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

Table 55 Strength of evidence domains for metformin-based combination comparisons in terms of nephropathy among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + SU (shorter duration studies) | RCT: 2 (433) | High | Consistent | Direct | Imprecise | Undetected | Low | Metformin + TZD favored
Metformin + TZD vs. metformin + DPP-4 (shorter duration study) | RCT: 1 (514) | High | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin + TZD vs. metformin + GLP-1 receptor agonist (shorter duration study) | RCT: 1 (514) | High | Unknown | Direct | Imprecise | Undetected | Low | Metformin + GLP-1 favored
Metformin + SU vs. metformin + GLP-1 receptor agonist (shorter duration study) | RCT: 1 (42) | High | Unknown | Direct | Imprecise | Undetected | Low | Metformin + GLP-1 favored
Metformin + DPP-4 inhibitor vs. metformin + GLP-1 receptor agonist | RCT: 1 (514) | High | Unknown | Direct | Imprecise | Undetected | Low | Metformin + GLP-1 favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Studies of comparisons including an SGLT-2 inhibitor are graded in the section on renal insufficiency in this report. Unless otherwise specified, conclusions for nephropathy are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

The evidence on nephropathy was limited by the lack of studies. For RCTs, major study limitations included small sample sizes and high rates of withdrawals (>20%), without use of an intention-to-treat approach. We could usually not determine consistency because of a lack of studies, and the evidence on all comparisons was imprecise because of insufficient sample size. We did not detect reporting bias. However, the small number of studies limited our ability to assess publication bias. Many of the studies did not provide measures of dispersion for nephropathy outcomes, but we did not believe that this was actually a source of selective analysis reporting bias as much as a reflection of a lack of a focus on reporting of these outcomes given that they were not primary outcomes.

### Evidence for Neuropathy

For the neuropathy analyses, we included studies where newly developed neuropathy was reported for each treatment group. Four short trials reported on neuropathy as an adverse outcome.121, 142, 154, 183

#### Monotherapy Comparisons

##### Metformin Versus DPP-4 Inhibitors

A single RCT compared the effects of metformin with alogliptin on undefined neuropathy. At 26 weeks of followup, one participant developed unspecified neuropathy in each of the alogliptin arms [12.5 mg (n=213) and 25 mg (n=210)]); neuropathy was not reported on in the metformin arm.154 (SOE: Insufficient)

#### Metformin Versus a Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

In a single RCT of 26 weeks duration, one withdrawal owing to undefined neuropathy occurred in the metformin arm (n=34); no events were reported on in the two metformin plus rosiglitazone arms (n=35 and n=36).121 (SOE: Insufficient)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One RCT reported the occurrence of undefined diabetic neuropathy as 2.1 percent among participants in the metformin arm (n=94) and 4.2 percent in the metformin plus sitagliptin arm (n=96) at 30 weeks.142 (SOE: Low; Metformin favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

In a 6-month trial, neuropathy was described but was not a pre-specified outcome.183 One of 103 participants in the metformin plus thiazolidinedione arm developed neuropathy, and none of the 80 participants in the metformin plus sulfonylurea arm developed neuropathy.183 (SOE: Low; Neither favored)

#### Strength of Evidence for Neuropathy

The evidence grading for neuropathy is summarized in Table 56.

Table 56 Strength of evidence domains for comparisons in terms of neuropathy among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. DPP-4 inhibitors | RCT: 1 (527) | Low | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine Results not reported for all arms
Metformin vs. metformin + TZD | RCT: 1 (105) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine Results not reported for all arms
Metformin vs. metformin + DPP-4 inhibitor (shorter duration study) | RCT: 1 (190) | High | Unknown | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin + TZD vs. metformin + SU (shorter duration study) | RCT: 1 (183) | High | Unknown | Indirect | Imprecise | Undetected | Low | Neither treatment favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for neuropathy are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

## Key Questions 3a and 3b Safety

### Study Design and Population Characteristics

We included 145 studies describing adverse effects for the comparisons of interest (Appendix D, Tables D10 to D13). We included 64 articles from our prior 2011 review16 and identified an additional 81 studies for this update. Six of the newly-included studies were updates of earlier studies.85, 87, 110, 113, 196, 210 The majority were RCTs (62 from the previous report and an additional 75 for the update). Most of the RCTs (109 out of 137, 80%) lasted 1 year or less. Sixteen RCTs (12%) had at least 2 years of followup. Few studies were designed explicitly to evaluate adverse events. Of the 22 studies designed to evaluate the adverse events specified in Key Question 3, most focused on cancer254, 255 and renal toxicity.249, 252 Thirty-one of 81 RCTs (38%) did not report on the use of rescue therapy; rescue therapy was allowed in 29 studies (36%) and was disallowed in 21 studies (26%).

The mean age of participants ranged from approximately 40 years to 81 years, with the majority of studies reporting a mean age in the upper 50s. About 50 percent of the participants were female. Sixty-two studies did not report race or ethnicity. In the studies that reported race, the majority of the participants were Caucasians. No study included more than 25 percent African American participants; two studies included more than 70 percent Hispanic participants121, 186 and seven studies included more than 70 percent Asian participants.74, 92, 109, 155, 160, 254, 256

### Risk of Bias

We included 137 trials in this section. All of the trials were described as randomized. Fifty-one percent of the trials described their randomization scheme, and another 65 percent of the trials were described as being double-blinded. Thirty-six percent of all double-blinded RCTs also described the steps taken to ensure blinding. The majority of trials (86 percent) described the withdrawals and dropouts. Of the 16 RCTs with at least 2 years of followup, 12 had over 20% loss to followup.

Of the eight observational studies included for this Key Question, 88 percent reported actual probability values and 63 percent described their measurement of the outcomes of interest. All studies described and adjusted for confounding factors and conducted statistical analyses. Seventy-five percent of studies described the number of participants who were lost to followup after the start of the period of observation.

### Key Points and Evidence Grades

#### Hypoglycemia

##### Mild, Moderate, or Total Hypoglycemia

Unless otherwise noted, results on hypoglycemia refer to the number of participants experiencing hypoglycemia and not to the number of events.

- Metformin monotherapy was favored over the following:
  ○ Sulfonylurea monotherapy for mild-moderate hypoglycemia (pooled OR for sulfonylurea versus metformin, 4.00; 95% CI, 1.75 to 9.83) (SOE: High)
  ○ The combination of metformin plus a thiazolidinedione (pooled OR for metformin plus a thiazolidinedione versus metformin monotherapy for total hypoglycemia, 1.56; 95% CI, 0.99 to 2.44) (SOE: Moderate)
  ○ The combination of metformin plus a sulfonylurea for mild, moderate, or total hypoglycemia (range in ORs, 2.15 to 28.6) (SOE: Moderate)
  ○ The combination of metformin plus an SGLT-2 inhibitor for mild or moderate hypoglycemia (pooled OR, 1.74; 95% CI, 0.83 to 3.66) (SOE: Moderate)
- The risks of mild-moderate and total hypoglycemia were similar for metformin monotherapy and the combination of metformin plus a DPP-4 inhibitor. (SOE: High)
  ○ Pooled OR for metformin plus a DPP-4 inhibitor versus metformin monotherapy:
    ▪ Mild-moderate hypoglycemia: 0.97; 95% CI, 0.63 to 1.51
    ▪ Total hypoglycemia: 0.96; 95% CI, 0.55 to 1.67
- Sulfonylurea monotherapy increased the risk of total hypoglycemia compared with thiazolidinedione monotherapy (pooled OR 6.31; 95% CI, 4.08 to 9.76). (SOE: High)
- SGLT-2 inhibitor monotherapy was associated with a lower risk of hypoglycemia compared with metformin monotherapy (pooled OR, 0.46; 95% CI, 0.16 to 1.30). (SOE: Moderate)
- DPP-4 inhibitor monotherapy was favored over sulfonylurea monotherapy (range of OR, 0.08 to 0.26 from individual studies for sulfonylurea versus DPP-4 inhibitor monotherapy). (SOE: Moderate)
- Mild-moderate hypoglycemia was more common with sulfonylurea monotherapy than with GLP-1 receptor agonist monotherapy (range in OR, 3.2 to 5.3). (SOE: Moderate)
- When compared with metformin plus a sulfonylurea, metformin plus an SGLT-2 inhibitor had less risk of mild or moderate hypoglycemia (range in OR, 0.03 to 0.13). (SOE: High)
- When compared with metformin plus sulfonylurea, several combinations had less risk of mild, moderate, or total hypoglycemia: metformin plus a thiazolidinedione, metformin plus a DPP-4 inhibitor, and metformin plus a GLP-1 receptor agonist (range in OR, 0.07 to 0.19). (SOE: High or Moderate for all comparisons)
- When compared with metformin plus basal insulin or premixed insulin, metformin plus a GLP-1 receptor agonist had less risk of mild or moderate hypoglycemia (range in OR, 0.18 to 0.35). (SOE: Moderate)
- Moderate grade evidence showed a lower risk of hypoglycemia when metformin is combined with a basal insulin rather than a premixed insulin (range in OR, 0.23 to 0.89).

##### Severe Hypoglycemia

- Only the sulfonylurea comparisons convincingly demonstrated an increased risk of severe hypoglycemia in the sulfonylurea arms compared with nonsulfonylurea medications:
  ○ Sulfonylurea versus metformin (range in OR, 1.41 to 2.04) (SOE: Moderate)
  ○ Sulfonylurea versus thiazolidinediones (OR, 8.1) (SOE: Moderate)
  ○ Metformin plus sulfonylurea versus metformin plus SGLT-2 inhibitors, and metformin plus sulfonylurea versus metformin plus DPP-4 inhibitors. (SOE: Moderate or High)

#### Gastrointestinal (GI) Side Effects

- GI adverse events are more common with:
  ○ Metformin than with DPP-4 inhibitors (pooled OR 2.6 and 2.7 for diarrhea and nausea, favoring DPP-4 inhibitors), (SOE: High);
  ○ Metformin than thiazolidinediones (between 1.7 to 4.2 fold higher odds), (SOE: Moderate);
  ○ Metformin than sulfonylureas (between 2.2 to 2.4 fold higher odds), (SOE: Moderate);
  ○ GLP-1 receptor agonists than metformin for nausea and vomiting (between 1.3 to 1.7 fold increased odds with GLP-1 receptor agonists). (SOE: Moderate)
  ○ GLP-1 receptor agonists than sulfonylureas (between 1.5 to 2.4 fold higher odds of diarrhea), (SOE: Moderate)
  ○ Metformin plus a GLP-1 receptor agonist than metformin plus a DPP-4 inhibitor (between 1.0 to 7.8 fold higher odds with metformin plus GLP-1 receptor agonists), (SOE: Moderate);
  ○ Metformin plus a GLP-1 receptor agonist than metformin plus a thiazolidinedione (between 2.9 to 6.3 fold higher odds with metformin plus a GLP-1 receptor agonist). (SOE: Moderate)
- GI adverse events are equally common with:
  ○ Thiazolidinediones and sulfonylureas (SOE: High)
  ○ Metformin monotherapy and metformin plus a DPP-4 inhibitor (SOE: Moderate for any GI adverse event, nausea, and vomiting for shorter duration studies)
  ○ Metformin plus a sulfonylurea and metformin plus a DPP-4 inhibitor in longer studies (SOE: High)
  ○ Metformin monotherapy and combination therapy with metformin plus a SGLT-2 inhibitor (for diarrhea) (SOE: Moderate)
  ○ Metformin plus a thiazolidinedione and metformin plus a sulfonylurea. (SOE: Moderate)

#### Cancer

- Type of cancer was not designated a priori in most of the studies reporting on cancer; thus, the following conclusions apply to any cancer, unless specified.
- Even though the FDA has issued warnings regarding increased risk of bladder cancer risk with pioglitazone, we found low or insufficient strength of evidence on TZD-based comparisons and cancer outcomes.
- Despite FDA warnings of a possible increased risk of thyroid cancer with GLP-1 receptor agonists, we found low-strength or insufficient evidence on GLP-1 receptor agonist-based comparisons and cancer outcomes.

#### Congestive Heart Failure

- Thiazolidinediones alone increase the risk of heart failure when compared with sulfonylureas (pooled OR in four RCTs of 1.6; 95% CI, 0.96 to 2.8) or metformin (two RCTs lasting less than a year with no events, one 4-year RCT with an absolute risk difference of 3% and range in HR of 1.2 to 1.5 in two observational studies with 6 to 8 years of followup). (SOE: Low)
- Despite recent concerns of congestive heart failure with DPP-4 inhibitors, we found low or insufficient strength of evidence on the comparative safety of this drug class for this outcome.

#### Pancreatitis

- Despite FDA warnings regarding an increased risk of pancreatitis with GLP-1 receptor agonists and DPP-4 inhibitors, we found low or insufficient evidence on the comparative safety of these drug classes for this outcome.

#### Genital Mycotic Infections (for Comparisons That Include SGLT-2 Inhibitors)

- Compared with metformin monotherapy, genital infection rates were higher for SGLT-2 inhibitor monotherapy and for the combination of metformin plus an SGLT-2 inhibitor. Rates of genital infections for combination therapy with metformin plus an SGLT-2 inhibitor were higher compared to the following:
  ○ Metformin monotherapy: pooled OR for women, 3.0; 95% CI, 1.2 to 7.2 and pooled OR for men, 2.7; 95% CI, 0.8 to 9.0 (SOE: High)
  ○ Metformin plus a sulfonylurea: pooled OR for women, 5.2; 95% CI, 3.4 to 7.8; pooled OR for men, 7.6; 95% CI, 4.0 to 14.4 (SOE: High)
  ○ Metformin plus a DPP-4 inhibitor

#### Other Serious Adverse Events

- There was no moderate or high strength of evidence for the following adverse events: liver injury, lactic acidosis, severe allergic reactions, macular edema/decreased vision, urinary tract infections (for SGLT-2 inhibitors) impaired renal function (for SGLT-2 inhibitors), fractures (for SGLT-2 inhibitors), and volume depletion (for SGLT-2 inhibitors). Therefore, we were unable to draw any firm conclusions regarding the diabetes medication comparisons and these safety outcomes.

### Evidence for Hypoglycemia

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

Five RCTs addressed hypoglycemia for metformin versus thiazolidinediones, finding no consistent differences in hypoglycemia by arm (Table 57).50, 70, 71, 73, 74 We were unable to conduct a meta-analysis because of differences in the definitions of hypoglycemia and lengths of followup. (SOE: Low; Metformin favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

Table 57 Randomized controlled trials comparing metformin with thiazolidinediones on hypoglycemia

Author, Year | Followup | Metformin (Dose^*^) | TZD (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin Vs TZD)
Kahn, 2006^50^ | 4 years | Metformin (max 2000 mg) | Rosiglitazone (max 8 mg) | Total (self-reported) | 168/1454 (11.6%) vs 142/1456 (9.8%)
Yoon, 2011^74^ | 48 weeks | Metformin (max 2000 mg; mean 1234.2 mg) | Rosiglitazone (max 8 mg; mean 5.9 mg) | Total (signs or symptoms) | 4/114 (3.5%) vs 8/117 (6.8%)
Erem, 2014^70^ | 48 weeks | Metformin (max 2000 mg) | Pioglitazone (max 45 mg) | Total (not specified) | 0/19 (0%) vs 0/19 (0%)
Russell-Jones, 2012^73^ | 26 weeks | Metformin (max 2500 mg) | Pioglitazone (max 45 mg) | Severe^‡^ Total (signs or symptoms) | 0/246 (0%) vs 0/163 (0%) 10/246 (4.1%) vs 6/163 (3.7%)
Genovese, 2013^71^ | 16 weeks | Metformin (max 2550 mg) | Pioglitazone (max 45 mg) | Total (not specified) | 0 episodes among 26 patients vs 4 episodes among 24 patients

Max = maximum; mg = milligram; TZD = thiazolidinedione

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Severe hypoglycemia was defined as symptoms resulting in loss of consciousness or seizure that showed prompt recovery after glucose administration, or documented blood glucose less than 3.0 mmol/L that required the assistance of another person because of severe impairment in consciousness.

##### Metformin Versus Sulfonylureas

Fifteen studies addressed this comparison (14 RCTs and one observational study).50, 60, 74, 129, 131-134, 136-138, 231, 257-259 Meta-analysis of five short-term RCTs deemed sufficiently homogeneous for quantitative synthesis suggested an increased risk of mild to moderate hypoglycemia for sulfonylureas versus metformin (pooled OR, 2.59; 95% CI, 0.98 to 8.86) (Figure 54). Exclusion of any one study did not change this inference.

Figure 54 Pooled odds ratio of mild or moderate hypoglycemia comparing metformin with sulfonylureas

CI = confidence interval; Group 1 = metformin; Group 2 = sulfonylureas; OR = odds ratio; pl = profile likelihood estimate

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The line at the bottom of the graph indicates the 95 percent confidence interval for the profile likelihood pooled estimate.

Pooled odds ratio of mild or moderate hypoglycemia comparing metformin with sulfonylureas.

We did not include several studies in the meta-analysis because of differences in hypoglycemia definitions,131, 133, 134, 231 in study duration,50, 258 in how hypoglycemic events were reported,258 dosing of SU,129 and in study design.259 We did not include two studies in the meta-analysis of relative odds because neither had any events in either arm.138, 257 Results of the studies not included in the meta-analyses were consistent with the findings of the meta-analysis showing an increased risk of hypoglycemia for sulfonylurea versus metformin monotherapy (Table 58). Based on limited data to evaluate this, rates of hypoglycemia did not appear to be higher for the glyburide compared to other sulfonylurea arms across the studies.

Table 58 Studies comparing metformin with sulfonylureas for hypoglycemia

Author, Year Study Design | Followup | Metformin (Dose in mg^*^) | SU (Dose in mg^*^) | Definition of Hypoglycemia | Results^†^ (Metformin Vs SU)
Hermann, 1994^134^ RCT | 24 weeks | Metformin (max 3000) | Glyburide (max 14) | Severe (based on clinical findings or available BG) | 8/38 (21.1%) vs 12/34 (35.3%); P = 0.18
Hong, 2013^231^ RCT | 36 months | Metformin (max 1500; mean 1400) | Glipizide (max 30; mean 28.3) | Severe (required assistance and/or PG < 56 mg/dL [3.1 mmol/L]) | 3/156 (1.9%) vs 4/148 (2.7%)
Chien, 2007^138^ RCT | 16 weeks | Metformin (max 2000; mean 1910) | Glyburide (max 20; mean 19) | Mild-moderate (symptomatic or BG < 60 mg/dL) | 0/25 (0%) vs 0/23 (0%)
Blonde, 2002^131^ RCT | 16 weeks | Metformin (max 2000) | Glyburide (fixed at 10) | Symptomatic and FSG <= 60 mg/dL | 1/153 (1%) vs. 3/164 (2%)
Garber, 2003^129^ RCT | 16 weeks | Metformin (max 2000) | Glyburide (max 10) | Symptoms suggesting hypoglycemia | 29/164 (18%) vs. 98/151 (65%)
Marre^‡^, 2002^132^ RCT | 16 weeks | Metformin (max 2000) | Glibenclamide (max 20) | Symptoms or labs | 0/104 (0%) vs. 7/103 (7%)
Garber, 2002^133^ RCT | 20 weeks | Metformin (max 2000) | Glyburide (max 10) | Symptomatic and BG < 60 mg/dL | 0/159 (0%) vs. 10/160 (6%)
DeFronzo^‡^, 1995^137^ RCT | 29 weeks | Metformin (max 2500) | Glyburide (max 20) | Not reported | 4/210 (2%) vs. 6/209 (3%)
Kahn, 2006^50^ RCT | 4 years | Metformin (max 2000) | Glyburide (max 15) | Total (self-reported) | 168/1454 (11.6%) vs 557/1441 (38.7%)
Wright, 2006^258^ RCT | 6 years | Metformin (max 2550) | Glyburide (max 20) | Mild to severe (not just transient symptoms) | Mean annual percentage 0.3% among 290 patients vs 1.2% among 1418 patients
Yamanouchi^‡^, 2005^60^ RCT | 12 weeks | Metformin (fixed at 750) | Glimepiride (max 2) | Not reported | 0/39 (0%) vs. 1/37 (3%)
Charpentier^‡^, 2001^136^ RCT | 20 weeks | Metformin (fixed at 2550) | Glimepiride (max 6) | Symptomatic | 8/75 (11%) vs. 17/150 (11%)
Derosa, 2004^257^ RCT | 48 weeks | Metformin (max 3000) | Glimepiride (max 4) | Mild-moderate (not specified) | 0/75 (0%) vs 0/73 (0%)
Yoon^‡^, 2011^74^ RCT | 48 weeks | Metformin (mean 1234.2; max 2000) | Glimepiride (mean 4.5; max: 8) | Symptomatic | 4/114 (4%) vs. 23/118 (19%)
Weir, 2011^259^ Retrospective cohort | 3 months | Metformin (NR) | Glyburide (NR) | Total (presented to an emergency room or hospital with an admission diagnosis of hypoglycemia) | Among patients with normal renal function 27/572 (4.7%) vs 53/193 (27.5%); aOR = 9.0 (95% CI, 4.9 to 16.4) Among patients with impaired renal function 29/580 (5.0%) vs 109/444 (24.5%); aOR = 6.0 (95% CI, 3.8 to 9.5)

aOR = adjusted odds ratio; BG = blood glucose; CI = confidence interval; max = maximum; mg = milligrams; mg/dL = milligrams per deciliter; mmol/L = millimoles per liter; PG = plasma glucose; RCT = randomized controlled trial; SU = sulfonylurea

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Results were included in the meta-analysis.

Three studies (two RCTs and one observational study) reported on severe hypoglycemia (range in OR 0.49 to 0.71; range in RD -1% to -23%), all favoring metformin (Table 58).134, 231, 259 (SOE: High; Metformin favored for mild, moderate, or total hypoglycemia) (SOE: Moderate; Metformin favored for severe hypoglycemia)

##### Metformin Versus DPP-4 Inhibitors

Six RCTs (reported in seven publications) compared metformin with DPP-4 inhibitors and reported on hypoglycemia.73, 82-87

Meta-analysis of the short-term, sufficiently-homogeneous RCTs favored DPP-4 inhibitors over metformin for symptomatic hypoglycemia (pooled OR, 0.52; 95% CI, 0.30 to 0.90) (Figure 55).73, 82, 83 Consistent with these findings, longer-term followup from two studies also revealed less hypoglycemia in the DPP-4 inhibitor arms compared with the metformin arms.85, 87 Of note, differences in hypoglycemia rates across the arms were not as clear when the definition of hypoglycemia required biochemical confirmation.73, 84

Figure 55 Pooled odds ratio of symptomatic hypoglycemia comparing metformin with DPP-4 inhibitors

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = dipeptidyl peptidase-4; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of symptomatic hypoglycemia comparing metformin with DPP-4 inhibitors.

Rates of severe hypoglycemia were low in the studies reporting on this outcome. Of four short RCTs (24 to 26 weeks), two reported no severe hypoglycemia in either arm.73, 84 One study reported a single event in the metformin arm and none in the DPP-4 inhibitor arm,86 and the other study reported two events in the DPP-4 inhibitor arm and did not report on severe hypoglycemia in the metformin arm.82 Of two RCTs with long-term followup (76 to 104 weeks), one reported no severe hypoglycemia events,87 and the other reported three events of severe hypoglycemia in the metformin monotherapy arms (n=2 for metformin 1000 mg and n=1 for metformin 2000 mg daily) and none in the DPP-4 inhibitor arm.85

Three of the six RCTs did not use an intention-to-treat approach, and withdrawals were high in all three of these studies,83-85 with two excluding data from persons initiating rescue therapy.83, 84 (SOE: Low; DPP-4 inhibitors favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

##### Metformin Versus SGLT-2 Inhibitors

Four RCTs (reported in three articles) compared metformin with SGLT-2 inhibitors and reported on total hypoglycemia.88, 89, 239 The meta-analysis favored SGLT-2 inhibitors versus metformin for any hypoglycemia, although the combined result was not statistically significant (Figure 56).

Figure 56 Pooled odds ratio of any hypoglycemia comparing metformin with SGLT-2 inhibitors

CI = confidence interval; Group 1 = metformin; Group 2 = sodium-glucose co-transporter-2; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of any hypoglycemia comparing metformin with SGLT-2 inhibitors.

In a 2013 RCT, Ferrannini et al.,90 an extension of one of the included studies239 with 78 weeks of followup found slightly higher rates of hypoglycemia in the metformin arm (3.6%) versus empagliflozin arms (10 mg, 0.9%; 25 mg, 1.8%); we did not include this study in the meta-analysis because of its longer duration.

Two studies reported no events of severe hypoglycemia.88 (SOE: Moderate; SGLT-2 inhibitors favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

##### Metformin Versus GLP-1 Receptor Agonists

Two of three RCTs compared metformin with GLP-1 receptor agonists (duration 26 to 52 weeks) and found a slightly higher risk of mild or moderate hypoglycemia for GLP-1 receptor agonists compared to metformin (Table 59).73, 91, 92 The third RCT reported similar risks across arms for this outcome. No study reported severe hypoglycemia events in either arm. (SOE: Low; Metformin favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

Table 59 Randomized controlled trials comparing metformin with GLP-1 receptor agonists on hypoglycemia

Author, Year | Followup (Weeks) | Metformin (Dose^*^) | GLP-1 Receptor Agonist (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin Vs GLP-1 Receptor Agonist)
Russell-Jones, 2012^73^ | 26 | Metformin (max 2500 mg) | Exenatide (fixed at 2.0 mg weekly) | Mild-moderate (signs or symptoms associated with BG < 3.0 mmol/L (either self-treated or resolved independently)) | 0/246 (0%) vs 5/248 (2.0%)
Russell-Jones, 2012^73^ | 26 | Metformin (max 2500 mg) | Exenatide (fixed at 2.0 mg weekly) | Severe^‡^ | 0/246 (0%) vs 0/248 (0%)
Russell-Jones, 2012^73^ | 26 | Metformin (max 2500 mg) | Exenatide (fixed at 2.0 mg weekly) | Total (signs or symptoms) | 10/246 (4.1%) vs 13/248 (5.2%)
Umpierrez, 2014^91^ | 52 | Metformin (max 2000 mg or ≥ 1500 mg depending on tolerability) | Dulaglutide (fixed at 0.75 mg weekly) | Total (signs or symptoms and/or PG ≤ 70 mg/dL [3.9 mmol/L]) | 34/268 (12.7%) vs 30/270 (11.1%)
Umpierrez, 2014^91^ | 52 | Metformin (max 2000 mg or ≥ 1500 mg depending on tolerability) | Dulaglutide (fixed at 0.75 mg weekly) | Severe (required third party assistance) | 0/268 (0%) vs 0/270 (0%)
Umpierrez, 2014^91^ | 52 | Metformin (max 2000 mg or ≥ 1500 mg depending on tolerability) | Dulaglutide (fixed at 1.5 mg weekly) | Total (signs or symptoms and/or PG ≤ 70 mg/dL [3.9 mmol/L]) | 34/268 (12.7%) vs 33/269 (12.3%)
Umpierrez, 2014^91^ | 52 | Metformin (max 2000 mg or ≥ 1500 mg depending on tolerability) | Dulaglutide (fixed at 1.5 mg weekly) | Severe (required third party assistance) | 0/268 (0%) vs 0/269 (0%)
Yuan, 2012^92^ | 26 | Metformin (max 2000 mg) | Exenatide (max 2.0 mg) | Mild (not specified) | 1/26 (3.8%) vs 4/33 (12.1%)
Yuan, 2012^92^ | 26 | Metformin (max 2000 mg) | Exenatide (max 2.0 mg) | Severe (required third party assistance or hospital treatment) | 0/26 (0%) vs 0/33 (0%)

BG = blood glucose; GLP-1 = glucagon-like peptide-1; max = maximum; mg = milligrams; mg/dL = milligram per deciliter; mmol/L = millimole per liter; PG = plasma glucose

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Severe hypoglycemia was defined as symptoms resulting in loss of consciousness or seizure that showed prompt recovery after glucose administration, or documented blood glucose less than 3.0 mmol/L that required the assistance of another person because of severe impairment in consciousness.

##### Thiazolidinediones Versus Sulfonylureas

Nine RCTs compared thiazolidinedione with sulfonylurea monotherapy and reported on hypoglycemia (Table 60).50, 60, 74, 94, 95, 100, 103, 217, 253

Table 60 Randomized controlled trials comparing thiazolidinediones with sulfonylureas on mild to moderate hypoglycemia

Author, Year Study Design | Followup (Weeks) | TZD (Dose^*^) | SU (Dose^*^) | Definition of Hypoglycemia | Results^†^ (TZD Vs SU)
Jain^‡^, 2006^95^ | 24 | Pioglitazone (max 45 mg) | Glyburide (max 15 mg) | 2 or more symptoms or BG < 60 mg/dL | 11/251 (4%) vs 61/251 (24%)
St. John Sutton^‡^, 2002^217^ | 52 | Rosiglitazone (max 8 mg) | Glyburide (max 20 mg) | Symptomatic | 0/104 (0%) vs 7/99 (7%)
Tan^‡^, 2004^100^ | 52 | Pioglitazone (max 45 mg) | Glibenclamide (max 10.5 mg) | Symptoms or BG < 50 mg/dL | 4/91 (4%) vs 32/109 (29%)
Hanefeld^‡^, 2007^94^ | 52 | Rosiglitazone (max 8 mg) | Glibenclamide (max 15 mg) | Not reported | 3/200 (2%) vs 25/207 (12%)
Kahn, 2006^50^ | 312 | Rosiglitazone (max 8 mg) | Glyburide (max 15 mg) | Self-reported | 142/1456 (10%) vs 557/1441 (39%)
Yamanouchi, 2005^60^ | 12 | Pioglitazone (30 mg for women and 45 mg for men) | Glimepiride (max 2 mg) | Not reported | 0/38 (0%) vs 1/37 (3%)
Agarwal, 2005^253^ | 16 | Pioglitazone | Glipizide | Not reported | 2 events among 22 patients vs 3 events among 22 patients
Shihara, 2011^103^ | 24 | Pioglitazone (mean 23.24 mg; max 30 mg for women and 45 mg for men) | Glimepiride (mean 1.51 mg; max 6 mg) | BG < 60 mg/dL | 5/96 (5%) vs 6/95 (6%)
Yoon^‡^, 2011^74^ | 48 | Rosiglitazone (mean 5.9 mg; max 8 mg) | Glimepiride (mean 4.5 mg; max 8 mg) | Symptomatic | 8/117 (7%) vs 23/118 (19%)

BG = blood glucose; mg = milligrams; mg/dL = milligrams per deciliter; SU = sulfonylurea; TZD = thiazolidinedione

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Included in meta-analysis.

Results from the meta-analysis of five sufficiently-homogeneous, short-term RCTs showed that the risk of total hypoglycemia was higher for sulfonylurea compared with thiazolidinedione monotherapy (pooled OR for sulfonylurea compared with thiazolidinedione monotherapy, 6.31; 95% CI, 4.08 to 9.76) (Figure 57). We did not find evidence of significant statistical heterogeneity, and removal of any one study did not change the overall inference.

Figure 57 Pooled odds ratio of any hypoglycemia comparing thiazolidinediones with sulfonylureas

CI = confidence interval; Group 1 = thiazolidinediones; Group 2 = sulfonylureas; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of any hypoglycemia comparing thiazolidinediones with sulfonylureas.

We did not include one short-term (16 weeks) study in the meta-analysis, because it reported on the number of events and not the number of participants experiencing events; this study reported two events of hypoglycemia in the thiazolidinedione arm and three events in the sulfonylurea arm.253 We excluded another short-term (24 weeks) RCT from the meta-analysis, because its mean daily dose of glimepiride (1.5 mg/day) was much lower than the dosing of sulfonylureas in the other studies included in the meta-analysis. This study still found higher rates of hypoglycemia (blood glucose < 60 mg/dL) in the sulfonylurea (7/95, 7.4%) than thiazolidinedione (5/96, 5.2%) arm.103

The longer study, ADOPT, also found higher rates of total hypoglycemia for the sulfonylurea arm (557/1441, 38.7%) compared with the thiazolidinedione arm (142/1456, 9.8%). This study also found more severe hypoglycemia in the sulfonylurea arm (8/1441, 0.6%) compared with the thiazolidinedione arm (1/1456, 0.1%). One of the short-term studies reported that two participants experienced severe hypoglycemia in the sulfonylurea arm but did not report on this outcome for the thiazolidinedione arm.94 (SOE: High; Thiazolidinediones favored for mild, moderate, or total hypoglycemia) (SOE: Moderate; Thiazolidinediones favored for severe hypoglycemia)

##### Thiazolidinediones Versus DPP-4 Inhibitors

Three short-term studies evaluated hypoglycemia for the comparison of thiazolidinediones to DPP-4 inhibitors (Table 61).48, 73, 104 Of two studies reporting on total hypoglycemia, rates were similar in one study and higher in the pioglitazone versus the sitagliptin arm in the other.48, 73 Two studies reported on severe hypoglycemia and observed no events.73, 104 (SOE: Insufficient for total hypoglycemia; Low: Neither favored for severe hypoglycemia)

Table 61 Randomized controlled trials comparing thiazolidinediones with DPP-4 inhibitors on hypoglycemia

Author, Year | Followup (Weeks) | TZD (Dose^*^) | DPP-4 Inhibitor (Dose^*^) | Definition of Hypoglycemia | Results^†^ (TZD Vs DPP-4 Inhibitor)
Alba, 2013^48^ | 12 | Pioglitazone (fixed at 30 mg) | Sitagliptin (fixed at 100 mg) | Total (all reports of hypoglycemia; no glucose measurement required) | 2/54 (3.7%) vs 0/52 (0%)
Rosenstock, 2010^104^ | 26 | Pioglitazone (fixed at 30mg) | Alogliptin (fixed at 25 mg) | Severe (required third party assistance) | 0/163 (0%) vs 0/164 (0%)
Russell-Jones, 2012^73^ | 26 | Pioglitazone (max 45 mg) | Sitagliptin (fixed at 100 mg) | Total (signs or symptoms) | 6/163 (3.7%) vs 5/163 (3.1%)
Russell-Jones, 2012^73^ | 26 | Pioglitazone (max 45 mg) | Sitagliptin (fixed at 100 mg) | Severe^‡^ | 0/163 (0%) vs 0/163 (0%)

DPP-4 = dipeptidyl peptidase-4; mg = milligrams; TZD = thiazolidinedione

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Severe hypoglycemia was defined as symptoms resulting in loss of consciousness or seizure that showed prompt recovery after glucose administration, or documented blood glucose less than 3.0 mmol/L that required the assistance of another person because of severe impairment in consciousness.

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

Two RCTs (26 and 48 weeks in duration) found higher rates of non-severe hypoglycemia for exenatide compared to pioglitazone but no difference in severe hypoglycemia (no events) across arms.73, 105 In the 26-week trial 0/163 (0%) experienced mild hypoglycemia in the pioglitazone arm versus 5/248 (2%) in the exenatide arm.73 In the 48-week trial, corresponding event (symptoms with blood glucose <3.9 mmol/l [<70 mg/dl]) rates were 13/142 (9.2%) and 5/136 (3.7%) in the exenatide and pioglitazone arms, respectively.105 (SOE: Low; Thiazolidinediones favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

##### Sulfonylureas Versus DPP-4 Inhibitors

Comparisons for both mild and severe hypoglycemia favored the DPP-4 inhibitor arms over sulfonylureas (for mild, moderate, or total hypoglycemia for SU vs. DPP-4 inhibitors: range in OR 3.8 to 12.4; range in RD 6% to 15%). Four RCTs examined hypoglycemia with this comparison; differences in followup length and definitions of hypoglycemia precluded a meta-analysis (Table 62). (SOE: Moderate; DPP-4 inhibitors favored for mild, moderate, or total hypoglycemia) (SOE: Low; DPP-4 inhibitors favored for severe hypoglycemia)

Table 62 Randomized controlled trials comparing sulfonylureas with DPP-4 inhibitors on hypoglycemia

Author, Year | Followup (Weeks) | SU (Dose^*^) | DPP-4 Inhibitor (Dose^*^) | Definition of Hypoglycemia | Results^†^ (SU Vs DPP-4 Inhibitor)
Arjona Ferreira, 2013^107^ | 58 | Glipizide (max 20 mg; mean 7.7 mg) | Sitagliptin (fixed at 50 mg for those with moderate renal insufficiency and 25 mg for those with severe renal insufficiency) | Severe (required third party assistance or medical intervention or exhibited markedly depressed level of consciousness, loss of consciousness, or seizure) | 6/212 (2.8%) vs 3/210 (1.4%)
Arjona Ferreira, 2013^107^ | 58 | Glipizide (max 20 mg; mean 7.7 mg) | Sitagliptin (fixed at 50 mg for those with moderate renal insufficiency and 25 mg for those with severe renal insufficiency) | Total (signs and/or symptoms) | 36/212 (17%) vs 13/210 (6.2%); P < 0.001
Gupta, 2013^260^ | 24 | Glimepiride (max 4 mg) | Sitagliptin (max 200 mg) | Total (not specified) | 11 episodes among 71 patients vs 3 episodes among 77 patients
Barnett, 2012^106^ | 34 | Glimepiride (max 4 mg) | Linagliptin (fixed at 5 mg) | Mild-moderate (Symptoms and/or PG ≤ 70 mg/dL [3.9 mmol/]) | 5/64 (7.8%) vs 3/137 (2.2%)
Barnett, 2012^106^ | 34 | Glimepiride (max 4 mg) | Linagliptin (fixed at 5 mg) | Severe (required third party assistance) | 0/64 (0%) vs 0/137 (0%)
Scott, 2007^108^ | 12 | Glipizide (max 20 mg) | Sitagliptin (fixed at 25 mg) | Total (self-report and glucose measurements) | 21/123 (17.1%) vs 5/123 (4.1%)
Scott, 2007^108^ | 12 | Glipizide (max 20 mg) | Sitagliptin (fixed at 50 mg) | Total (self-report and glucose measurements) | 21/123 (17.1%) vs 5/123 (4.1%)
Scott, 2007^108^ | 12 | Glipizide (max 20 mg) | Sitagliptin (fixed at 100 mg) | Total (self-report and glucose measurements) | 21/123 (17.1%) vs 2/122 (1.6%)

DPP-4 = dipeptidyl peptidase-4; max = maximum; mg = milligrams; mg/dL = milligrams per deciliter; mmol/L = millimole per liter; PG = plasma glucose; SU = sulfonylurea

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Sulfonylureas had greater risk of mild to moderate hypoglycemia compared with GLP-1 receptor agonists (range in OR 3.1 to 5.3; range in RD 12% to 21%) (Table 63). Five studies assessed this outcome and could not be pooled because of heterogeneity in outcome definitions and followup length. No study reported any events of severe hypoglycemia. (SOE: Moderate; GLP-1 receptor agonists favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

Table 63 Randomized controlled trials comparing sulfonylureas with GLP-1 receptor agonists on hypoglycemia

Author, Year | Followup (Weeks) | SU (Dose^*^) | GLP-1 Receptor Agonist (Dose^*^) | Definition of Hypoglycemia | Results^†^ (SU Vs GLP-1 Receptor Agonist)
Garber, 2011^113^ | 104 | Glimepiride (max 8mg) | Liraglutide (max 1.2 mg) | Mild-moderate (did not require assistance, BG < 56 mg/dL [3.1 mmol/L]) | 64/248 (25.8%) vs 30/251 (12%)
Garber, 2011^113^ | 104 | Glimepiride (max 8mg) | Liraglutide (max 1.2 mg) | Severe (required third-party assistance) | 0/248 (0%) vs 0/251 (0%)
Garber, 2011^113^ | 104 | Glimepiride (max 8 mg) | Liraglutide (max 1.8 mg) | Mild-moderate (did not require assistance, BG < 56 mg/dL [3.1 mmol/L]) | 64/248 (25.8%) vs 25/247 (10.1%)
Garber, 2011^113^ | 104 | Glimepiride (max 8 mg) | Liraglutide (max 1.8 mg) | Severe (required third-party assistance) | 0/248 (0%) vs 1/247 (0.4%)^‡^
Kaku, 2011^110^ | 52 | Glibenclamide (fixed at 1.25 -2.5 mg) | Liraglutide (max 0.9 mg) | Mild-moderate (self-treated) | 1.10 events per patient-year vs 0.19 events per patient-year
Kaku, 2011^110^ | 52 | Glibenclamide (fixed at 1.25 -2.5 mg) | Liraglutide (max 0.9 mg) | Severe (required third party assistance) | 0/132 (0%) vs 0/268 (0%)
Madsbad, 2004^111^ | 12 | Glimepiride (max 4 mg) | Liraglutide (Fixed (0.60 mg)) | Mild-moderate (BG < 2.8 mmol/L) | 4/26 (15.4%) vs 1/30 (3.3%)
Madsbad, 2004^111^ | 12 | Glimepiride (max 4 mg) | Liraglutide (Fixed (0.75 mg)) | Mild-moderate (BG < 2.8 mmol/L) | 4/26 (15.4%) vs 0/28 (0%)
Seino, 2010^109^ | 24 | Glibenclamide (max 2.5 mg) | Liraglutide (max 0.9 mg) | Mild-moderate (symptoms) | 45/132 (34.1%) vs 36/268 (13.4%)
Seino, 2010^109^ | 24 | Glibenclamide (max 2.5 mg) | Liraglutide (max 0.9 mg) | Mild-moderate (symptoms and BG < 3.1 mmol/L) | 29/132 (22%) vs 22/268 (8.2%)
Seino, 2010^109^ | 24 | Glibenclamide (max 2.5 mg) | Liraglutide (max 0.9 mg) | Severe (required third party assistance) | 0/132 (0%) vs 0/268 (0%)

BG = blood glucose; GLP-1 = glucagon-like peptide-1; max = maximum; mg = milligrams; mg/dL = milligrams per deciliter; mmol/L = millimole per liter; SU = sulfonylurea

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Event in the context of insulin infusion as part of a “sub-study” procedure.

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

One study assessed hypoglycemia for the comparison of DPP-4 inhibitors versus SGLT-2 inhibitors.114 The study compared sitagliptin with empagliflozin at 24 weeks, with one of 223 patients (<1%) in the sitagliptin arm with any hypoglycemia, one of 224 patients (<1%) in the 10 mg empagliflozin arm, and one of 223 patients (<1%) in the 25 mg empagliflozin arm. No patients experienced severe hypoglycemia. (SOE: Low; Neither favored for mild, moderate, or total hypoglycemia)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

One 26-week RCT assessed hypoglycemia for the comparison of DPP-4 inhibitors versus GLP-1 receptor agonists.73 Investigators compared sitagliptin with exenatide at 26 weeks. Total hypoglycemia was slightly higher for the GLP-1 receptor agonist arm: 13/248 (5.2%) patients in the exenatide arm vs. 5/163 (3.1%) in the sitagliptin arm. Mild hypoglycemia was also higher in the exenatide (5/248, 2.0%) than the sitagliptin arm (0/163, 0%). No patients had severe hypoglycemia in either arm. (SOE: Low; DPP-4 inhibitors favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

More patients experienced hypoglycemia in the combination arm than in the metformin-alone arm. We combined eight sufficiently-homogeneous, short-term RCTs and found an increased odds of mild or moderate hypoglycemia for metformin plus thiazolidinedione versus metformin alone (pooled OR, 1.56; 95% CI, 0.99 to 2.44) (Figure 58).59, 117-120, 122, 123, 247 We did not find statistical heterogeneity.

Figure 58 Pooled odds ratio of any hypoglycemia comparing metformin with combination of metformin plus a thiazolidinedione

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus thiazolidinedione; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of any hypoglycemia comparing metformin with combination of metformin plus a thiazolidinedione.

We excluded one RCT from this meta-analysis because its longer followup. This study compared metformin (titrated to a maximum of 2000 mg daily) with metformin plus rosiglitazone (titrated to a maximum of 8 mg/2000 mg daily) at 80 weeks and reported 10 total hypoglycemia events in the metformin-alone arm (3% of patients), and 20 hypoglycemia events in the metformin-rosiglitazone arm (6% of patients).127 These results were consistent with our findings reported above. Another study was excluded from the meta-analysis because of its low-dose combination arm. The study compared metformin (fixed at 1700 mg daily) with a lower-dose combination arm [metformin (fixed at 500 mg daily) and rosiglitazone (fixed at 4 mg daily)] and reported no hypoglycemia in either arm at 24 weeks.124 (SOE: High, Metformin favored for mild, moderate, or total hypoglycemia)

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

Ten RCTs compared metformin with the combination of metformin plus a sulfonylurea and found more mild, moderate, and total hypoglycemia in the combination arms compared with monotherapy arms.128, 129, 131, 132, 136-141 We did not pool these studies because of differences in definitions of hypoglycemia and dosing of medications; individual study characteristics are shown in Figure 59 and Table 64. Rates of hypoglycemia did not appear higher with glyburide than with any other sulfonylurea. Only two studies reported on severe hypoglycemia and did not report any events.140, 141 (SOE: Moderate; Metformin favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

Figure 59 Odds ratios for studies evaluating mild or moderate hypoglycemia comparing metformin with combination of metformin plus a sulfonylurea

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus sulfonylurea; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratios for studies evaluating mild or moderate hypoglycemia comparing metformin with combination of metformin plus a sulfonylurea.

Table 64 Additional randomized controlled trials comparing metformin with a combination of metformin plus a sulfonylurea on hypoglycemia

Author, Year | Followup (Weeks) | Metformin (Dose in mg^*^) | Metformin + SU (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin Vs SU)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500) | Metformin (fixed at ≥ 1500) + glimepiride (max 4) | Mild-moderate (Asymptomatic, but BG ≤ 3.9 mmol/L) | 1/101 (1.0%) vs 3/307 (1.0%)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500) | Metformin (fixed at ≥ 1500) + glimepiride (max 4) | Mild-moderate (Symptomatic and BG ≤ 3.9 mmol/L) | 4/101 (4.0%) vs 55/307 (17.9%)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500) | Metformin (fixed at ≥ 1500) + glimepiride (max 4) | Severe (required third party assistance) | 0/101 (0%) vs 0/307 (0%)
Kim, 2014^140^ | 26 | Metformin (max 2500) | Metformin (max 2000) + glimepiride (fixed at 1-8) | Total (symptomatic) | 4/108 (3.7%) vs 39/100 (0.4%)
Kim, 2014^140^ | 26 | Metformin (max 2500) | Metformin (max 2000) + glimepiride (fixed at 1-8) | Severe (not specified) | 0/108 (0%) vs 0/100 (0%)
Forst, 2010^139^ | 12 | Metformin (fixed) | Metformin (fixed) + glimepiride (max 3) | Total (not specified) | 0/71 (0%) vs 3/65 (4.6%)
DeFronzo, 1995^137^ | 29 | Metformin (max 2500) | Metformin (max 2500) + glyburide (max 20) | Not reported | 4/210 (2%) vs 38/213 (18%)
Charpentier, 2001^136^ | 20 | Metformin (fixed at 2550) | Metformin (fixed at 2550) + glimepiride (max 6) | Symptomatic | 8/75 (11%) vs 30/147 (20%)
Marre, 2002^132^ | 16 | Metformin (max 2000) | Metformin (max 2000) + glibenclamide (max 10) | Symptoms or labs | 0/104 (0%) vs 12/103 (12%)
Blonde, 2002^131^ | 16 | Metformin (max 2000) | Metformin (max 2000) + glyburide (max 20) | FSG<=60mg/dl + symptomatic | 1/153 (1%) vs 22/162 (14%)
Garber, 2003^129^ | 16 | Metformin (max 2000) | Metformin (max 1000 mg) + glyburide (max 5) | Symptoms suggesting hypoglycemia | 29/164 (18%) vs 59/171 (35%)
Feinglos, 2005^128^ | 16 | Metformin (fixed at ≥ 1000) | Metformin (fixed at ≥ 1000 mg) + glipizide (fixed at 2.5) | FSG <60 mg/dl with symptoms or FSG <50 mg/dl without symptoms or FBG<55 mg/dl without symptoms | 2/56 (4%) vs 9/56 (16%)
Chien, 2007^138^ | 16 | Metformin (max 2000) | Metformin (max 2000 mg) + glyburide (max 20) | Symptomatic or BG < 60 mg/dL | 0/25 (0%) vs. 0/26 (0%)

BG = blood glucose; FBG = fasting blood glucose; FSG = fingerstick glucose; max = maximum; mg = milligrams; mmol/L = millimole per liter; SU = sulfonylurea

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

We included 27 studies (31 publications) for the comparison of metformin and combination of metformin plus a DPP-4 inhibitor for hypoglycemia.51, 80, 81, 83-87, 118, 139, 141-156, 159-162, 164, 261 Six RCTs were from the 2010 report,80, 81, 83, 142-144, 261 with two RCTs being published extensions of those prior studies.85, 87 We identified 21 new studies for this report. Overall, mild, moderate, total, or severe hypoglycemia were similar for metformin versus the combination of metformin plus a DPP-4 inhibitor.

###### Mild or Moderate Hypoglycemia

One long-term RCT reported mild hypoglycemia in 1% of patients in the metformin arm compared with 1.3% of patients in the metformin plus sitagliptin arm at 104 weeks.141 Fourteen short-term studies reported on mild or moderate hypoglycemia (Figure 60).80, 83, 84, 86, 118, 142-144, 147, 148, 151, 152, 155, 261 The pooled odds ratio for mild or moderate hypoglycemia across these studies suggested similar risk of hypoglycemia for the combination of metformin plus a DPP-4 inhibitor compared to metformin (pooled OR, 0.97; 95% CI, 0.63 to 1.51). We did not identify significant statistical heterogeneity, and removal of any single study did not affect the overall inference of no difference in hypoglycemia risk across treatments.

Figure 60 Pooled odds ratio of mild or moderate hypoglycemia comparing metformin with combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of mild or moderate hypoglycemia comparing metformin with combination of metformin plus a DPP-4 inhibitor.

Another short-term RCT reported mild hypoglycemia events per person year and found a higher rate of events (4.8 events per person-year) in the metformin arm compared with the metformin plus sitagliptin arm (0.1 events per person-year) at 26 weeks.159

###### Severe Hypoglycemia

Thirteen RCTs reported on severe hypoglycemia for this comparison.51, 86, 144, 145, 148, 151, 152, 155, 156, 160, 261 Few events of severe hypoglycemia were reported with 10 of 13 studies reporting no events (Figure 61).

Figure 61 Pooled odds ratio of severe hypoglycemia comparing metformin with combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of severe hypoglycemia comparing metformin with combination of metformin plus a DPP-4 inhibitor.

###### Total Hypoglycemia

Eleven studies reported on total hypoglycemia events with short term (<52 week) followup.139, 145, 147-150, 153, 156, 160-162, 164 The pooled odds ratio for metformin vs. metformin plus a DPP-4 inhibitor was 0.96 (95% CI, 0.55, 1.67), suggesting similar risk of total hypoglycemia for metformin and the combination of metformin plus a DPP-4 inhibitor (Figure 62). We did not find evidence of significant statistical heterogeneity, and the exclusion of a single study did not change the inference. Three studies shown in Figure 62 did not contribute to the pooled OR because no events occurred in either arm.139, 149, 150

Figure 62 Pooled odds ratio of any hypoglycemia comparing metformin with combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of any hypoglycemia comparing metformin with combination of metformin plus a DPP-4 inhibitor.

One study had longer follow up (76 weeks) and reported 20 events in the metformin arm (6.1%) compared with 15 in the metformin plus saxagliptin arm (4.7%) at 76 weeks.87 (SOE: High; Neither favored for mild, moderate, or total hypoglycemia) (SOE: Moderate; Neither favored for severe hypoglycemia)

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Seven short-term studies (published in six articles) reported on total hypoglycemia.88, 153, 156, 165, 166, 168 Meta-analysis of these studies demonstrated a weighted pooled odds ratio for metformin plus an SGLT-2 inhibitor vs. metformin of 1.74 (95% CI, 0.83, 3.66), suggesting a possible increased risk of total hypoglycemia for the combination treatment (Figure 63).

Figure 63 Pooled odds ratio of any hypoglycemia comparing metformin with combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of any hypoglycemia comparing metformin with combination of metformin plus a SGLT-2 inhibitor.

Another study reported on total hypoglycemia with 78 weeks of followup and reported higher rates of total hypoglycemia in the metformin compared to metformin plus SGLT-2 inhibitor arm: two patients of 56 in the metformin arm (3.6%), three patients of 166 (1.8%) in the arm receiving 10 mg of empagliflozin, and four patients of 166 (2.4%) in the arm receiving 25 mg of empagliflozin.90 Mean metformin dose was not reported in this study, and the article states that participants were on their pre-enrollment dose of metformin (1500 mg or greater or maximum tolerated dose) during the study.90

One long-term RCT (102 weeks) study reported on mild hypoglycemia events and reported four events in both the metformin arm (4.4%) and the metformin plus dapagliflozin combination arm (4.4%).169

Six short-term studies (published in five articles) reported on severe hypoglycemia events with followup of less than 1 year (range 12 to 24 weeks), and none of these studies reported any severe events.88, 156, 165, 166, 168 One study with more 102 weeks of followup reported no severe hypoglycemic events.170 (SOE: Moderate; Metformin favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Four studies compared metformin with a combination of metformin plus a GLP-1 receptor agonist,141, 159, 171, 174 and reported on hypoglycemia (Table 65). The single long-term (104-week) study showed no severe hypoglycemia in either arm and did not find a clinically-significant difference in mild-moderate hypoglycemia between arms; this study had large losses to followup and did not use an intention-to-treat approach to analysis.141

Table 65 Randomized controlled trials comparing metformin with a combination of metformin plus a GLP-1 receptor agonist on hypoglycemia

Author, Year | Followup (Weeks) | Metformin (Dose^*^) | Metformin + GLP-1 Receptor Agonist (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin Vs Metformin + GLP-1 Receptor Agonist)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + albiglutide (max 50 mg weekly) | Mild-moderate (Asymptomatic, but PG ≤ 3.9 mmol/L) | 1/101 (1%) vs 4/302 (1.3%)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + albiglutide (max 50 mg weekly) | Mild-moderate (Symptomatic and PG ≤ 3.9 mmol/L) | 4/101 (4.0%) vs 9/302 (3.0%)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + albiglutide (max 50 mg weekly) | Severe (required third party assistance) | 0/101 (0%) vs 0/302 (0%)
Nauck, 2014^159^ | 26 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed at 0.75 mg/week) | Mild-moderate (Signs and symptoms and/or PG ≤ 70 mg/dL [3.9 mmol/L]) | 2/177 (1.1%)^‡^ vs 16/302 (5.3%)
Nauck, 2014^159^ | 26 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed at 0.75 mg/week) | Severe (required third party assistance) | 0/177 (0%)^‡^ vs 0/302 (0%)
Nauck, 2014^159^ | 26 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed at 1.5 mg/week) | Mild-moderate (Signs and symptoms and/or PG ≤ 70 mg/dL [3.9 mmol/L]) | 2/177 (1.1%)^‡^ vs 31/304 (10.2%)
Nauck, 2014^159^ | 26 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed at 1.5 mg/week) | Severe (required third party assistance) | 0/177 (0%)^‡^ vs 0/304 (0%)
Derosa, 2013^171^ | 48 | Metformin (mean 2500 mg) | Metformin (mean 2500 mg) + exenatide (max 20 mcg) | Total (FPG < 60 mg/dL) | 0/85 (0%) vs 0/86 (0%)
DeFronzo, 2005^174^ | 30 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + exenatide 10 mcg | Symptoms (with or without PG <60 mg/dl [3.3 mmol/l]) | 6/113 (5.3%) vs. 5/110 (4.5%)
DeFronzo, 2005^174^ | 30 | Metformin (fixed at ≥ 1500 mg) | Metformin (fixed at ≥ 1500 mg) + exenatide 20 mcg | Symptoms (with or without PG <3.3 mmol/l) | 6/113 (5.3%) vs. 6/110 (5.3%)

FPG = fasting plasma glucose; GLP-1 = glucagon-like peptide-1; mcg = micrograms; mg = milligrams; mg/dL = milligrams per deciliter; mmol/L = millimole per liter; PG = plasma glucose; vs = versus

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Although study had 52 weeks of followup, incidence of hypoglycemia was only available at 26 weeks. In the trial, patients were switched from a combination of metformin and placebo to a combination of metformin and sitagliptin.

Two of three shorter studies (26 to 48 weeks) showed no difference in non-severe hypoglycemia for the metformin and combination arms, but definitions of hypoglycemia varied across these three studies.159, 171, 174 The study suggesting an increased risk of hypoglycemia in the metformin plus GLP-1 receptor agonist arms versus metformin had large losses to followup across its arms. No severe hypoglycemia events were reported in this study, which was the only short-term study reporting on this outcome.159 (SOE: Low; Neither favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Six short-duration RCTs reporting on mild or moderate hypoglycemia compared the combination of metformin plus a thiazolidinedione with metformin plus a sulfonylurea, showing higher risk of hypoglycemia in the metformin plus sulfonylurea arm (pooled OR, 7.5; 95% CI, 4.0 to 13.8) (Figure 64).175, 177, 178, 180, 183, 185 The trial by Hamann et al. was designed so that patients were withdrawn from the study if they did not reach an efficacy target after 8 weeks of treatment.175 The rates of hypoglycemia were high as medications were titrated up to efficacy, although the relative odds of hypoglycemia in the two arms were comparable to the other studies. No single study strongly influenced the results of the meta-analysis, and no substantial heterogeneity was identified.

Figure 64 Pooled odds ratio of any hypoglycemia comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea

CI = confidence interval; Group 1 = combination of metformin plus thiazolidinedione; Group 2 = combination of metformin plus a sulfonylurea; Met = metformin; OR = odds ratio; SU = sulfonylurea; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of any hypoglycemia comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea.

One study reported on severe hypoglycemia, showing results consistent with the mild to moderate hypoglycemia outcome.180 In Garber et al., seven of 159 patients had severe hypoglycemic events in the metformin plus sulfonylurea arm, and none did in the metformin plus thiazolidinedione arm.180 This study included patients with high baseline HbA1c and had a higher proportion of Asian patients than most studies (12% Asian). (SOE: High; Combination of metformin plus a thiazolidinedione favored for mild, moderate, or total hypoglycemia) (SOE: Low; Combination of metformin plus a thiazolidinedione favored for severe hypoglycemia)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Three studies (two RCTs and one observational study) compared the combination of metformin plus a thiazolidinedione with metformin plus a DPP-4 inhibitor, showing no clear differences between-groups in hypoglycemia risk.186, 188, 262 One low-quality study randomized 56 patients to metformin and rosiglitazone and 56 patients to metformin and sitagliptin. One patient in the rosiglitazone group withdrew for hypoglycemia, but it is not clearly reported how many in each group experienced hypoglycemia.186 One study compared mild hypoglycemia in a metformin plus pioglitazone arm with a metformin plus sitagliptin arm at 26 weeks.188 There was one patient with an event in the metformin plus pioglitazone arm and five patients with events in the metformin plus sitagliptin arm. This study also evaluated severe hypoglycemia, finding no events in either arm. A prospective cohort study also assessed severe hypoglycemia; no patients with these events were recorded.262 (SOE: Low; Neither favored for mild, moderate, or total hypoglycemia) (SOE: Moderate; Neither favored for severe hypoglycemia)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two short RCTs compared metformin plus a thiazolidinedione with metformin plus a GLP-1 receptor agonist, showing few differences between-group in hypoglycemia risk. The first 20-week study randomized 45 patients to metformin and rosiglitazone and 45 patients to metformin and exenatide, at comparable doses.189 No patients receiving metformin plus rosiglitazone reported hypoglycemia, and two patients receiving metformin plus exenatide reported hypoglycemia, although this difference was not statistically significant.189 There were no severe hypoglycemic events in this study. The second 26-week study randomized 325 patients to either metformin and pioglitazone or metformin and exenatide, at comparable doses.188 The study reported one patient with mild hypoglycemia in the metformin plus pioglitazone arm and two patients with mild hypoglycemia in the metformin plus exenatide arm. The study also reported that no patients had severe hypoglycemia in either arm. (SOE: Low; Neither favored for mild, moderate, total, or severe hypoglycemia)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Eleven studies of the comparison of a combination of metformin plus a sulfonylurea versus a combination of metformin plus a DPP-4 inhibitor found more patients with severe and non-severe hypoglycemia in the metformin plus sulfonylurea arms compared with the metformin plus DPP-4 inhibitor arms (Figure 65).139, 141, 190-197, 263

Figure 65 Pooled odds ratio of hypoglycemia comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration and severity of hypoglycemia

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; Met = metformin; OR = odds ratio; SU – sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

* The profile likelihood estimate provided a similar result.

Pooled odds ratio of hypoglycemia comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor, stratified by study duration and severity of hypoglycemia.

Five studies, each lasting 2 years, reported on the outcome of severe hypoglycemia, favoring metformin plus a DPP-4 inhibitor over metformin plus a sulfonylurea (pooled OR, 0.09; 95% CI, 0.03 to 0.26).141, 194-197 Similarly, three studies, each lasting less than 1 year, reported on the outcome of severe hypoglycemia, favoring metformin plus a DPP-4 inhibitor over metformin plus a sulfonylurea (pooled OR, 0.16; 95% CI, 0.05 to 0.56).190-192 The range in RD for severe hypoglycemia in the shorter and longer studies was 0% to 3%.

Four additional studies were pooled for a meta-analysis of hypoglycemia (defined as mild, moderate, or total) with followup of 12 to 52 weeks. The pooled odds ratio was 0.19 (95% CI, 0.10 to 0.36), favoring metformin plus a DPP-4 inhibitor.139, 190, 193, 263 Four longer studies, each with followup of 2 years, reported on mild, moderate, or total hypoglycemia, with all four studies reporting significantly less hypoglycemia in the metformin plus DPP-4 inhibitor arms compared with the metformin plus sulfonylurea arms (pooled OR, 0.07; 95% CI, 0.04 to 0.14).141, 194, 195, 197 For all meta-analyses, no single study markedly influenced the results. Only one meta-analysis had substantial heterogeneity, yet the point estimates were fairly similar among these studies. (SOE: High; Combination of metformin plus a DPP-4 inhibitor favored for mild, moderate, total, or severe hypoglycemia in shorter studies (<1 year) and longer studies (lasting 2 years)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

For the combined outcome of mild or total hypoglycemia, and for severe hypoglycemia, the comparison of a combination of metformin plus a sulfonylurea versus a combination of metformin plus a SGLT-2 inhibitor favored the metformin plus SGLT-2 inhibitor combinations over the combination of metformin plus a sulfonylurea.

Three 2-year studies were pooled, assessing mild or total hypoglycemia for this comparison.199-201 The weighted odds ratio was 0.08 (95% CI, 0.03 to 0.17), favoring metformin plus SGLT-2 inhibitor combinations. There was substantial heterogeneity for this meta-analysis (I-squared, 83%); however, point estimates were fairly similar among the trials (Figure 66). Two of the three studies used equipotent drug dosing between the treatment arms.199, 201 One study mildly underdosed the metformin plus sulfonylurea arm (mean glimepiride dose of 2.7 mg) in comparison with the SGLT-2 inhibitor arm.200 No single study strongly influenced the meta-analysis results. Two of these studies reported hypoglycemia in shorter (52-week) and longer (208-week) studies with similar findings favoring the metformin plus SGLT-2 inhibitor comparison.54, 198

Figure 66 Pooled odds ratio of mild or moderate hypoglycemia comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor^*^ * The profile likelihood estimate provided a similar result.

CI = confidence interval; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; Met = metformin; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of mild or moderate hypoglycemia comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor

Two of these trials also assessed severe hypoglycemia for this comparison (range in RD 1% to 3%).198, 199 As above, the combination of metformin plus a SGLT-2 inhibitor was favored in both studies. The first RCT assessed severe hypoglycemia at 52 weeks in 965 randomized patients.198 There were 15 patients with a severe hypoglycemic event in the metformin plus sulfonylurea arm and two patients in the metformin plus SGLT-2 inhibitor arm. The second RCT assessed severe hypoglycemia at 104 weeks in 814 randomized patients.199 Severe hypoglycemic events were reported in 7 percent of patients in the metformin plus sulfonylurea arm and 1.7 percent of patients in the metformin plus SGLT-2 inhibitor arm. In two extension studies, lasting 2 and 4 years, the findings were similar, favoring the combination of metformin plus a SGLT-2 inhibitor.54, 201 (SOE: High; Combination of metformin plus a SGLT-2 inhibitor favored for mild, moderate, or total hypoglycemia) (SOE: Moderate; Combination of metformin plus a SGLT-2 inhibitor favored for severe hypoglycemia)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three RCTs compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a GLP-1 receptor agonist, showing a lower risk of total/mild/moderate hypoglycemia with the combination of metformin plus a GLP-1 receptor agonist (range in RD -15% to -30%) and no clear between-group differences in severe hypoglycemia risk (Figure 67).53, 141, 204 No meta-analysis could be conducted for this comparison because of differences in study duration and hypoglycemia definitions. In all studies, glimepiride was the sulfonylurea given in combination with metformin. (SOE: Moderate; Combination of metformin plus a GLP-1 receptor agonist favored for mild, moderate, or total hypoglycemia) (SOE: Low, Neither favored for severe hypoglycemia)

Figure 67 Odds ratio of hypoglycemia comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a GLP-1 receptor agonist, stratified by study duration and severity of hypoglycemia

CI = confidence interval; GLP-1 = glucagon-like peptide-1; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = combination of metformin plus a glucagon-like peptide-1 agonist; Met = metformin; OR = odds ratio; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Odds ratio of hypoglycemia comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a GLP-1 receptor agonist, stratified by study duration and severity of hypoglycemia.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Basal Insulin

One study addressed the comparison of a combination of metformin plus a sulfonylurea versus a combination of metformin plus a basal insulin, favoring metformin and insulin glargine. This 48-week RCT compared metformin and glimepiride with metformin and insulin glargine.206 While patients continued on the same pre-study dose of metformin of around 1500 mg, both the sulfonylurea and the insulin glargine were titrated to reach blood sugar targets. Nineteen patients of 30 (63%) in the metformin plus glimepiride arm had mild hypoglycemia compared with 10 of 34 (29%) in the metformin plus insulin glargine arm. No severe hypoglycemia events occurred in either treatment arm. (SOE: Low; Combination of metformin plus basal insulin favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither arm favored for severe hypoglycemia)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a Premixed Insulin

Two RCTs compared metformin plus sulfonylurea with metformin plus a premixed insulin, showing no clear between-group differences in hypoglycemia risk (Table 66).207, 208 (SOE: Low; Neither favored for mild, moderate, or total hypoglycemia) (SOE: Insufficient for severe hypoglycemia)

Table 66 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a premixed insulin on hypoglycemia

Author, Year | Followup | Comparison | Outcome | Results
Malone, 2003^207^ | 16 weeks | Metformin + glargine versus metformin + lispro 75/25 | Nocturnal | (N = 597 in trial) Greater number of participants with nocturnal hypoglycemia (p < 0.01) with metformin plus sulfonylurea than metformin plus insulin
Malone, 2003^207^ | 16 weeks | Metformin + glargine versus metformin + lispro 75/25 | Severe | Comparable number with severe hypoglycemia (p=0.10)
Kvapil, 2006^208^ | 16 weeks | Metformin + glibenclamide versus metformin + aspart 70/30 | Mild or moderate | 9/114 versus 13/108; RR = 1.5 (95% CI, 0.7 to 3.4)

CI = confidence interval; RR = relative risk

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Five studies considered hypoglycemia for the comparison of a combination of metformin plus a DPP-4 inhibitor versus a combination of metformin plus a SGLT-2 inhibitor, showing no clear between-group differences in hypoglycemia risk (Figure 68). Four RCTs, with equipotent doses in each arm, showed no significant between-group differences in severe hypoglycemia risk.156, 158, 209

Figure 68 Odds ratio of hypoglycemia comparing a combination of metformin plus an SGLT-2 inhibitor with a combination of metformin plus a DPP-4 inhibitor, stratified by severity of hypoglycemia

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; Met = metformin; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Odds ratio of hypoglycemia comparing a combination of metformin plus a SGLT-2 inhibitor with a combination of metformin plus a DPP-4 inhibitor, stratified by severity of hypoglycemia.

One 52-week RCT158 randomized 714 patients to metformin plus sitagliptin or metformin plus canagliflozin, finding 4.1 percent of patients in the metformin plus sitagliptin arm with any hypoglycemic event compared with 6.8 percent of patients in the metformin plus canagliflozin arm. A 78-week, lower-quality RCT90 found 3.6 percent of patients with any hypoglycemic event in the metformin plus sitagliptin arm, 1.8 percent of patients with such events in the low-dose metformin plus empagliflozin arm, and 2.4 percent of patients in the high-dose metformin plus empagliflozin arm.

Two shorter RCTs assessed total hypoglycemia with followup at 12 weeks, showing a non-significant greater risk of total hypoglycemia in the metformin plus DPP-4 inhibitor arms.153, 156 (SOE: Low; Neither arm favored for mild, moderate, total, and severe hypoglycemia)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three studies reported on hypoglycemia for this comparison, showing no clear between-group differences in hypoglycemia risk (Table 67).141, 159, 188 All three studies compared metformin plus sitagliptin, but each of the studies used a different GLP-1 receptor agonist in the metformin plus GLP-1 receptor agonist comparator arm (albiglutide, exenatide, and dulaglutide). None of the three studies had any severe hypoglycemia in either arm. For mild to moderate hypoglycemia, there were conflicting results with two of the three studies favoring the metformin plus DPP-4 inhibitor arms. This may be due to different types of GLP-1 receptor agonists, although there may be unidentified sources of heterogeneity, too. (SOE: Low; Neither arm favored for mild, moderate, total, and severe hypoglycemia)

Table 67 Randomized controlled trials comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist on hypoglycemia

Author, Year | Followup (Weeks) | Metformin + DPP-4 Inhibitor (Dose^*^) | Metformin + GLP-1 Receptor Agonist (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin + DPP-4 Inhibitor Vs Metformin + GLP-1 Receptor Agonist)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + albiglutide (max 50 mg weekly) | Mild-moderate (asymptomatic, but BG ≤ 3.9 mmol/L) | 4/302 (1.3%) vs 4/302 (1.3%)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + albiglutide (max 50 mg weekly) | Mild-moderate (symptomatic and BG ≤ 3.9 mmol/L) | 5/302 (1.7%) vs 9/302 (3%)
Ahren, 2014^141^ | 104 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + albiglutide (max 50 mg weekly) | Severe (required third party assistance) | 0/302 (0%) vs 0/302 (0%)
Bergenstal, 2010^188^ | 26 | Metformin (fixed, mean 1583 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed, mean 1504 mg) + exenatide (fixed at 2 mg weekly) | Mild-moderate (symptomatic and BG < 3 mmol/L) | 5/166 (3%) vs 2/160 (1.3%)
Bergenstal, 2010^188^ | 26 | Metformin (fixed, mean 1583 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed, mean 1504 mg) + exenatide (fixed at 2 mg weekly) | Severe^‡^ | 0/166 (0%) vs 0/160 (0%)
Nauck, 2014^159^ | 52 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed 0.75 mg weekly) | Mild-moderate (signs, symptoms and/or BG ≤ 70 mg/dL) | 15/315 (4.8%) vs 16/302 (5.3%)
Nauck, 2014^159^ | 52 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed 0.75 mg weekly) | Severe (required third party assistance) | 0/315 (0%) vs 0/302 (0%)
Nauck, 2014^159^ | 52
Nauck, 2014^159^ | 52 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed 1.5 mg weekly) | Mild-moderate (signs, symptoms and/or BG ≤ 70 mg/dL) | 15/315 (4.8%) vs 31/304 (10.2%)
Nauck, 2014^159^ | 52 | Metformin (fixed at ≥ 1500 mg) + sitagliptin (fixed at 100 mg) | Metformin (fixed at ≥ 1500 mg) + dulaglutide (fixed 1.5 mg weekly) | Severe (required third party assistance) | 0/315 (0%) vs 0/304 (0%)

BG = blood glucose; DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; max = maximum; mg = milligrams; mg/dL = milligrams per deciliter; mmol/L = millimole per liter

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Severe hypoglycemia was defined as a loss of consciousness, seizure, or coma that resolved after treatment with glucagon or glucose, or severe impairment that required third-party assistance to resolve the episode and a blood glucose concentration of lower than 3 mmol/L.

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a Basal Insulin

One RCT assessed hypoglycemia for the comparison of a combination of metformin plus a DPP-4 inhibitor versus a combination of metformin plus a basal insulin, finding more hypoglycemic events in the metformin plus insulin arm (Table 68).211 (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

Table 68 Randomized controlled trials comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a basal insulin on hypoglycemia

Author, Year | Followup (Weeks) | Metformin + DPP-4 Inhibitor (Dose^*^) | Metformin + Basal Insulin (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin + DPP-4 Inhibitor Vs Metformin + Basal Insulin)
Aschner, 2012^211^ | 24 | Metformin (baseline dose 1835 mg) + sitagliptin (fixed at 100 mg) | Metformin (baseline dose 1852 mg) + insulin glargine (max 0.5 U/kg) | Severe (severe symptomatic) | 1/264 (0.4%) vs 3/237 (1.3%)
Aschner, 2012^211^ | 24 | Metformin (baseline dose 1835 mg) + sitagliptin (fixed at 100 mg) | Metformin (baseline dose 1852 mg) + insulin glargine (max 0.5 U/kg) | Total (symptomatic and BG ≤ 3.9 mmol/L) | 28/264 (10.6%) vs 86/237 (36.3%)

BG = blood glucose; DPP-4 = dipeptidyl peptidase-4; max = maximum; mg = milligrams; mmol/L = millimole per liter; U/kg = units per kilogram

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Basal Insulin

Two RCTs compared metformin plus basal insulin with the combination of metformin plus exenatide, with lower risk of mild or moderate hypoglycemia in the metformin plus exenatide arms in both studies (range in RD of -3% to -25%) (Table 69).212, 264 Both RCTs reported no between-group differences in severe hypoglycemia.212, 264 (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

Table 69 Randomized controlled trials comparing a combination of metformin plus a GLP-1 receptor agonist with a combination of metformin plus a basal insulin on hypoglycemia

Author, Year | Followup (Weeks) | Metformin + GLP-1 (Dose^*^) | Metformin + Basal Insulin (Dose^*^) | Definition of Hypoglycemia | Results^†^ (Metformin + GLP-1 Vs Metformin + Basal Insulin)
Davies, 2013^264^ | 26 | Metformin (fixed at ≥ 1000 mg) + exenatide (fixed at 2 mg weekly) | Metformin (fixed at ≥ 1000 mg) + insulin detemir (mean initial dose 0.21 IU/kg; mean end dose 20.8 IU, end dose 0.51 IU/kg) | Mild-moderate (symptoms that were self-treated or resolved on their own, with documented BG < 3.0 mmol/L) | 0/33 (0%) vs 1/29 (3.4%)
Davies, 2013^264^ | 26 | Metformin (fixed at ≥ 1000 mg) + exenatide (fixed at 2 mg weekly) | Metformin (fixed at ≥ 1000 mg) + insulin detemir (mean initial dose 0.21 IU/kg; mean end dose 20.8 IU, end dose 0.51 IU/kg) | Severe hypoglycemia^‡^ | 0/33 (0%) vs 0/29 (0%)
Diamant, 2010^212^ | 84 | Metformin (continued stable dose) + exenatide (fixed at 2 mg weekly) | Metformin (continued stable dose) + insulin glargine (started at 10 IU then titrate to glycemic goal of 4-5.5 mmol/L) | Mild-moderate (symptoms and BG < 3.0 mmol/L and was either self-treated or resolved independently) | 13/164 (7.9%) vs 51/157 (32.5%)
Diamant, 2010^212^ | 84 | Metformin (continued stable dose) + exenatide (fixed at 2 mg weekly) | Metformin (continued stable dose) + insulin glargine (started at 10 IU then titrate to glycemic goal of 4-5.5 mmol/L) | Severe hypoglycemia^‡^ | 1/164 (0.6%) vs 1/157 (0.6%)

BG = blood glucose; GLP-1 = glucagon-like peptide-1 receptor agonist; IU = international units; IU/kg = international units per kilogram; mg = milligrams; mmol/L = millimole per liter;

* All doses were titrated, unless otherwise stated.

† Results are presented as n/N (%) unless otherwise stated.

‡ Any hypoglycemic episode with symptoms consistent with hypoglycemia that led to loss of consciousness or seizure, with prompt recovery in response to glucagon or glucose administration, or documented hypoglycemia [blood glucose <3.0mmol] necessitating assistance of another person

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Premixed Insulin

One study assessed the comparison of a combination of metformin plus a GLP-1 receptor agonist versus a combination of metformin plus a premixed insulin, showing less hypoglycemia in the metformin plus GLP-1 receptor agonist arm compared with the metformin plus premixed insulin arm. This 26-week RCT found an incidence of first hypoglycemic episodes of 8.0 percent in the metformin plus exenatide group versus 20.5 percent in the metformin plus insulin aspart 70/30 group (RD, -12.5%).213 No severe hypoglycemia was reported. (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither favored for severe hypoglycemia)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

Five trials examined the comparison of metformin plus basal insulin to metformin plus a mix of long- and short-acting insulin, consistently favoring the former (range in RD, -5% to -28%) (Table 70).214-216, 223, 224 Due to the heterogeneity of these trials (I-squared, 78.8%), they were not pooled in a meta-analysis. The heterogeneity may be owing to the difference in followup times, insulin preparations, and insulin dosing. (SOE: Moderate; Combination of metformin plus a basal insulin favored for mild, moderate, or total hypoglycemia) (SOE: Low; Neither arm favored for severe hypoglycemia)

Table 70 Randomized controlled trials comparing a combination of metformin plus a basal insulin with a combination of metformin plus a premixed insulin on hypoglycemia

Author, Year | Comparison | Outcome | Results | RR and Comments (Combination Metformin and Another Insulin as Reference Group)
Malone, 2004^223^ | Metformin + glargine versus metformin + lispro 75/25 | Mild or moderate at 32 weeks | 40/101 versus 57/100 (87 versus 181 events) | RR = 0.69 (95% CI 0.5 to 0.9), both arms of cross-over pooled
Malone, 2004^223^ | Metformin + glargine versus metformin + lispro 75/25 | Severe at 32 weeks | None | NA
Malone, 2005^224^ | Metformin + glargine versus metformin + lispro 75/25 | Mild or moderate at 32 weeks | 0.44 versus 0.61 events/patient/30 days | P = 0.47; more daytime hypoglycemia with lispro 75/25 but less nocturnal hypoglycemia
Malone, 2005^224^ | Metformin + glargine versus metformin + lispro 75/25 | Severe at 32 weeks | None | NA
Raskin, 2007^215^ | Metformin + glargine versus metformin + aspart 70/30 | Mild or moderate at 28 weeks | 11/78 versus 33/79 (23 versus 121 events) | RR = 0.34 (95% CI 0.2 to 0.6)
Robbins, 2007^214^ | Metformin + glargine versus metformin + lispro 50/50 | Mild or moderate at 24 weeks | 75/158 versus 79/157 | RR = 0.94 (95% CI 0.8 to 1)
Robbins, 2007^214^ | Metformin + glargine versus metformin + lispro 50/50 | Severe at 24 weeks | 2/158 versus 3/157 | RR = 0.66 (95% CI 0.1 to 4)
Davies, 2007^216^ | Metformin + NPH versus metformin + NPH/regular 70/30 | Mild or moderate | 7/29 versus 8/27 | RR = 0.81 (95% CI 0.34 to 1.9); a poorly conducted trial

CI = confidence interval; NA = not available; NPH = neutral protamine Hagedorn; RR = relative risk

#### Strength of Evidence for Hypoglycemia

As noted in the Key Points, Table 71, Table 72, and Table 73, we found moderate or high strength of evidence for many of the monotherapy comparisons evaluating hypoglycemia and also found a number of combination comparisons with high or moderate strength of evidence. We found several comparisons of interest for which there was no or minimal evidence, especially among the combination comparisons. Study limitations for most comparisons were low or medium, with only two comparisons having high study limitations owing to lack of blinding, lack of description of withdrawals and dropouts, or high losses to followup. In general, we did not find strong differences in outcomes in the lower- versus higher-quality studies. When we found low strength of evidence for hypoglycemia, this tended to occur in the setting of fair to poor study quality and inconsistency for monotherapy comparisons and was related to insufficient data in the combination comparisons. We generally found consistency among studies if there were more than three studies for a given comparison. Most evidence on hypoglycemia was precise for monotherapy comparisons; there was less precision when there were fewer studies, as in the combination comparisons. We did not find any evidence of publication bias using the Begg's and Egger's test for the comparisons with greater than ten studies. We identified unpublished studies that could have influenced our rating of the evidence. A single unpublished study found more hypoglycemia in a DPP-4 inhibitor arm than in the comparator metformin arm; this was consistent with our findings and could have strengthened the evidence. Also, we identified two additional studies of the comparison of sulfonylurea to DPP-4 inhibitor monotherapy which were consistent with the published studies; the addition of this evidence may have allowed us to rate the strength of evidence as high for this comparison.

Table 71 Strength of evidence domains for monotherapy comparisons in terms of hypoglycemia among adults with type 2 diabetes

Comparison^*^ | Outcome | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD | Mild, moderate, total | 5 (4,197) | Medium | Inconsistent | Direct | Precise | Undetected | Low | Metformin favored
Metformin vs. TZD | Severe | 1 (409) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. SU | Mild, moderate, total | RCTs: 14 (7,332) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin favored; 4.0 (1.8 to 9.8)
Metformin vs. SU | Mild, moderate, total | Observational: 1 (1789) | Medium | Unknown | Direct | Precise | n/a | High | Metformin favored; 4.0 (1.8 to 9.8)
Metformin vs. SU | Severe | 2 (376) | Low | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin favored; range in OR, 0.49 to 0.71; range in RD, -1% to -23%
Metformin vs. DPP-4 inhibitors | Mild, moderate, total | 6 (6,710) | High | Consistent for symptomatic hypoglycemia | Direct | Precise | Undetected | Low | DPP-4 inhibitor favored
Metformin vs. DPP-4 inhibitors | Severe | 6 (6,710) | High | Inconsistent | Direct | Imprecise | Suspected | Low | Neither favored
Metformin vs. SGLT-2 inhibitors | Mild, moderate, total | 5 (2,700) | Medium | Consistent | Direct | Precise | Undetected | Moderate | SGLT-2 inhibitors favored; 0.5 (0.2 to 1.3)
Metformin vs. SGLT-2 inhibitors | Severe | 2 (831) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. GLP-1 receptor agonists | Mild, moderate, total | 3 (1360) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin vs. GLP-1 receptor agonists | Severe | 3 (1360) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
TZD vs. SU | Mild, moderate, total | 8 (6,212) | Low | Consistent | Direct | Precise | Undetected | High | TZD favored; 6.3 (4.1 to 9.8)
TZD vs. SU | Severe | 2 (3,304) | Low | Consistent | Direct | Precise | Undetected | Moderate | TZD favored; OR, 8.1; RD, 0.4%
TZD vs. DPP-4 inhibitors | Mild, moderate, total | 3 (1,686) | Low | Inconsistent | Direct | Precise | Undetected | Insufficient | Unable to determine
TZD vs. DPP-4 inhibitors | Severe | 2 (653) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
TZD vs. GLP-1 receptor agonists | Mild, moderate, total | 2 (689) | Medium | Consistent | Direct | Imprecise | Undetected | Low | TZD favored
TZD vs. GLP-1 receptor agonists | Severe | 1 (411) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
SU vs. DPP-4 inhibitors | Mild, moderate, total | 4 (1,065) | Medium | Consistent | Direct | Precise | Undetected | Moderate | DPP-4 favored; range in OR, 3.8 to 12.4; range in RD, 6% to 15%
SU vs. DPP-4 inhibitors | Severe | 2 (623) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | DPP-4 favored
SU vs. GLP-1 receptor agonists | Mild, moderate, total | 5 (2,467) | Medium | Consistent | Direct | Precise | Undetected | Moderate | GLP-1 favored for mild-moderate hypoglycemia; range in OR, 3.1 to 5.3; range in RD, 12% to 21%
SU vs. GLP-1 receptor agonists | Severe | 3 (1546) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
DPP-4 inhibitors vs. SGLT-2 inhibitors | Mild, moderate, total | 1 (670) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
DPP-4 inhibitors vs. SGLT-2 inhibitors | Severe | 1 (670) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
DPP-4 inhibitors vs. GLP-1 receptor agonists | Mild, moderate, total | 1 (411) | Low | Unknown | Direct | Imprecise | Undetected | Low | DPP-4 favored
DPP-4 inhibitors vs. GLP-1 receptor agonists | Severe | 1 (411) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored

CI = confidence interval; DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; OR = odds ratio; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) due to the few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 72 Strength of evidence domains for metformin versus metformin-based combination comparisons in terms of hypoglycemia among adults with type 2 diabetes

Comparison^*^ | Outcome | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + TZD | Mild, moderate, total | 10 (3,906) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin favored; 1.6 (0.99 to 2.4)
Metformin vs. metformin + SU | Mild, moderate, total | 12 (3,732) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin favored, range in OR, 0.99 to 28.55; range in RD, 0% to 35%
Metformin vs. metformin + SU | Severe | 2 (544) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + DPP-4 inhibitors | Mild, moderate, total | 27 (17,946) | Low | Consistent | Direct | Precise | Undetected | High | Neither favored; pooled OR for mild-moderate, 0.97 (0.6 to 1.5) Pooled OR for total, 1.0 (0.6 to 1.7
Metformin vs. metformin + DPP-4 inhibitors | Severe | 12 (5,674) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + SGLT-2 inhibitors (<2 years) | Mild, moderate, total | 10 (6,178) | Low | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin favored; 1.7; 95% CI, 0.8 to 3.7
Metformin vs. metformin + SGLT-2 inhibitors (<2 years) | Severe | 7 (2,934) | Low | Consistent | Direct | Imprecise | Undetected | Moderate | Neither favored; no events
Metformin vs. metformin + GLP-1 receptor agonists | Mild, moderate, total | 4 (2,654) | High | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + GLP-1 receptor agonists | Severe | 2 (1,186) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither favored

CI = confidence interval; DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; OR = odds ratio; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 73 Strength of evidence domains for metformin-based combination comparisons in terms of hypoglycemia among adults with type 2 diabetes

Comparison^*^ | Outcome | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + SU | Mild, moderate, total | 7 (975) | Medium | Consistent | Direct | Imprecise | Undetected | High | Metformin + TZD favored; 7.5 (4.0 to 13.8)
Metformin + TZD vs. metformin + SU | Severe | 1 (314) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin + TZD favored
Metformin + TZD vs. metformin + DPP-4 inhibitors | Mild, moderate, total | 2 (603) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither drug combination favored
Metformin + TZD vs. metformin + DPP-4 inhibitors | Severe | RCT 1 (491) Obs 1 (83) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + TZD vs. metformin + GLP-1 receptor agonists | Mild, moderate, total | 2 (415) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither drug combination favored
Metformin + TZD vs. metformin + GLP-1 receptor agonists | Severe | 2 (415) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither drug combination favored
Metformin + SU vs. metformin + DPP-4 inhibitors | Mild, moderate, total | 10 (6,757) | Medium | Consistent | Direct | Imprecise | Undetected | High | Metformin + DPP4-inhibitors favored Pooled OR for studies ≤52 weeks: 0.2 (0.1 to 0.4) Pooled OR for studies >52 weeks: 0.1 (0.04 to 0.14)
Metformin + SU vs. metformin + DPP-4 inhibitors | Severe | 6 (4,717) | Medium | Consistent | Direct | Imprecise | Undetected | High | Metformin + DPP-4 inhibitors favored Pooled OR for studies <52 weeks: 0.2 (0.1 to 0.6) Pooled OR for studies ≥52 weeks: 0.1 (0.03 to 0.3)
Metformin + SU vs. metformin + SGLT-2 inhibitors (< 2 years) | Mild, moderate, total | 3 (3,815) | Low | Consistent | Direct | Precise | Undetected | High | Metformin + SGLT-2 inhibitors favored; 0.1 (0.03 to 0.2)
Metformin + SU vs. metformin + SGLT-2 inhibitors (< 2 years) | Severe | 2 (1,779) | Low | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin + SGLT-2 inhibitors favored in studies lasting 1-2 years; range in OR, 0.13 to 0.23; range in RD, -3% to -1%
Metformin + SU vs. metformin + GLP-1 receptor agonists | Mild, moderate, total | 3 (2,557) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 inhibitor favored in studies lasting 16 to 238 weeks; range in OR, 0.07 to 0.29; range in RD, -30% to -15%
Metformin + SU vs. metformin + GLP-1 receptor agonists | Severe | 3 (2,557) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + SU vs. metformin + basal insulin | Mild, moderate, total | 1 (75) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin + insulin favored
Metformin + SU vs. metformin + basal insulin | Severe | 1 (75) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither arm favored
Metformin + SU vs. metformin + premixed insulin | Mild, moderate, total | 2 (827) | Medium | Consistent | Direct | Imprecise | Suspected | Low | Neither arm favored
Metformin + SU vs. metformin + premixed insulin | Severe | 1 (597) | High | Unknown | Direct | Imprecise | Suspected | Insufficient | Unable to draw a conclusion
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | Mild, moderate, total | 4 (2,889) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Neither arm favored in studies lasting 12 to 78 weeks
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | Severe | 2 (1,359) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither arm favored
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | Mild, moderate, total | 3 (1,851) | Medium | Inconsistent | Direct | Precise | Undetected | Low | Neither arm favored in studies lasting 26 to 104 weeks
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | Severe | 3 (1,851) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither arm favored in studies lasting 26 to 104 weeks
Metformin + DPP-4 inhibitors vs. metformin + basal insulin | Mild, moderate, total | 1 (515) | Medium | Unknown | Direct | Precise | Undetected | Low | Metformin + DPP-4 inhibitor favored
Metformin + DPP-4 inhibitors vs. metformin + basal insulin | Severe | 1 (515) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither arm favored
Metformin + GLP-1 receptor agonists vs. metformin + basal insulin | Mild, moderate, total | 2 (397) | Medium | Consistent | Direct | Imprecise | Undetected | Low^‡^ | Metformin + GLP-1 receptor agonist favored in studies lasting 26 to 84 weeks
Metformin + GLP-1 receptor agonists vs. metformin + basal insulin | Severe | 2 (383) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither arm favored
Metformin + GLP-1 receptor agonists vs. metformin + premixed insulin | Mild, moderate, total | 1 (363) | High | N/A | Direct | Imprecise | Undetected | Low^‡^ | Metformin + GLP-1 receptor agonist favored
Metformin + GLP-1 receptor agonists vs. metformin + premixed insulin | Severe | 1 (363) | High | Unknown | Direct | Imprecise | Undetected | Low | Neither arm favored
Metformin + basal insulin vs. metformin + premixed insulin | Mild, moderate, total | 5 (530) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin + basal insulin favored; range in OR, 0.3 to 0.9; range in RD, -28% to -5%
Metformin + basal insulin vs. metformin + premixed insulin | Severe | 3 (613) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither arm favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; OR = odds ratio; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

‡ If we compare the metformin plus GLP-1 receptor agonists versus metformin plus premixed or basal insulin, then metformin plus GLP-1 receptor agonists have less hypoglycemia over metformin plus either premixed or basal insulin with moderate strength of evidence

### Evidence for Gastrointestinal Side Effects

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

Eight RCTs compared GI adverse events between metformin and either pioglitazone or rosiglitazone.50, 59, 62, 64, 67, 70, 73, 74 GI adverse events were more common with metformin compared with thiazolidinediones in the majority of RCTs, except for dyspepsia, where the number of events were comparable for both treatments. More people had diarrhea and nausea with metformin than thiazolidinediones (Figure 69). There were no overly influential studies in the meta-analysis for diarrhea, and there was little heterogeneity between these studies. (SOE: Moderate; Thiazolidinediones favored for diarrhea and nausea)

Figure 69 Pooled odds ratio of gastrointestinal adverse events comparing metformin with thiazolidinediones

CI = confidence interval; Group 1 = metformin; Group 2 = thiazolidinediones; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of gastrointestinal adverse events comparing metformin with thiazolidinediones.

##### Metformin Versus Sulfonylureas

Twelve RCTs compared GI adverse events between metformin and a sulfonylurea.50, 74, 129-131, 133, 134, 136-138, 251, 257 GI adverse events tended to be more common with metformin than with sulfonylurea (Table 74). Based on meta-analyses, there were fewer GI adverse events with sulfonylureas than with metformin for the outcomes of diarrhea (OR, 0.42; 95% CI, 0.24 to 0.72; I-squared, 48.4%; six studies), abdominal pain (OR, 0.44; 95% CI, 0.29 to 0.67; I-squared, 0%; three studies), nausea and vomiting (OR, 0.45; 95% CI, 0.31 to 0.65; I-squared, 0%; three studies) and any GI adverse event (OR, 0.45; 95% CI, 0.28 to 0.72; I-squared, 22.2%; four studies). (SOE: Moderate; Sulfonylureas favored)

Table 74 Studies comparing metformin with sulfonylureas on gastrointestinal adverse events

Author, Year | Outcome | Event Rates (Metformin Versus Sulfonylureas)
Hermann, 1994^134^ | Any GI outcome | 63% (24/38) versus 32% (11/34)
Hermann, 1994^134^ | Abdominal pain | 18% (7/38) versus 6% (2/34)
Hermann, 1994^134^ | Diarrhea | 50% (19/38) versus 0 (0/34)
Hermann, 1994^134^ | Nausea | 24% (9/38) versus 9% (3/34)
Hermann, 1994^134^ | Withdrawal for GI symptoms | 14% versus 0%
DeFronzo, 1995^137^ | Nausea and diarrhea | 1.4% (3/210) versus 1.0% (2/209)
Amador-Licona, 2000^251^ | Diarrhea and abdominal pain | 14.3% (4/28) for metformin; event rates are not reported for sulfonylurea
Charpentier, 2001^136^ | Diarrhea | 7% (5/75) versus 1% (1/150)
Blonde, 2002^131^ | Nausea and vomiting | 12.4% (19/153) versus 5.5% (9/164)
Blonde, 2002^131^ | Dyspepsia/heartburn | 4.6% (7/153) versus 3% (5/164)
Blonde, 2002^131^ | Flatulence | 2% (3/153) versus 0% (0/164)
Garber, 2002^133^ | | Metformin (n = 159); glyburide (n = 160)
Garber, 2002^133^ | Any GI outcome | 43% versus 24%
Garber, 2002^133^ | Diarrhea | 15.1% versus 4.4%
Garber, 2002^133^ | Nausea/vomiting | 6.3% versus 0.6%
Garber, 2002^133^ | Abdominal pain | 5% versus 3.1%
Garber, 2002^133^ | Dyspepsia | 5% versus 2.5%
Garber, 2003^129^ | Nausea/vomiting | 10.4% (17/164) versus 6.6% (10/151)
Garber, 2003^129^ | Abdominal pain | 6.1% (10/164) versus 4% (6/151)
Garber, 2003^129^ | Diarrhea | 18% (30/164) versus 5.3% (18/151)
Goldstein, 2003^130^ | Diarrhea | 17.3% (13/75) versus 13.1% (11/84)
Derosa, 2004^257^ | Nausea and diarrhea | 2.4% (2/75) versus 0% (0/73)
Kahn, 2006^50^ | Combined GI events | 38% (557/1454) versus 22% (316/1441)
Kahn, 2006^50^ | Nausea | 11.7% (170/1454) versus 6.9% (99/1441)
Kahn, 2006^50^ | Vomiting | 5.8% (84/1454) versus 3.1% (45/1441)
Kahn, 2006^50^ | Diarrhea | 23.7% (345/1454) versus 9.9% (142/1441)
Kahn, 2006^50^ | Abdominal discomfort | 15.4% (224/1454) versus 11.3% (163/1441)
Chien, 2007^138^ | Combined GI events | 32% (8/25) versus 13% (3/23)
Yoon, 2011^74^ | Diarrhea | 8.8% (10/114) versus 3.4% (4/118)
Yoon, 2011^74^ | Discomfort, pain, nausea or vomiting | 8.8% (10/114) versus 8.5% (10/118)

GI = gastrointestinal

##### Metformin Versus DPP-4 Inhibitors

Six RCTs compared metformin with a DPP-4 inhibitor and reported on GI adverse events.73, 82, 84-87 Metformin had more GI adverse events compared with each of the DPP-4 inhibitors (Figure 70). One trial identified solely in ClinicalTrials.gov had results consistent with the published studies (NCT01076088). We combined the three studies with similar study durations and dosages for nausea and diarrhea. We did not combine “any” GI adverse event outcomes, because study durations were not sufficiently similar. Based on meta-analyses, there were fewer nausea outcomes for DPP-4 inhibitors compared with metformin (pooled OR, 0.37; 95% CI, 0.15 to 0.91; I-squared, 4%; three studies) and fewer diarrhea outcomes for the same comparison (pooled OR, 0.38, 95% CI, 0.18 to 0.83; I-squared, 25%; three studies). The excluded longer studies were consistent with the findings, favoring DPP-4 inhibitors over metformin (Figure 70). (SOE: High; DPP-4 inhibitors favored)

Figure 70 Odds ratio of gastrointestinal adverse events comparing metformin with DPP-4 inhibitors

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = dipeptidyl peptidase-4 inhibitors; OR = odds ratio

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing metformin with DPP-4 inhibitors.

##### Metformin Versus SGLT-2 Inhibitors

Three trials (published in two articles) compared metformin with dapagliflozin.88, 89 One trial compared metformin with empagliflozin,239 Diarrhea and nausea tended to be more common with metformin than with the SGLT-2 inhibitors (Figure 71). We did not pool the trials owing to dosage differences. (SOE: Low; SGLT-2 inhibitors favored for diarrhea and nausea)

Figure 71 Odds ratio of gastrointestinal adverse events comparing metformin with SGLT-2 inhibitors

CI = confidence interval; Dapa = dapagliflozin; Empa = empagliflozin, Group 1 = metformin; Group 2 = sodium-glucose co-transporter-2 inhibitors; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing metformin with SGLT-2 inhibitors.

##### Metformin Versus GLP-1 Receptor Agonists

Two trials compared metformin with exenatide.73, 92 One trial compared metformin with once-weekly subcutaneously injected 0.75 mg or 1.5 mg of dulaglutide.91 Diarrhea non-significantly differed between metformin and GLP-1 receptor agonists (OR, 0.78; 95% CI, 0.54 to 1.14; I-squared, 0%; three studies). However, nausea (OR, 1.28 and 1.71), vomiting (pooled OR, 1.73; 95% CI, 1.01 to 2.95; I-squared, 0%; three studies) and dyspepsia (OR, 2.33) were more common with the GLP-1 receptor agonists (Figure 72). (SOE: Low; GLP-1 receptor agonists favored for diarrhea; SOE: Moderate; Metformin favored for nausea/vomiting)

Figure 72 Odds ratio of gastrointestinal adverse events comparing metformin with GLP-1 receptor agonists

CI = confidence interval; GLP-1 = glucagon-like peptide-1; Group 1 = metformin; Group 2 = glucagon-like peptide-1 agonists; OR = odds ratio

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing metformin with GLP-1 receptor agonists.

##### Thiazolidinediones Versus Sulfonylureas

Five RCTs compared diarrhea occurrence with pioglitazone or rosiglitazone to either glyburide, glibenclamide or glimepiride and showed no differences between treatments (Figure 73).50, 52, 74, 94, 95 The range in percentages of subjects with any type of GI adverse events in the thiazolidinediones (1% to 13%) was similar to the range with any type of GI adverse events in the sulfonylurea arms (1% to 18%), with a range in RD of -1.2% to 1.7%. Studies of diarrhea were not combined in a meta-analysis due to differences in study duration. (SOE: High; Neither favored)

Figure 73 Odds ratio of gastrointestinal adverse events comparing thiazolidinediones with sulfonylureas

CI = confidence interval; Group 1 = thiazolidinediones; Group 2 = sulfonylureas; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing thiazolidinediones with sulfonylureas.

##### Thiazolidinediones Versus DPP-4 Inhibitors

Two trials compared pioglitazone with sitagliptin with no meaningful difference between treatments for GI adverse events.48, 73

One trial identified solely in ClinicalTrials.gov (NCT01183013) reported no cases of diarrhea or vomiting in any of the 134 participants receiving pioglitazone (45 mg daily) or the 130 participants receiving linagliptin (5 mg daily). (SOE: Low; Neither favored)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

Two trials compared pioglitazone with exenatide for outcomes of constipation, diarrhea, dyspepsia, nausea, and vomiting.73, 105 Exenatide-treated participants tended to have more gastrointestinal side effects than those receiving pioglitazone, in both trials (range in RD 0.1% to 7% depending on the GI adverse event reported).

A trial identified in ClinicalTrials.gov (NCT01147627) reported significantly more GI adverse events with exenatide compared with pioglitazone (37/142 versus 1/136 for nausea; 15/142 versus 1/136 for vomiting; 6/142 versus 4/136 for diarrhea). (SOE: Low; Thiazolidinediones favored)

##### Sulfonylureas Versus DPP-4 Inhibitors

One RCT compared glipizide (n=212) with sitagliptin (n=210).107 The authors stated that there were no significant differences between treatments for outcomes of abdominal pain, diarrhea, and vomiting at 58 weeks, but that sitagliptin-treated participants had statistically significantly less nausea (P = 0.025); the number or percent of individuals with nausea was not reported.

One RCT compared glimepiride with linagliptin.106 By 34 weeks, 9 percent of individuals on each drug had an unspecified GI adverse event.

One trial was identified only in ClinicalTrials.gov (NCT01006603). A comparable number of GI adverse events occurred with glimepiride and with saxagliptin (19/359 versus 15/359 for diarrhea; 8/359 versus 4/359 for nausea). (SOE: Low; Neither favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Three RCTs compared GI adverse events between glibenclamide and liraglutide.109, 110, 113 GI adverse events were more common with GLP-1 receptor agonists (range in RD 3% to 9% for studies lasting 52 weeks or less) (Figure 74). We did not pool any of these outcomes due to insufficient studies per outcome or differences in study duration for diarrhea. (SOE: Moderate; Sulfonylureas favored for diarrhea) (SOE: Low; Sulfonylureas favored for other GI adverse events)

Figure 74 Pooled odds ratio of gastrointestinal adverse events comparing sulfonylureas with GLP-1 receptor agonists

CI = confidence interval; GLP-1 = glucagon-like peptide-1; Group 1 = sulfonylureas; Group 2 = glucagon-like peptide-1 agonists; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of gastrointestinal adverse events comparing sulfonylureas with GLP-1 receptor agonists.

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

One RCT compared sitagliptin to exenatide.73 At 26 weeks, there tended to be more diarrhea (5.5% vs 10.9%), dyspepsia (1.8% vs 7.3%), nausea (3.7% vs 11.3%), and vomiting (1.8% vs 4.8%) with exenatide than sitagliptin. (SOE: Low; DPP-4 inhibitors favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

Ten RCTs compared metformin with a combination of metformin and a thiazolidinedione for the rates of GI adverse events. Diarrhea was more common among the metformin monotherapy group (OR, 0.59; 95% CI, 0.45 to 0.76; I-squared, 16.4%; five studies), with no consistent differences in other GI adverse events (Figure 75).59, 67, 117-121, 125, 127, 247 Dosages of metformin were generally similar in both arms within trials, and differences in dosages between trials did not appear to impact the GI adverse events. (SOE: Low; Combination of metformin plus a thiazolidinedione favored for diarrhea; Neither favored for other GI-related outcomes)

Figure 75 Odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a thiazolidinedione

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a thiazolidinedione; mg = milligrams; OR = odds ratio

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a thiazolidinedione.

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

Twelve RCTs examined GI adverse events comparing metformin with metformin plus a sulfonylurea.47, 129-131, 133, 134, 136-141 No clear differences in GI adverse events were identified between arms (Figure 76). For the outcome with at least three studies, there was a pooled OR of 0.66 (95% CI, 0.34 to 1.28; I-squared, 0%; three studies) for diarrhea. We did not combine the four studies reporting on any GI adverse event owing to differences in study duration and dosing differences. Two of the studies used lower doses of metformin with combination therapy compared with monotherapy.47, 129 Studies that reported on combinations of adverse events that did not conform with the definition of “any” adverse event (diarrhea, nausea, vomiting or pain) are not included in the summary figure. (SOE: Low; Neither arm favored)

Figure 76 Odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a sulfonylurea^*^ * Studies with more than one dosing arm under the same gastrointestinal outcome are reported twice in the figure to demonstrate effects of different dosing arms.

CI = confidence interval; GI = gastrointestinal; Group 1 = metformin; Group 2 = combination of metformin plus a sulfonylurea; mg = milligrams; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a sulfonylurea

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Three RCTs compared metformin with metformin plus alogliptin.84, 154, 157 Five RCTs compared metformin with metformin plus linagliptin.86, 139, 152, 155, 162 Six RCTs compared metformin and metformin plus saxagliptin.87, 144, 146, 147, 151, 161 Twelve RCTs compared metformin and metformin plus sitagliptin.85, 118, 141-143, 145, 148, 149, 153, 156, 159, 256

There were inconsistent findings for GI adverse events depending on the outcome examined. There were no between-group differences for abdominal pain, nausea, and any GI adverse event (Figure 77 and Figure 78). Diarrhea was more common in the metformin monotherapy arm in the shorter studies but may have been more common in the metformin plus DPP-4 inhibitor arms in the longer studies (Figure 79). Vomiting occurred less often with metformin monotherapy in the longer studies, and showed no differences between groups in studies lasting less than a year (Figure 80).

Figure 77 Pooled odds ratio of abdominal pain or nausea comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of abdominal pain or nausea comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

Figure 78 Pooled odds ratio of any gastrointestinal adverse event comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of any gastrointestinal adverse event comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

Figure 79 Pooled odds ratio of diarrhea comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of diarrhea comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

Figure 80 Pooled odds ratio of vomiting comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of vomiting comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

All the RCTs except for two147, 162 had comparable dosing of metformin in the monotherapy and combination arms. The first study with dosing differences was included in the meta-analyses where appropriate since dosing differences were small between arms (1500 to 2000 mg metformin in the monotherapy and 1500 mg metformin in the combination arm) and unlikely to impact the findings.147 Sensitivity analyses excluding this study confirmed that the study did not influence the results.147 The second study162 was excluded from the meta-analyses since the metformin monotherapy arm was at 2000 mg daily and the metformin dosing in the combination arm was only at 1000 mg daily, which could bias the study findings to favor the combination arm. In this excluded study,162 diarrhea occurred 16 percent of the time in the metformin monotherapy arm and 12 percent in the combination arm. These findings and other GI adverse events reported in this study162 were consistent with the meta-analysis results for the comparably-dosed studies.

Two trials were identified solely in ClinicalTrials.gov (NCT00960076; NCT01076088). The former found less diarrhea with metformin monotherapy compared with metformin combined with saxagliptin (3.5% versus 5.8%). The other trial reported similar numbers of individuals with GI adverse events in the metformin monotherapy group (nine people reported diarrhea; 4 people reported nausea) and the metformin plus sitagliptin group (4 people reported diarrhea; 8 people reported nausea). (SOE for abdominal pain: Low; Neither favored for shorter and longer studies) (SOE for nausea: Moderate for shorter studies and low for longer studies; Neither favored) (SOE for any GI adverse event: Moderate for shorter studies and Low for longer studies; Neither favored) (SOE for diarrhea: Low; combination favored for shorter studies and metformin favored for longer studies) (SOE for vomiting: Low for longer studies; Metformin monotherapy favored and Moderate for shorter studies; neither favored)

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

One RCT compared metformin with metformin combined with canagliflozin for diarrhea and nausea.156 Four RCTs (published in three articles) compared metformin to metformin combined with dapagliflozin for diarrhea and nausea.88, 169, 170 One RCT compared metformin to metformin combined with empagliflozin for diarrhea and nausea.153 There were no consistent differences in diarrhea between arms. Nausea tended to be more common with combination therapy, although the finding was not statistically significant (Figure 81). (SOE: Moderate; Neither favored for diarrhea) (SOE: Low; metformin favored for nausea)

Figure 81 Pooled odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = metformin; Group 2 = metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Four RCTs compared metformin with metformin plus a GLP-1 receptor agonist.141, 159, 174, 256 Metformin plus a GLP-1 receptor agonist showed no clear between-group differences in GI adverse events compared with metformin alone in one study,256 but there were more GI adverse events in the combination arm in the other studies (Figure 82).141, 159, 174 We did not pool data in meta-analyses due to insufficient numbers of studies and due to differences in study duration. (SOE: Low; Neither favored)

Figure 82 Odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; GLP-1 = glucagon-like peptide-1; Group 1 = metformin; Group 2 = metformin plus a glucagon-like peptide-1 agonist; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing metformin with a combination of metformin plus a GLP-1 receptor agonist.

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Five RCTs compared GI adverse events in the combination of metformin plus a thiazolidinedione versus metformin plus a sulfonylurea, with little between-group difference (Table 75). The RD between-groups ranged from -5.0% to 2.1%.175, 178, 180, 181, 265 (SOE: Moderate; Neither favored)

Table 75 Randomized controlled trials comparing a combination of metformin plus a thiazolidinedione with a combination of metformin plus a sulfonylurea on gastrointestinal adverse events

Author, Year | Outcome | Event Rates (Metformin Plus Thiazolidinedione Versus Metformin Plus Sulfonylurea)
Derosa, 2005^265^ | Flatulence | 4.2% (2/48) versus 2.1% (1/47)
Garber, 2006^180^ | Combined GI events | 10% (16/155) versus 11% (18/159)
Garber, 2006^180^ | Diarrhea | 3% (5/155) versus 6% (10/159)
Garber, 2006^180^ | Abdominal pain | 4% (6/155) versus 6% (10/159)
Umpierrez, 2006^178^ | Diarrhea | 4.7% (5/104) versus 6% (6/96) (no difference)
Hamann, 2008^175^ | Combined GI events | 13% (38/294) versus 18% (54/301)
Maffioli, 2013^181^ | Withdrawal owing to nausea | 1% (1/86) versus 1% (1/84)

GI = gastrointestinal

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Three RCTs compared GI adverse events in the combination of metformin plus pioglitazone or rosiglitazone versus the combination of metformin plus sitagliptin with mixed results.118, 187, 188 Diarrhea and nausea tended to be more common with sitagliptin in one trial,188 but there was only one occurrence of each (4%) in the sitagliptin group (and none reported in the pioglitazone group) in the other trial.187 In the third trial, six of 87 patients in the metformin plus rosiglitazone arm and one of 94 patients in the metformin plus sitagliptin arm experienced a GI adverse event, a difference that was close to statistically significant.118 (SOE: Low; Neither favored)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

One RCT compared diarrhea, nausea, and vomiting in the combination of metformin plus pioglitazone versus the combination of metformin plus exenatide at 26 weeks.188 There was more diarrhea (7% versus 18%), nausea (5% versus 24%), and vomiting (3% versus 11%) in the group receiving exenatide; all differences are statistically significant. The range in ORs was 2.9 to 6.3, and range in RDs were 8% to 19%. (SOE: Moderate; Combination of metformin plus a thiazolidinedione favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Seven RCTs compared diarrhea, abdominal pain, nausea, vomiting, and unspecified GI adverse events in the combination of metformin plus glipizide or glimepiride versus metformin plus alogliptin, linagliptin, sitagliptin, or saxagliptin, with no difference between treatments (Figure 83).139, 141, 192-195, 197 The OR for the four trials with similar study duration of 104 weeks for diarrhea was 0.97 (95% CI, 0.76 to 1.24; I-squared, 0 percent).141, 194, 195, 197 No single study strongly influenced the results, and no substantial heterogeneity was identified.

Figure 83 Odds ratio of gastrointestinal adverse events comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = a combination of metformin plus a sulfonylurea; Group 2 = a combination of metformin plus a dipeptidyl peptidase-4 inhibitor; Met = metformin; OR = odds ratio; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor.

One trial was identified in ClinicalTrials.gov (NCT00856284) that randomized 869 people to metformin plus 5 mg of glipizide and 378 people to metformin plus 25 mg of alogliptin. Metformin plus alogliptin had more GI adverse events (32 nausea, 1 severe vomiting, 60 diarrhea) than metformin plus glipizide (20 nausea and 63 diarrhea). No severe diarrhea was described in either group. (SOE: High; Neither favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs compared metformin plus glipizide or glimepiride with metformin plus dapagliflozin or empagliflozin on the outcomes of diarrhea and nausea.54, 199, 200 There was little difference between treatments. A meta-analysis was not performed because the trials reported adverse events at 1, 2, and 4 years after randomization.

One trial identified from ClinicalTrials.gov (NCT01368081) reported no significant difference in the number of individuals with diarrhea with metformin plus sulfonylurea (5 of 63) and metformin plus empagliflozin (4 of 65). (SOE: Low; Neither favored)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three RCTs compared metformin plus glibenclamide or glimepiride with metformin plus albiglutide or exenatide for diarrhea, nausea, or vomiting, with a similar and low incidence of adverse events in one trial of exenatide (diarrhea: 1/65 versus 2/63; vomiting: 1/65 versus 1/63),205 but a greater percentage of individuals with GI adverse events with exenatide in another trial (diarrhea: 7% versus 12%; nausea: 2% versus 29%; vomiting: 2% versus 9%).53 Diarrhea and nausea were more common with albiglutide (diarrhea: 11.9% versus 8.6%; nausea: 8.9% versus 5.2%; vomiting: 5.6% versus 3.6%; unspecified adverse events: 36.4% versus 37.6%).141 A meta-analysis was not performed because the trials differed in duration. (SOE: Low; Combination of metformin plus a sulfonylurea favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Two trials compared metformin plus sitagliptin with metformin plus different doses of canagliflozin or empagliflozin.153, 156 Diarrhea and nausea were reported for the canagliflozin comparisons, and dyspepsia was reported for the empagliflozin comparisons. There were no clear differences in GI side effects for either medication. (SOE: Low; Neither favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Four trials reported on GI adverse events comparing metformin plus sitagliptin with metformin plus albiglutide, dulaglutide, or exenatide.141, 159, 188, 256 There were more GI adverse events with GLP-1 receptor agonists in three of the four trials, with a range in RD of 0% to 23% (Figure 84). (SOE: Moderate; Combination of metformin plus a DPP-4 inhibitor favored)

Figure 84 Odds ratio of gastrointestinal adverse events comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; Group 1 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; Group 2 = combination of metformin plus a glucagon-like peptide-1 agonist; Met = metformin; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Odds ratio of gastrointestinal adverse events comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist.

##### Combination of Metformin Plus a GLP-1 Receptor Agonist Versus a Combination of Metformin Plus a Premixed Insulin

One trial compared metformin plus exenatide with metformin plus insulin aspart 70/30 at 26 weeks for diarrhea, dyspepsia, nausea, and vomiting.213 There was no difference in diarrhea between the treatments (11% versus 8%). Differences between groups for the other outcomes could not be evaluated because they were only reported for exenatide (6% dyspepsia; 19% nausea; 10% vomiting). (SOE: Insufficient)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

One RCT compared metformin in a combination regimen with either insulin glargine or lispro for diarrhea; neither arm was favored.214

One trial was reported only in ClinicalTrials.gov (NCT01068652). Thirteen of 200 people who received metformin plus insulin detemir had diarrhea compared with 15 of 203 people in the metformin plus biphasic insulin aspart 30 group. (SOE: Low; Neither favored)

#### Strength of Evidence for Gastrointestinal Side Effects

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 76, Table 77, and Table 78 and summarized in the key points. All studies were RCTs. Study limitations for most comparisons in the strength of evidence table were graded as low or medium; only two comparisons were graded as having high study limitations owing to lack of description of randomization or blinding or failure to describe withdrawals or dropouts. In general, we did not find strong relative differences in outcomes by study quality. We did not find any evidence of publication bias comparing results published in peer-reviewed journals to results published on ClinicalTrials.gov. However, for the comparison of thiazolidinediones with GLP-1 receptor agonists, an additional trial was found in ClinicalTrials.gov with consistent findings to the two published studies favoring thiazolidinediones. This study would likely increase the strength of evidence from low to moderate. We considered GI side effects a direct outcome, because they were measured directly from patient report. The most common reasons for downgrading the evidence were imprecision, inconsistency, and study limitations.

Table 76 Strength of evidence domains for monotherapy comparisons in terms of gastrointestinal side effects among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD | 8 (6,250) | Medium | Consistent | Direct | Precise | Undetected | Moderate | TZD favored for diarrhea, 0.24 (0.17 to 0.34) and nausea
Metformin vs. SU | 12 (6094) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | SU favored for diarrhea, 0.42 (0.24 to 0.72); abdominal pain, 0.44 (0.29 to 0.67); nausea and vomiting, 0.45 (0.31 to 0.65); and any GI adverse events, 0.45 (0.28 to 0.72)
Metformin vs. DPP-4 inhibitors | 6 (5,842) | Low | Consistent | Direct | Precise | Undetected | High | DPP-4 inhibitors favored for nausea, 0.37 (0.15 to 0.91) and diarrhea, 0.38 (0.18 to 0.83)
Metformin vs. SGLT-2 inhibitors | 4 (2,041) | Medium | Consistent | Direct | Imprecise | Undetected | Low | SGLT-2 inhibitors favored for diarrhea and nausea
Metformin vs. GLP-1 receptor agonists | 3 (879) | Low | Inconsistent | Direct | Imprecise for diarrhea; Precise for nausea/ vomiting | Undetected | Low for diarrhea; Moderate for nausea/ vomiting | GLP-1 receptor agonists favored for diarrhea; Metformin favored for nausea/vomiting, 1.73 (1.01 to 2.95)
TZD vs. SU | 5 (6,432) | Low | Consistent | Direct | Precise | Undetected | High | Neither favored; range in OR, 0.8 to 2.0; range in RD, -1.2% to 1.7%
TZD vs. DPP-4 inhibitors | 2 (1,031) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
TZD vs. GLP-1 receptor agonists | 2 (1,236) | Low | Consistent | Direct | Imprecise | Undetected^‡^ | Low | TZD favored
SU vs. DPP-4 inhibitors | 2 (653) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
SU vs. GLP-1 receptor agonists | 3 (1,568) | High | Consistent | Direct | Precise for diarrhea; Imprecise for all other GI adverse events | Undetected | Moderate for diarrhea; Low for abdominal pain, any GI adverse event, nausea and vomiting | SU favored; range in OR for diarrhea, 1.5 to 2.4; range in RD for diarrhea, 3% to 9%
DPP-4 inhibitors vs. GLP-1 receptor agonists | 1 (820) | Low | Not applicable | Direct | Not evaluated | Undetected | Low | DPP-4 inhibitors favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; OR = odds ratio; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

‡ An additional article was found in clinical trials.gov which was consistent with the two other studies favoring thiazolidinediones over GLP-1 receptor agonists. Inclusion of this study may have increased our strength of evidence from low to moderate.

Table 77 Strength of evidence domains for metformin versus metformin combination comparisons in terms of gastrointestinal side effects among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + TZD | 10 (3,878) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin + TZD favored for diarrhea; Neither favored for other GI-related outcomes
Metformin vs. metformin + SU | 12 (4,317) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither drug favored for diarrhea or any GI adverse events
Metformin vs. metformin + DPP-4 inhibitors | 26 (14,324) | Low | Consistent for nausea, any GI adverse event, and vomiting; Inconsistent for all others | Direct | Precise for nausea, any GI adverse event, and vomiting for shorter studies; Imprecise for all others | Undetected | Moderate for any GI adverse event, nausea, and vomiting (shorter studies) Low for abdominal pain, diarrhea, and vomiting (longer studies) | Neither favored for shorter studies; 0.9 (0.6 to 1.3) for nausea; 0.9 (0.7 to 1.3) for any GI adverse event; 1.1 (0.6 to 2.0) for vomiting; and for abdominal pain For diarrhea, the combination was favored in the shorter studies and metformin monotherapy was favored in the longer studies For vomiting in the longer studies, metformin monotherapy was favored
Metformin vs. metformin + SGLT-2 inhibitors | 6 (2,918) | Low | Consistent | Direct | Precise | Undetected | Moderate for diarrhea; Low for nausea | Neither favored for diarrhea, 0.9 (0.5 to 1.5), Metformin favored for nausea
Metformin vs. metformin + GLP-1 receptor agonists | 4 (2,713) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 78 Strength of evidence domains for metformin-based combination comparisons in terms of gastrointestinal side effects among adults with type 2 diabetes

Comparison | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + SU | 5 (1,382) | Low | Consistent | Direct | Precise | Undetected | Moderate | Neither favored; range in OR, 0.5 to 2.0; range in RD, -5% to 2.1%
Metformin + TZD vs. metformin + DPP-4 inhibitors | 3 (747) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + TZD vs. metformin + GLP-1 receptor agonists | 1 (514) | Low | Not applicable | Direct | Imprecise | Undetected | Moderate | Metformin + TZD favored; range in OR, 2.9 to 6.3; range in RD, 8% to 19%
Metformin + SU vs. metformin + DPP-4 inhibitors (long-term studies) | 7 (8,321) | Low | Consistent | Direct | Precise | Undetected | High | Neither favored for diarrhea at 104 weeks; 1.0 (0.8 to 1.2)
Metformin + SU vs. metformin + SGLT-2 inhibitors | 3 (3,177) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + SU vs. metformin + GLP-1 receptor agonists | 3 (2,018) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin + SU favored
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 2 (946) | Medium | Not applicable | Direct | Not evaluated | Undetected | Low | No difference
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | 4 (2,891) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + DPP-4 inhibitors favored; range in OR, 1.0 to 5.1; range in RD, 0% to 23%
Metformin + GLP-1 receptor agonists vs. metformin + premixed insulin | 1 (363) | High | Not applicable | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + basal insulin vs. metformin + premixed insulin | 1 (317) | Medium | Not applicable | Direct | Imprecise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; OR = odds ratio; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Cancer

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

A single retrospective cohort study, from the England Cancer Registry, reported no difference in non-melanoma cancer risk for thiazolidinediones users (N=31,372) versus metformin users (N=109,708) (adjusted RR, 0.96; 95% CI, 0.81 to 1.13, P not reported) over 4 years of followup.255 (Not graded)

##### Metformin Versus Sulfonylureas

Four retrospective, cohort studies compared cancer outcomes for metformin and sulfonylurea users (Table 79).225, 254, 255, 266 Three studies reported no difference between metformin and sulfonylurea users.225, 255, 266 The other study only provided results stratified by statin use, indicating a possible interaction with statin use.254 (SOE: Low; Neither favored for long-term cancer risk)

Table 79 Retrospective cohort studies comparing metformin with sulfonylureas on cancer

Author, Year | Population | Followup | Outcome | Results
van Staa, 2012^255^ | England Cancer Registry [n=68,209 (sulfonylurea); n=109,708 (metformin)] | 4-5 years | Non-melanoma cancer | HR 1.03; 95% CI, 0.91 to 1.17 Reference=metformin
Andersson, 2010^225^ | Danish Patient Registry Patients with heart failure (N=5,852) | 10 years | Death from cancer | HR 1.01; 95% CI, 0.72 to 1.43 Reference=sulfonylurea
Lehman, 2012^254^ | Veterans Health Administration [n=533 (metformin-statin); n=2404 (sulfonylurea-statin); n=175 (metformin-no statin); n=1,930 (sulfonylurea-no statin)] | 270.4 weeks | Incident prostate cancer | Statin users HR 0.69; 95% CI, 0.5 to 0.92, P = 0.01 Reference=sulfonylurea Non users of statins HR 2.15; 95% CI, 1.83 to 2.52, P < 0.0001 Reference=sulfonylurea
Kowall, 2015^266^ | German Disease Analyzer (IMS Health) – primary care clinics (N=22,556) | 4.8 years | Incident cancer by ICD-10 code | Adjusted HR, 1.09; 95% CI, 0.87 to 1.36 Reference=metformin

CI = confidence interval; HR = hazard ratio; ICD-10 = International Classification of Diseases

##### Metformin Versus DPP-4 Inhibitors

Two RCTs of metformin plus placebo (N=510) versus a DPP-4 inhibitor plus placebo (N=514) evaluated cancer outcomes.85, 87 Each study reported one cancer event: one death due to pancreatic neoplasm/sepsis87 and one occurrence of esophageal cancer,85 in the metformin arms. Neither study reported on cancer in the DPP-4 inhibitor arm.85, 87 Followup ranged from 76^87^ to 104 weeks.85 (SOE: Insufficient)

##### Metformin Versus SGLT-2 Inhibitors

A single RCT (N=404) of metformin plus placebo versus dapagliflozin plus placebo, with 24 weeks of followup, reported on occurrence of cancer.88 The RCT reported no bladder cancer in either arm and a single case of breast cancer in the SGLT-2 arm; breast cancer was not reported on in the metformin arm.88 (SOE: Insufficient)

##### Thiazolidinediones Versus Sulfonylureas

A 56-week, multi-center trial in the US, including Puerto Rico, reported two events of stage IV colon cancer (2/251, 0.8%) in the sulfonylurea arm and none in the thiazolidinedione arm (0/251, 0.0%).95 (SOE: Low; Thiazolidinediones favored)

##### Sulfonylureas Versus DPP-4 Inhibitors

Two short-term RCTs compared sulfonylurea with DPP-4 inhibitor monotherapy and reported on cancer outcomes collected through passive ascertainment.106, 107 One 52-week RCT reported one case of colon cancer in the glimepiride arm (1/76, 1.3%) and did not report on cancer in the linagliptin arm (NR/151).106 The other RCT compared glipizide with sitagliptin among participants with at least moderate renal insufficiency and reported five cases of cancer in the sitagliptin arm (5/210, 2.3%) and none in the sulfonylurea arm (0/212, 0.0%), over 58 weeks of followup.107 In that study, cancer cases were chronic myeloid leukemia in a participant with baseline leukocytosis, breast cancer diagnosed after 4 days of sitagliptin initiation, lung cancer in a participant with 40 pack-years of smoking, a pancreatic mass, and a case of polycythemia vera in a participant with a germline JAK-2 mutation.107 (SOE: Insufficient)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

One RCT compared glimepiride with liraglutide and reported on cancer outcomes with 104 weeks of followup but did not report if ascertainment was active.113 Two cases of breast cancer occurred in the liraglutide 1.8 mg arm (2/251, 0.8%) and two cases of thyroid tumors (one benign thyroid neoplasm and one papillary thyroid cancer) in the liraglutide 1.2 mg arm (1/247, 0.4%); cancer outcomes were not reported on in the sulfonylurea arm (N=248).113 These events were only reported if they were considered to be possibly related to the trial drug.113 (SOE: Insufficient)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

A single RCT compared metformin (N=101) with metformin plus glimepiride (N=307) and reported no cases of thyroid cancer in either arm at 104 weeks.141 Of note, withdrawal rates were greater than 30 percent across arms, and the investigators did not use an intention-to-treat analysis. (SOE: Insufficient)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Nine RCTs compared metformin with metformin plus a DPP-4 inhibitor.85, 87, 105, 141, 142, 154, 159, 160, 162 We did not combine these studies in a meta-analysis because of lack of consistent ascertainment of and reporting on cancer outcomes; and, when reported, heterogeneous definitions of cancer outcomes (Table 80). Two studies had long-term follow up (104 weeks).85, 141 Of these, the RCT with active ascertainment reported two cases of thyroid cancer in the metformin plus DPP-4 inhibitor arm (0.7%) and none in the metformin arm (0.0%) at 104 weeks.141 Results were mixed across the other studies, with many arms not reporting on cancer outcomes. (SOE: Insufficient)

Table 80 Randomized controlled trials comparing metformin with a combination of metformin plus a DPP-4 inhibitor on cancer

Author, Year | Followup (Weeks) | Outcome | Active/Passive Ascertainment | Metformin Events/N (%) | Metformin + DPP-4 Inhibitor Events/N (%)
Ji, 2015^162^ | 14 | Pancreatic cancer | NR | 0/345 | Linagliptin 5 mg: 0/344 (0)
Wang, 2015^160^ | 24 | Gastric cancer | NR | 0/100 (0) | 1/205 (0.5)
Wang, 2015^160^ | 24
Wang, 2015^160^ | 24 | Pancreatic cancer | NR | 0/100 (0) | 0/205 (0)
Nauck, 2009^154^ | 26 | Discontinuation because of prostate cancer | Passive | NR/104 | Alogliptin 12.5 mg: 1/213 (0.5) Alogliptin 25 mg: NR/210
Nauck, 2009^154^ | 26
Nauck, 2009^154^ | 26 | Discontinuation because of endometrial cancer | Passive | NR/104 | Alogliptin 12.5 mg: 1/213 (0.5) Alogliptin 25 mg: NR/210
Nauck, 2014^159,*^ | 26 | Thyroid cancer | NR | 0/177 (0) | 0/315 (0)
Raz, 2008^142^ | 30 | Cases of cancer | Active | 3/94 (3) | 0/96 (0)
Xu, 2015^105^ | 48 | Cholangiocarcinoma | NR | 0/136 (0) | 1/142 (0.7)
Pfutzner, 2011^87^ | 76 | Death due to pancreatic neoplasm/sepsis | NR | 1/328 (0.3) | Saxagliptin 5 mg: NR/320 Saxagliptin 10 mg: NR/323
Ahren, 2014^141^ | 104 | Thyroid cancer | Active | 0/101 (0) | 2/302 (0.7)
Williams-Herman, 2010^85^ | 104 | Esophageal cancer | NR | Metformin 1000 mg: 1/182 (0.5) | Metformin 2000 mg + sitagliptin 100 mg: NR/182
Williams-Herman, 2010^85^ | 104 | Esophageal cancer | NR | Metformin 2000 mg: NR/182 | Metformin 1000 mg + sitagliptin 100 mg: NR/190

DPP-4 = dipeptidyl peptidase-4; mg = milligram; NR = not reported

* Cancer outcome at 52 weeks not reported in the metformin arm and none reported in the MET+DPP-4 arm

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Four RCTs compared metformin with metformin plus an SGLT-2 inhibitor and reported on cancer outcomes (Table 81).88, 165, 169, 170 Reporting of cancer was incomplete for many studies, and studies did not report on whether there was active ascertainment for cancer outcomes. Therefore, we did not perform a meta-analysis for this comparison (Table 81). Cancer outcomes were rare but appeared to occur at similar rates in the treatment arms; most studies were small and less than 1 year in duration. (SOE: Low; Neither favored)

Table 81 Randomized controlled trials comparing metformin with a combination of metformin plus a SGLT-2 inhibitor on cancer

Author, Year | Followup (Weeks) | Outcome | Active/Passive Ascertainment | Metformin Events/N (%) | Metformin + SGLT-2 Inhibitor Events/N (%)
Qiu, 2014^165^ | 18 | Colon cancer | NR | NR/93 | Canagliflozin 100 mg: NR/93 Canagliflozin 300 mg: 1/93 (1.1)
Henry, 2012^88^ | 24 | Bladder malignancy | NR | 0/201 (0) | 0/194 (0)
Bolinder, 2012^169^ | 50 | Prostatic cancer or prostatic adenoma | NR | 1/91 (1.1) | 1/91 (1.1)
Bolinder, 2012^169^ | 50 | Basal cell carcinoma | NR | 1/91 (1.1) | NR/91
Bolinder, 2012^169^ | 50 | Breast cancer leading to discontinuation | NR | 0/91 (0) | 1/91 (1.1)
Bailey, 2013^170^ | 102 | Unspecified adverse event (lung cancer) | NR | 1/137 (0.7) | Dapagliflozin 2.5 mg: NR/137 Dapagliflozin 5 mg: 1/137 (0.7) (bladder cancer) Dapagliflozin 10 mg: 1/135 (0.7) (breast cancer)

mg = milligram; NR = not reported; SGLT-2 = sodium-glucose co-transporter-2

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two RCTs compared metformin with metformin plus a GLP-1 receptor agonist and reported on cancer outcomes.141, 159 One trial did active surveillance for thyroid cancer and reported one case of follicular thyroid cancer in the metformin plus albiglutide arm (1/302, 0.3%) and no cases (0/101, 0.0%) in the metformin arm at 104 weeks.141 The 52-week RCT reported no cases of thyroid cancer in the metformin plus dulaglutide arms (metformin plus dulaglutide 0.75 mg/week, n=302; metformin plus dulaglutide 1.5 mg/week, n=304) and did not report on thyroid cancer in the metformin arm (n=177).159 (SOE: Low; Metformin favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

One 24-week RCT compared the combination of moderately-dosed metformin plus pioglitazone with the combination of moderately-dosed metformin plus glimepiride and reported on cancer outcomes, but whether ascertainment was active was not reported.185 A single case of prostate cancer occurred in the metformin plus glimepiride arm (1/142, 0.7%), and cancer was not reported on in the metformin plus pioglitazone arm (n=146).185 More than 20 percent of participants withdrew from each arm.185 (SOE: Insufficient)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

A single 26-week RCT compared the combination of metformin plus pioglitazone with the combination of metformin plus sitagliptin and reported on cancer outcomes; the method of ascertainment was not described.188 A single case of papillary thyroid cancer occurred in the metformin plus sitagliptin arm (1/166, 0.6%), and no events were reported in the metformin plus pioglitazone arm (0/165, 0.0%).188 More participants withdrew from the metformin plus pioglitazone arm (21%) than the metformin plus sitagliptin arm, and the investigators did not use an intention-to-treat analysis for this outcome.188 (SOE: Insufficient)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

A single 26-week RCT compared the combination of metformin plus pioglitazone with the combination of metformin plus weekly exenatide and reported on cancer outcomes; the method of ascertainment was not described.188 No cases of thyroid cancer were reported in either arm (metformin plus pioglitazone: 0/165, 0.0% and metformin plus exenatide: 0/160, 0.0%).188 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Three RCTs, with 104 weeks of followup, compared the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor and reported on cancer outcomes (Table 82).141, 194, 195 Cancer incidence was slightly higher in the metformin plus DPP-4 arms than the metformin plus sulfonylurea arms, in these 2-year trials. More than 20 percent of participants withdrew from these studies. Two of the studies used an intention-to-treat analysis.194, 195 An additional RCT with only 52 weeks of followup also reported a higher incidence of cancer in metformin plus DPP-4 inhibitor arm than in the metformin plus a sulfonylurea.193 (SOE: Low; Combination of metformin plus a sulfonylurea favored)

Table 82 Randomized controlled trials comparing a combination of metformin with a sulfonylurea with a combination of metformin plus a DPP-4 inhibitor on cancer

Author, Year | Followup (Weeks) | Outcome | Active/Passive Ascertainment | ITT Analysis | Metformin + SU Events/N (%) | Metformin + DPP-4 Inhibitor Events/N (%)
Ahren, 2014^141^ | 104 | Thyroid cancer | Active | No | 0/307 (0.0%) | 2/302 (0.7%)
Gallwitz, 2012^194^ | 104 | Prostate, breast, and colon cancer^*^ | NR | Yes | 7/775 (0.9%) | 10/776 (1.3%)
Goke, 2010^195^ | 104 | Acute myeloid leukemia | NR | Yes | NR/430 | 1/428 (0.2%)
Schernthaner, 2015^193^ | 52 | Neoplasm | NR | No | 3/360 (0.8) | 10/360 (2.8%)

DPP-4 = dipeptidyl peptidase-4; ITT = intention-to-treat; NR = not reported; SU = sulfonylurea

* Unclear if ascertained for specific types of cancer

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a SGLT-2 Inhibitor

Two RCTs compared the combination of metformin plus an sulfonylurea with the combination of metformin plus an SGLT-2 inhibitor and reported on cancer outcomes.199, 201 In one 104-week trial using passive ascertainment, the authors reported more cases of cancer (prostate cancer, n=3; breast cancer, n=1; gastric cancer, n=1; and pancreatic cancer, n=2) in the metformin plus dapagliflozin arm (7/406, 1.7%) than in the metformin plus glipizide arm (prostate cancer, basal cell skin cancer, and lung cancer; 3/408, 0.7%).199 In the other RCT (also with 104 weeks of followup), a single death due to cervical cancer was reported in the metformin plus sulfonylurea arm; the study did not report on this outcome for the metformin plus SGLT-2 inhibitor arms.201 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Two RCTs compared the combination of metformin plus glimepiride with the combination of metformin plus a GLP-1 receptor agonist and reported on cancer outcomes.53, 141 Both trials reported thyroid cancer events in the metformin plus GLP-1 receptor agonist arm.53, 141 In the study by Ahren 2014, the investigators actively ascertained for thyroid cancer with 104 weeks of followup and found no thyroid cancer in the metformin plus glimepiride arm (0/307, 0.0%) and one case in the metformin plus albiglutide arm (1/302, 0.3%).141 In the other trial (maximum followup of 3 years), which did not report on the method of ascertainment of cancer outcomes, the authors reported three cases of thyroid cancer (3/511, 0.6%) in the metformin plus exenatide arm and did not report on thyroid cancer for the metformin plus sulfonylurea arm. In that trial, the authors also reported a single case of breast cancer in the metformin plus sulfonylurea arm (1/508, 0.2%) and did not report on breast cancer for the metformin plus exenatide arm.53 (SOE: Low; Combination of metformin plus a sulfonylurea favored for long-term risk of thyroid cancer)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three short-term RCTs159, 188, 210 and one long-term RCT compared the combination of metformin plus a GLP-1 receptor agonist with the combination of metformin plus a DPP-4 inhibitor and found conflicting results on risk of thyroid cancer (Figure 85). None of the short-term studies reported active ascertainment of thyroid cancer, and one did not provide results for the intention-to-treat population.188 The long-term RCT (104 weeks) actively ascertained thyroid cancer and reported two events in the metformin plus DPP-4 arm and one event in the metformin plus GLP-1 receptor agonist arm; the authors did not evaluate this outcome in the intention-to-treat population.141

Figure 85 Pooled odds ratio of cancer events comparing the combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; Met = metformin; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of cancer events comparing the combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus a GLP-1 receptor agonist.

Withdrawal rates were high across the study arms (range, 13% to 77%) with most arms having more than 30 percent losses to followup.141, 159, 188, 210 (SOE: Low; Combination of metformin plus a GLP-1 receptor agonist favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a Basal Insulin

A single 25-week RCT compared the combination of metformin plus sitagliptin with the combination of metformin plus insulin glargine and reported two cases of cancer (Kaposi's sarcoma and prostate cancer) in the metformin plus sitagliptin arm (2/264, 0.8%) and none in the metformin plus insulin glargine arm (0/237, 0.0%).211 (SOE: Low; Combination of metformin plus a basal insulin favored)

#### Strength of Evidence for Cancer

We found low or insufficient strength of evidence on cancer outcomes for all comparisons of interest, as described in the Key Points and Table 83, Table 84, and Table 85.

Table 83 Strength of evidence domains for monotherapy comparisons and cancer outcomes among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SU | Observational: 4 (211,367) | Medium | Consistent | Direct | Imprecise | NA | Low | Neither favored
Metformin vs. DPP-4 inhibitors | RCTs: 2 (1,014) | Low | Consistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. SGLT-2 inhibitors | RCT: 1 (404) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
TZD vs. SU | RCT: 1 (502) | Medium | Unknown | Direct | Imprecise | Undetected | Low | TZD favored
SU vs. DPP-4 inhibitors | RCTs: 2 (653) | Low | Inconsistent | Direct | Imprecise | Suspected | Insufficient | Unable to determine
SU vs. GLP-1 receptor agonists | RCT: 1 (746) | Medium | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; NA = not applicable; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

Table 84 Strength of evidence domains for metformin versus metformin-based combination comparisons and cancer outcomes among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + SU | RCT: 1 (1049) | High | Unknown | Direct | Imprecise | Suspected | Insufficient | Unable to determine
Metformin vs. metformin + DPP-4 inhibitors | RCTs: 8 (6266) | Low | Inconsistent | Direct | Imprecise | Suspected | Insufficient | Unable to determine 4 RCTs did not report on events in all arms
Metformin vs. metformin + SGLT-2 inhibitors | RCTs: 4 (1610) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + GLP-1 receptor agonists | RCTs: 2 (2147) | High | Inconsistent | Direct | Imprecise | Suspected | Low | Metformin favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; NA = not applicable; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

Table 85 Strength of evidence domains for combination therapy comparisons and cancer among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + pio vs. metformin + SU | RCT: 1 (305) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + pio vs. metformin + DPP-4 inhibitors | RCT: 1 (514) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + pio vs. metformin + GLP-1 receptor agonists | RCT: 1 (514) | High | Unknown | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + DPP-4 inhibitors (long-term studies) | RCTs: 4 (4,179) | Medium | Consistent | Direct | Imprecise | Suspected | Low | Metformin + SU favored for longer-term cancer risk
Metformin + SU vs. metformin + SGLT-2 inhibitors (long-term studies) | RCT: 2 (2264) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + GLP-1 receptor agonists (long-term studies) | RCT: 2 (2,078) | High | Consistent | Direct | Imprecise | Undetected | Low | Metformin + SU favored for long-term thyroid cancer risk
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists | RCT: 4 (3,107) | High | Consistent | Direct | Imprecise | Undetected | Low | Metformin + GLP-1 receptor agonists favored
Metformin + DPP-4 inhibitor vs. metformin + basal insulin | RCT: 1 (515) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin + basal insulin favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; pio = pioglitazone; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

The major limitation of the evidence on cancer for the diabetes medication comparisons was the lack of studies. For RCTs, major study limitations included high rates of withdrawals (>20%) combined with lack of an intention-to-treat approach and lack of active ascertainment of, or reporting on, cancer outcomes. We usually could not determine consistency because of a lack of studies (i.e., one study available for a given comparison), or evidence was graded as inconsistent based on only a few studies for each comparison. The evidence on all comparisons was imprecise because of insufficient sample size for cancer outcomes.

We identified several unpublished studies that may have affected our grading of the evidence. For the comparison of sulfonylurea monotherapy and DPP-4 inhibitor monotherapy, two unpublished studies favored sulfonylurea monotherapy. These results could have moved our evidence grade from “insufficient” to “low” for this comparison and suggested that sulfonylurea monotherapy is favored over DPP-4 inhibitors. Also, addition of an unpublished study with long-term followup of the published study comparing metformin to metformin plus a sulfonylurea would have led to the conclusion that metformin is favored over the combination of metformin plus a sulfonylurea, although with low strength of evidence. The same unpublished study also provided additional results for the comparison of metformin to combination therapy with metformin and a DPP-4 inhibitor and to the combination of metformin plus a GLP-1 receptor agonist; results suggested that metformin was favored over both combination therapies. These would also have been conclusions based on low strength of evidence for both comparisons. Two unpublished studies with long-term follow up supported the published evidence that the combination of metformin plus a sulfonylurea is favored over the combination of metformin plus a DPP-4 inhibitor.

We found two additional unpublished studies of comparisons for which there were no published studies: thiazolidinedione vs. DPP-4 inhibitors and metformin plus basal insulin vs. metformin plus premixed insulin.

Finally, most evidence for the comparisons of interest included studies that did not report on cancer events in all arms. While this limited our ability to synthesize data quantitatively, we do not believe that this was a source of selective analysis reporting bias, as much as a reflection of a lack of a focus on active ascertainment and reporting of cancer outcomes.

### Evidence for Congestive Heart Failure

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

Three RCTs50, 70, 76 and two observational studies233, 243 examined heart failure for the comparison of metformin versus thiazolidinediones (Table 86). We did not conduct a meta-analysis because of differences in study duration and design. The two RCTs, each lasting less than 1 year, showed no events of heart failure in either arm.70, 76 The third RCT, the ADOPT study,50 had over 1,400 subjects in each arm with a median duration of treatment of 4 years. In this study, the investigators compared metformin with rosiglitazone on the primary outcome of time to monotherapy failure. While the study was not powered to detect differences in cardiovascular events and excluded patients with heart failure at baseline, there was no statistically significant difference between the incidence of investigator-reported heart failure in these two arms (22/1456 for rosiglitazone versus 19/1454 for metformin).50

Table 86 Studies comparing metformin with thiazolidinediones on congestive heart failure

Author, Year | Study Design | Comparison | Heart Failure Incidence (Metformin as Reference Group)
Kahn, 2006^50^ | RCT | Rosiglitazone versus metformin | 22/1456 versus 19/1454 versus; OR, 1.2 (95% CI, 0.6 to 2.3)
Erem, 2014^70^ | RCT | Pioglitazone versus metformin | 0/19 versus 0/19
Esposito, 2011^76^ | RCT | Pioglitazone versus metformin | 0/55 versus 0/55
Pantalone, 2009^233^ | Observational study | Rosiglitazone versus Metformin | HR, 1.16 (95% CI, 0.78 to 1.73)
Pantalone, 2009^233^ | Observational study | Pioglitazone versus metformin | HR, 1.38 (95% CI, 1.00 to 1.90)
Hsiao, 2009^243^ | Observational study | Rosiglitazone versus metformin | HR, 1.30 (95% CI, 0.89 to 1.89)
Hsiao, 2009^243^ | Observational study | Pioglitazone versus metformin | HR, 1.54 (95% CI, 0.65 to 3.64)

CI = confidence interval; HR = hazard ratio for thiazolidinediones with metformin as reference group; OR = odds ratio; RCT = randomized controlled trial

Two observational studies with 6 to 8 years of followup also compared metformin with thiazolidinediones.233, 243 Both studies reported point estimates suggesting harm from thiazolidinediones compared with metformin; the results were only close to statistically significant for the comparison of pioglitazone versus metformin in one of the two studies (Table 86).233 (SOE: Low; Metformin favored)

##### Metformin Versus Sulfonylureas

Two studies (one RCT and one observational study) reported on the risk of heart failure events with metformin compared with the sulfonylureas, with both point estimates favoring metformin over sulfonylureas (Table 87).231, 233 The 144-week RCT compared metformin with glipizide in adults with diabetes and a history of coronary artery disease, and reported a small, non-significant, greater number of events in the glipizide arm (10/148) compared to the metformin arm (9/156).231 Rescue therapy was insulin and was initiated in about 20 percent of each arm. The larger retrospective observational study (N=20,450) compared metformin with sulfonylurea in patients within one health care system in the United States from 1998 to 2006.^233^ After adjusting for differences in baseline patient characteristics (e.g., gender, race, age, smoking status, and medications), sulfonylureas were associated with a greater risk of heart failure than metformin.233 (SOE: Low; Metformin favored)

Table 87 Studies comparing metformin with sulfonylureas on congestive heart failure

Author, Year | Study Design | Comparison | Heart Failure Incidence (Sulfonylurea as Reference Group)
Hong, 2013^231^ | RCT | Metformin versus glipizide | HR, 0.82 (95% CI, 0.31 to 2.13)
Pantalone, 2009^233^ | Observational study | Metformin versus sulfonylurea (unspecified drug type) | HR, 0.76 (95% CI, 0.64 to 0.91)

CI = confidence interval; HR = hazard ratio for metformin with sulfonylureas as the reference group; RCT = randomized controlled trial

##### Metformin Versus DPP-4 Inhibitors

One RCT, lasting 26 weeks, compared metformin with alogliptin, with no heart failure events in either arm.84 (SOE: Low; Neither favored)

##### Thiazolidinediones Versus Sulfonylureas

Four trials49, 50, 52, 217 and two observational studies233, 243 examined heart failure outcomes for the comparison of thiazolidinediones versus sulfonylureas (Table 88), finding no clear between-group differences. A meta-analysis of the four RCTs49, 50, 52, 217 showed an increased risk of congestive heart failure with thiazolidinediones compared with sulfonylureas, which did not reach statistical significance (pooled OR, 1.62; 95% CI, 0.95 to 2.76) (Figure 86). There was no evidence of statistical heterogeneity among the included studies (I^2^ = 0%). Consistent with the meta-analysis of the RCTs, the two observational studies also showed increased risk of heart failure which did not reach statistical significance in three of the four thiazolidinedione arms compared with the sulfonylurea arms.233, 243 (SOE: Low; Sulfonylureas favored)

Table 88 Observational studies comparing thiazolidinediones with sulfonylureas on congestive heart failure

Author, Year | Study Design | Comparison | Heart Failure Incidence (Sulfonylurea as Reference Group)
Pantalone, 2009^233^ | Observational study | Rosiglitazone versus sulfonylurea | HR, 0.88 (95% CI, 0.60 to 1.31), p = 0.55
Pantalone, 2009^233^ | Observational study | Pioglitazone versus sulfonylurea | HR, 1.05 (95% CI, 0.77 to 1.43), p = 0.76
Hsiao, 2009^243^ | Observational study | Rosiglitazone versus sulfonylurea | HR, 1.22 (95% CI, 0.86 to 1.74), p = 0.26
Hsiao, 2009^243^ | Observational study | Pioglitazone versus sulfonylurea | HR, 1.37 (95% CI, 0.58 to 3.20), p = 0.46

CI = confidence interval; HR = hazard ratio

Figure 86 Pooled odds ratio of congestive heart failure events comparing thiazolidinediones with sulfonylureas

CI = confidence interval; Group 1 = sulfonylureas; Group 2 = thiazolidinediones; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of congestive heart failure events comparing thiazolidinediones with sulfonylureas.

##### Thiazolidinediones Versus DPP-4 Inhibitors

One 26-week RCT compared pioglitazone with alogliptin, reporting no heart failure events in either arm.104 (SOE: Low; Neither drug favored)

##### Sulfonylureas Versus DPP-4 Inhibitors

One 58-week RCT comparing glipizide with sitagliptin reported four of 212 patients having heart failure events in the glipizide arm compared with none of 210 patients in the sitagliptin arm.107 The only rescue therapy was insulin, which was initiated in about 10 percent of participants in each arm. (SOE: Insufficient)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Thiazolidinedione

Three RCTs, lasting from 26 to 80 weeks, compared metformin alone with the combination of metformin plus a thiazolidinedione, showing a small, non-significant, greater number of heart failure events in the metformin plus thiazolidinedione arms in two of the three studies (Table 89).116, 126, 127 (SOE: Low; Metformin favored)

Table 89 Randomized controlled trials comparing metformin with a combination of metformin plus a thiazolidinedione on congestive heart failure

Author, Year | Study Design | Comparison | Heart Failure Incidence
Leiter, 2005^116^ | RCT | Metformin versus metformin plus rosiglitazone | 0/78 versus 0/158
Borges, 2011^127^ | RCT | Metformin versus metformin plus rosiglitazone | 0/334 versus 1/344
DeFronzo, 2012^126^ | RCT | Metformin versus metformin plus pioglitazone | NR/129 versus 1/129

RCT = randomized controlled trial

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Four 26-week RCTs lasting 24 to 26 weeks compared metformin alone with the combination of metformin plus a DPP-4 inhibitor, showing no significant increased risk of heart failure in either arm.84, 126, 154, 160 Two RCTs reported no events in either arm.84, 160 One RCT reported no events in the combination arm but did not report on events in the metformin monotherapy arm.126 The third RCT reported one event in the combination arm and did not report on events in the metformin monotherapy arm.154 We combined these four RCTs in a meta-analysis, using zero events for the arms where no data were reported, and found no significant increased risk of heart failure between groups (pooled OR, 1.5; 95% CI, 0.06 to 37) (Figure 87).84, 126, 154, 160 (SOE: Low; Neither favored)

Figure 87 Pooled odds ratio of congestive heart failure events comparing metformin with a combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin; Group 2 = combination of metformin plus a dipeptidyl peptidase-4 inhibitor; OR = odds ratio

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of congestive heart failure events comparing metformin with a combination of metformin plus a DPP-4 inhibitor.

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

One 24-week RCT comparing metformin plus pioglitazone with metformin plus glipizide reported two of 146 patients with heart failure events in the metformin plus pioglitazone arm and did not report whether there were any events in the 142 patients in the metformin plus glipizide arm.185 (SOE: Insufficient)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One 26-week RCT comparing different doses of metformin plus pioglitazone with different doses of metformin plus alogliptin reported two heart failure events in the 258 patients in the metformin plus pioglitazone arms and did not report on heart failure events in the metformin plus alogliptin arms.126 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One double-blind moderately-sized 52-week RCT compared fixed dose metformin plus titration of glimepiride (mean dose 3.3 mg) with fixed dose metformin plus fixed dose saxagliptin (5 mg daily) in adults 65 years or older.193 They reported six heart failure events (1.7%) in the metformin plus glimepiride arm compared with three events (0.8%) in the metformin plus saxagliptin arm. The study had about 20 percent loss to followup in each arm. (SOE: Insufficient)

##### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

In a RCT that compared a combination of insulin glargine daily plus metformin with a combination of insulin lispro 75/25 plus metformin, hospitalization due to heart failure was reported in a single patient on the insulin lispro 75/25 and metformin combination.223 (SOE: Insufficient)

#### Strength of Evidence for Congestive Heart Failure

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 90, Table 91, and Table 92 and summarized in the key points. Most studies were RCTs, although five medium-quality observational studies were included. Study limitations for all comparisons were low or medium. In general, we did not find strong differences in outcomes in the lower- versus higher-quality studies. However, many comparisons only had one or two studies, making these quality comparisons difficult. We did not find any evidence of publication bias in any of the comparisons for congestive heart failure. We also did not find any evidence of publication bias or reporting bias in the grey literature review, which would substantially alter our findings (Appendix E). Three studies reported events in one arm only; therefore, we were unable to draw firm conclusions from those studies. While this raises concerns for reporting bias, we expect arms with reporting on this outcome are likely to be the arms where more events occurred. For instance, two of the three studies reported the congestive heart failure events in the thiazolidinedione arms. However, this inconsistent reporting remains problematic.

Table 90 Strength of evidence domains for monotherapy comparisons in terms of congestive heart failure among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD (shorter studies) | RCTs: 2 (170) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither drug arm favored
Metformin vs. TZD (longer studies) | RCTs: 1(4360) | Medium | Consistent with observational studies | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin vs. TZD (longer studies) | Obs: 2 (65,237) | Medium | Consistent with RCT | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin vs. SU | RCT: 1 (304) | Low | Consistent with observational study | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin vs. SU | Obs: 1 (17,863) | Medium | Consistent with RCT | Direct | Precise | Undetected | Low | Metformin favored
Metformin vs. DPP-4 inhibitors | RCT: 1 (784) | Medium | Unable to determine | Direct | Imprecise | Undetected | Low | Neither drug favored
TZD vs. SU | RCTs: 4 (11,130) | Low | Consistent | Direct | Imprecise | Undetected | Low | SU favored
TZD vs. SU | Obs: 2 (116,625) | Medium | Consistent | Direct | Imprecise | Undetected | Low | SU favored
TZD vs. DPP-4 inhibitors | RCT: 1 (655) | Low | Unable to determine | Direct | Imprecise | Undetected | Low | Neither drug favored
SU vs. DPP-4 inhibitors | RCT: 1 (426) | Low | Unable to determine | Direct | Imprecise | Suspected | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; Obs = observational study; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 91 Strength of evidence domains for monotherapy versus metformin-based combination comparisons in terms of congestive heart failure among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + TZD | RCT: 3 (2947) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin vs. metformin + DPP-4 inhibitors | RCT: 4 (3170) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither drug arm favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; RCT = randomized controlled trial; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

Table 92 Strength of evidence domains for metformin-based combination comparisons in terms of congestive heart failure among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + SU | RCT: 1 (305) | Medium | Unable to determine | Direct | Imprecise | Suspected^‡^ | Insufficient | Unable to determine
Metformin + TZD vs. metformin + DPP-4 inhibitors | RCT: 1 (1554) | Medium | Unable to determine | Direct | Imprecise | Suspected^‡^ | Insufficient | Unable to determine
Metformin + SU vs. metformin + DPP-4 inhibitors | RCT: 1 (720) | Low | Unable to determine | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + basal insulin vs. metformin + premixed insulin | RCT: 1 (105) | Medium | Unable to determine | Direct | Imprecise | Suspected^‡^ | Insufficient | Unable to determine

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; RCT = randomized controlled trial; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

‡ Reporting bias was listed as suspected for each of these comparisons, because they did not report events in one of the study arms; however, the arm where the event was not reported is often in the drug arm where one might anticipate that there is likely to be no events.

### Evidence for Liver Injury

#### Monotherapy Comparisons

##### Metformin Versus Thiazolidinediones

Three RCTs comparing metformin with thiazolidinediones reported on liver injury. Two studies compared metformin with pioglitazone,62, 70 and one study compared metformin with rosiglitazone.74 Followup and liver injury definitions varied across studies, and results were mixed. All studies targeted at least 2,000 mg daily in their metformin arms, and doses of thiazolidinediones varied (Table 93). The longer studies were of poorer quality and did not find differences in liver injury between arms. The shortest and largest RCT was a high-quality trial which used the highest doses of the drugs (metformin 2,550 daily maximum dose and pioglitazone 45 mg daily maximum dose) and found more liver injury in the metformin than the pioglitazone arm. (SOE: Low; Neither favored)

Table 93 Randomized controlled trials comparing metformin with thiazolidinediones on liver injury

Author, Year | Study Size (Total N) | Followup | TZD | Definition of Liver Injury | Metformin Events/N (%) | TZD Events/N (%)
Yoon, 2011^74^ | 349 | 48 weeks | Rosiglitazone 5.9 mg daily (mean) | Abnormal liver function not defined | 0/114 (0) | 1/117 (0.85%)
Erem, 2014^70^ | 60 | 48 weeks | Pioglitazone started at 15 mg daily (most participants on ≤30 mg daily at end) | Liver enzymes > 2 times ULN | 0/13 (0) | 0/12 (0)
Schernthaner, 2004^62^ | 1,199 | 26 weeks | Pioglitazone started at 30 mg daily; 45 mg daily (maximum) | Liver enzymes > 3 times ULN | 2.2% | 0.9%

mg = milligrams; TZD = thiazolidinedione; ULN = upper limit normal

##### Metformin Versus Sulfonylureas

Two RCTs compared metformin with sulfonylureas and reported on liver injury.50, 74 Neither study provided a specific definition of liver injury, and both studies used sub-maximal doses of the sulfonylurea and comparable doses of metformin (titration to maximum of 2,000 mg daily). ADOPT, the study with long-term followup, found similar rates of liver injury in the two arms,50 and the other study reported more liver abnormalities in the sulfonylurea arm (Table 94).74 (SOE: Low; Neither favored)

Table 94 Randomized controlled trials comparing metformin with sulfonylureas on liver injury

Author, Year | Study Size (Total N) | Followup | SU | Definition of Liver Injury | Metformin Events/N (%) | SU Events/N (%)
Kahn, 2006^50^ ADOPT Study | 4360 | Not reported^*^ | Glyburide; started 2.5 mg; maximum 15 mg | Not defined | NR/1341 (1.1) | NR/1441 (0.8)
Yoon, 2011^74^ | 349 | 48 weeks | Glimepiride 4.5 mg daily (mean) | Abnormal liver function not defined | 0/114 (0) | 5/118 (4.24%); P = 0.05

ADOPT = A Diabetes Outcome Progression Trial; mg = milligrams; NR = not reported; SU = sulfonylurea

* Study was 6.1 years in duration, but followup for this outcome was not reported.

##### Thiazolidinediones Versus Sulfonylureas

Three RCTs comparing thiazolidinediones with sulfonylureas reported on liver injury.50, 52, 74 Followup and liver injury definitions varied (Table 95).

Table 95 Randomized controlled trials comparing thiazolidinediones with sulfonylureas on liver injury

Author, Year | Study Size (Total N) | Followup | TZD | SU | Definition of Liver Injury | TZD Events/N (%) | SU Events/N (%)
Kahn, 2006^50^ ADOPT Study | 4360 | Not reported^*^ | Rosiglitazone 8 mg (maximum) | Glyburide 15 mg daily (maximum) | Not defined | 0/1456 (0%) | 0/1441 (0%)
Yoon, 2011^74^ | 349 | 48 weeks | Rosiglitazone 5.9 mg daily (mean) | Glimepiride 4.5 mg daily (mean) | Abnormal liver function not defined | 1/117 (0.85%) | 5/118 (4.2%); P = 0.05
Tolman, 2009^52^ | 2120 | 24 weeks | Pioglitazone 45 mg daily (maximum) | Glyburide 15 mg daily (maximum) | Liver enzymes > 3 times ULN with confirmation | 0/1051 (0%) | 4/1046 (0.4%) P =0.06

ADOPT = A Diabetes Outcome Progression Trial; mg = milligrams; SU = sulfonylurea; TZD = thiazolidinedione; ULN = upper limit of normal

* Study was 6.1 years in duration, but followup time for this outcome was not reported

One study reported an non-significant increased risk of liver injury for sulfonylurea versus submaximal rosiglitazone,74 and the other two RCTs did not find substantial differences in livery injury between arms.50, 52 Of note, the highest-quality, largest and longest study reported no liver toxicity in either arm.50 (SOE: Low; Neither favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

One RCT examined liver injury (defined as hepatobiliary disorders) as an adverse event for this comparison.110 Seven of 132 participants treated with submaximally-dosed glibenclamide (fixed dose of 1.25 to 2.5 mg daily) developed liver injury at 52 weeks compared with 11 participants of 268 treated with liraglutide titrated to a maximum of 0.9 mg daily (5.3% versus 4.1%).110 (SOE: Low; Neither favored)

#### Metformin Versus Metformin-Based Comparisons

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Four RCTs compared metformin with the combination of metformin plus a DPP-4 inhibitor.146, 152, 160, 164 Followup and liver injury definitions varied (Table 96). In the longest study (52 weeks), both treatments were associated with similar rates of hepatic adverse events (not specified), at a dose of metformin 1000 mg/day.164 In the shorter studies (12 to 24 weeks), which used higher doses of metformin (1500 mg/day), events were rare, and occurred slightly more often in the metformin plus DPP-4 inhibitor arms.146, 152, 160 Overall, the lack of clarity on the definition of liver injury precluded conclusions on this outcome for this comparison. (SOE: Insufficient)

Table 96 Randomized controlled trials comparing metformin with metformin plus DPP-4 inhibitors on liver injury

Author, Year | Study Size (Total N) | Followup | DPP-4 Inhibitor | Definition of Liver Injury | Metformin Events/N (%) | Metformin + DPP-4 Inhibitor Events/N (%)
Haak, 2013^164^ | 567 | 52 weeks | Linagliptin 5 mg daily | Unspecified hepatic adverse events | 13 /170 (7.6%) | 11/171 (6.4%)
Wang, 2015^160^ | 305 | 24 weeks | Linagliptin 5 mg dialy | Alanine transaminase increase considered to be drug-related | 0/100 (0%) | 1/205 (0.5%)
Ross, 2012^152^ | 491 | 12 weeks | Linagliptin 5 mg daily | Unspecified elevation of liver enzymes | 0/44 (0%) | 2/224 (0.9%)
Yang, 2011^146^ | 570 | 24 weeks | Saxagliptin 5 mg daily | Abnormal liver function | 0/142 (0%) | 1/146 (0.6%)

DPP-4 = dipeptidyl peptidase-4; mg = milligrams

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

One RCT examined liver injury (defined as hepatic impairment) as an adverse event for the comparison of metformin versus a combination of metformin plus a SGLT-2 inhibitor.168 None of the 101 participants treated with metformin nor the 199 participants treated with either 5 or 10 mg of canagliflozin developed liver injury at 20 weeks. (SOE: Low; Neither favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

Two RCTs compared the combination of metformin plus a thiazolidinedione with the combination of metformin plus a sulfonylurea and reported on liver injury.179, 185 One trial reported no cases of liver injury (defined as hepatic failure) in the metformin plus pioglitazone arm (0/146; 0%) and one case in the metformin plus glimepiride arm (1/142; 0.7%), at 24 weeks.185 A smaller 48-week trial reported no cases of liver injury (defined as liver enzymes values greater than three times the upper limit of normal) in the metformin plus rosiglitazone (0/48) or metformin plus glimepiride (0/47) arms.179 (SOE: Insufficient)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

A single RCT examined liver injury (defined as alanine aminotransferase or aspartate aminotransferase values greater than three times the upper limit of normal) as an adverse event for the comparison of a combination of metformin plus a sulfonylurea versus a combination of metformin plus a SGLT-2 inhibitor.201 Three of 482 (0.6%) participants treated with glimepiride (mean daily dose 5.6 mg) developed liver injury (alanine aminotransferase values greater than three times the upper limit of normal) at 104 weeks compared with six of 483 (1.3%) treated with 100 mg canagliflozin and seven of 485 (1.5%) treated with 300 mg canagliflozin. Two participants (0.4%) in the glimepiride arm, five participants (1.1%) in the 100 mg canagliflozin arm, and three participants (0.6%) in the 300 mg canagliflozin arm had aspartate aminotransferase values greater than three times the upper limit of normal. (SOE: Low; Neither favored)

#### Strength of Evidence for Liver Injury

We found low strength of evidence for the monotherapy comparisons for which there was evidence on liver injury and insufficient evidence for all combination therapy comparisons for this outcome (Table 97). The evidence was limited by a small number of studies with a high risk of bias based on assessment of randomization, masking, and withdrawals. Studies addressing liver injury were generally small and did not use maximal dosing of medications, especially for the non-metformin arms. Also, heterogeneity in definitions of liver injury (or lack of reporting specific definitions) limited the strength of evidence and our ability to make conclusions. A single unpublished study supported findings that neither the combination of metformin plus a sulfonylurea or the combination of metformin plus an SGLT-2 inhibitor were favored for liver injury.

Table 97 Strength of evidence domains for comparisons in terms of liver injury among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. TZD | 3 (1608) | High | Inconsistent | Indirect | Imprecise | Undetected | Low | Neither favored
Metformin vs. SU | 2 (4709) | High | Inconsistent | Indirect | Imprecise | Undetected | Low | Neither favored
TZD vs. SU | 3 (6829) | Medium | Inconsistent | Indirect | Imprecise | Undetected | Low | Neither favored
SU vs. GLP-1 receptor agonists | 1 (400) | High | Unknown | Indirect | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + DPP-4 inhibitors | 4 (1933) | Low | Unknown | Indirect | Imprecise | Undetected | Insufficient | Unable to determine
Metformin vs. metformin + SGLT-2 inhibitors | 1 (299) | Low | Unknown | Indirect | Imprecise | Undetected | Low | Neither favored
Metformin + TZD vs. metformin +SU | 2 (723) | High | Inconsistent | Indirect | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + SGLT-2 inhibitors (long-term study) | 1 (1450) | Medium | Unknown | Indirect | Imprecise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Lactic Acidosis

#### Monotherapy Comparisons

##### Metformin Versus Sulfonylureas

We identified two short RCTs (lasting 18 and 16 weeks) reporting the rates of lactic acidosis for metformin and sulfonylureas. These RCTs reported no cases of lactic acidosis in any of the treatment arms.130, 131 (SOE: Low; Neither favored)

#### Metformin Versus Metformin-Based Comparisons

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

We identified two RCTs (lasting 18 and 16 weeks) reporting the rates of lactic acidosis for metformin and the combination of metformin and a sulfonylurea. These RCTs reported no cases of lactic acidosis in any of the treatment arms.130, 131 (SOE: Low; Neither favored)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One 12-week RCT reported that increased lactic acid blood levels were more frequent in participants treated with metformin alone (3/100; 3%) than in those treated with the combined regimen of metformin with alogliptin (1/96; 1%); the study did not provide a statistical comparison of these rates.157 Of note, metformin doses were very small in this study (500 to 750 mg daily). (SOE: Insufficient)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a Sulfonylurea

One 24-week RCT compared the rates of lactic acidosis between the combination of metformin and pioglitazone and the combination of metformin and glimepiride. One case of lactic acidosis was reported in the 142 participants (0.7%) receiving metformin plus glimepiride and none were reported in the 146 participants (0%) who received metformin plus pioglitazone.185 Of note, the participant with lactic acidosis was noted to have had multiple serious adverse events including heart failure, liver failure, renal failure, and electrolyte disturbances. (SOE: Low; Combination of metformin plus a thiazolidinedione favored)

#### Strength of Evidence for Lactic Acidosis

Few studies addressed lactic acidosis, and evidence was of low strength or insufficient when present (Table 98). The evidence was at low or medium risk of bias, and studies were small and brief in duration; thus the evidence was imprecise and consistency unknown. One of the four studies addressing lactic acidosis only reported on elevated blood levels of lactic acidosis and not on the clinical syndrome of lactic acidosis.

Table 98 Strength of evidence domains for comparisons in terms of lactic acidosis among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SU | 2 (886) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + SU | 2 (886) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + DPP-4 inhibitors | 1 (288) | Low | Unknown | Indirect | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + TZD vs. metformin +SU | 1 (288) | High | Unknown | Direct | Imprecise | Undetected | Low | Metformin + TZD favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Pancreatitis

#### Monotherapy Comparisons

##### Metformin Versus DPP-4 Inhibitors

A 26-week trial compared metformin (1,000 mg daily; n=109), metformin (2,000 mg daily; n=111), and alogliptin (25 mg daily; n=112) and actively ascertained for pancreatitis and found no cases of pancreatitis in these arms.84 (SOE: Low; Neither favored)

##### Metformin Versus GLP-1 Receptor Agonists

A 52-week RCT that compared metformin with dulaglutide reported no cases of pancreatitis (defined as a lipase increase higher than three times the upper limit) in any of the 268 participants receiving metformin or the 269 participants receiving dulaglutide.91 (SOE: Low; Neither favored)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

A single RCT compared pioglitazone (maximum tolerated dose up to 45 mg/day) with exenatide titrated to 10 μg twice daily and reported no cases (0/136, 0%) of pancreatitis in the pioglitazone arm and a single case (1/142, 0.7%) in the exenatide arm at 48 weeks.105 Pancreatitis was not defined, and the method of ascertainment was not reported.105 (SOE: Low; Pioglitazone favored)

##### Sulfonylureas Versus DPP-4 Inhibitors

We identified one RCT comparing the incidence of pancreatitis between sulfonylurea and DPP-4 inhibitors at 52 weeks.106 There were no cases of pancreatitis in any of the 76 participants receiving glimepiride or the 151 participants receiving linagliptin. The definition of pancreatitis was unspecified. (SOE: Low; Neither favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

Two RCTs compared sulfonylureas with GLP-1 receptor agonists and reported on pancreatitis.109, 112 One trial reported two cases of pancreatitis in the liraglutide arm (2/498; 0.4%) and no cases in the glimepiride arm (0/248; 0%) at 104 weeks.112 A 24-week trial reported no cases of pancreatitis in the liraglutide (n=272) or glibenclamide (n=139) arms.109 The criteria for a diagnosis of pancreatitis was unspecified in both studies. (SOE: Low; Sulfonylureas favored)

##### DPP-4 Inhibitors Versus GLP-1 Receptor Agonists

A 26-week RCT that compared liraglutide (n = 446) with sitagliptin (n = 219) reported no episodes of pancreatitis.210 The definition of pancreatitis was unspecified. (SOE: Low; Neither favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

A single RCT with long-term followup compared the incidence of pancreatitis with metformin to the combination of metformin plus a sulfonylurea.141 There were no cases of pancreatitis, at 104 weeks of followup, among the 100 participants who received monotherapy or the 302 participants who received combined therapy. Criteria for pancreatitis was enzymatic elevation at three times the upper limit plus clinical symptoms. (SOE: Low; Neither favored)

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

We identified 11 RCTs comparing the incidence of pancreatitis with metformin with the combination of metformin plus a DDP-4 inhibitor.51, 84, 141, 151, 152, 157, 159, 160, 162, 164, 256 Definitions of pancreatitis and duration of followup differed across studies (Table 99). Four RCTs did not describe active ascertainment of pancreatitis,51, 160, 164, 256 and three RCTs had substantial losses to followup.51, 84, 141 Pancreatitis was rare, with events in only three of the 11 studies. In the study of longer duration, rates of pancreatitis were similar (0.6%) across arms at 52 weeks.159 Events were reported in only the metformin plus DPP-4 inhibitor arms in the two shorter studies.84, 162 (SOE: Low; Neither favored)

Table 99 Randomized controlled trials comparing metformin with a combination of metformin plus a DPP-4 inhibitor on pancreatitis

Author, Year | Study Size | Followup | DPP-4 Inhibitor | Definition of Pancreatitis | Metformin Events/N | DPP-4 Inhibitor Events/N
Bergenstal, 2012^51^ | 666 | 156 weeks | Sitagliptin 100 mg daily | Unspecified | 0/93 | 0/184
Ahren, 2014^141^ | 1049 | 104 weeks | Sitagliptin 100 mg daily | Enzymes elevation > 3ULN + clinical symptoms Adjudicated | 0/100 | 0/299
Nauck, 2014^159^ | 1098 | 52 weeks | Sitagliptin 100 mg daily | Enzymes elevation > 3ULN + clinical symptoms Adjudicated | 1/177 (0.6%) | 2/315 (0.6%)
Skrivanek, 2014^256^ | 230 | 26 weeks | Sitagliptin 100 mg daily | Unspecified elevation of enzymes | 0/38 | 0/42
Pratley, 2014^84^ | 784 | 26 weeks | Alogliptin 25 mg daily | Unspecified elevation of enzymes | 0/222 | 2/220 (0.9%) 1 case confirmed
Seino, 2012^157^ | 288 | 12 weeks | Alogliptin 12.5 or 25 mg daily | Unspecified | 0/100 | 12.5 mg: 0/92 25 mg: 0/96
Haak, 2013^164^ | 567 | 52 weeks | Linagliptin 5 mg | Clinical diagnosis | 0/170 | 0/396
Wang, 2015^160^ | 305 | 24 weeks | Linagliptin 5 mg | Unspecified | 0/100 | 0/205
Ji, 2015^162^ | 689 | 14 weeks | Linagliptin 5 mg | Unspecified | 0/345 | 1/344 (0.3%)
Ross, 2012^152^ | 491 | 12 weeks | Linagliptin 5 mg | Unspecified | 0/44 | 0/447
White, 2014^151^ | 160 | 12 weeks | Saxagliptin 5 mg | Unspecified | 0/78 | 0/66

DPP-4 = dipeptidyl peptidase-4; mg = milligrams; ULN = upper limit of normal

##### Metformin Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

Three RCTs compared the incidence of pancreatitis with metformin and the combination of metformin plus a GLP-1 receptor agonist (Table 100).141, 159, 256 The longest study actively ascertained for pancreatitis but had substantial losses to followup. In this study with 104 weeks of followup, two cases of pancreatitis were reported in the metformin plus GLP-1 receptor agonist arm (2/296, 0.7%) and none were reported in the metformin arm (0/100, 0%).141 Results from the other two RCTs, which were brief in duration, were mixed. One reported no pancreatitis in either arm at 26 weeks but did not report on active ascertainment,256 and the other reported a single case of pancreatitis in the metformin monotherapy arm and no cases of pancreatitis in the combination arm and did actively ascertain for pancreatitis.159 (SOE: Low; Metformin favored)

Table 100 Randomized controlled trials comparing metformin with a combination of metformin plus a GLP-1 receptor agonist on pancreatitis

Author, Year | Study Size (Total N) | Followup | GLP-1 Receptor Agonist | Definition of Pancreatitis | Metformin Events/N (%) | DPP-4 inhibitor Events/N
Skrivanek, 2014^256^ | 230 | 26 weeks | Dulaglutide 0.75, 1.0, and 1.5 mg weekly | Unspecified elevation of enzymes | 0/38 | 0.75 mg: 0/21 1.0 mg: 0/10 1.5 mg: 0/25
Nauck, 2014^159^ | 1098 | 52 weeks | Dulaglutide 0.75 and 1.5 mg weekly | Enzymes elevation > 3ULN + clinical symptoms Adjudicated | 1/177 (0. 5%) | 0.75 mg: 0/302 1.5 mg: 0/304
Ahren, 2014^141^ | 1049 | 104 weeks | Albiglutide 50 mg weekly (maximum) | Enzymes elevation > 3ULN + clinical symptoms Adjudicated | 0/100 | 2/296 (0.7%)

DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; mg = milligrams; ULN = upper limit of normal

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a DPP-4 Inhibitor

The 26-week DURATION-2 RCT reported two cases of pancreatitis in the 165 participants who were treated with the metformin plus pioglitazone (2/165, 1.2%) combination compared with none of the 166 participants who received the metformin plus sitagliptin combination (0/166, 0%).188 Pancreatitis was not actively ascertained, and criteria for diagnosis were unspecified; this study had differential losses to followup across the arms (metformin plus thiazolidinedione, 21%; metformin plus DPP-4 inhibitor, 13%). (SOE: Low; Combination of metformin plus a DPP-4 inhibitor favored for short-term risk of pancreatitis)

##### Combination of Metformin Plus a Thiazolidinedione Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

The DURATION-2 RCT described above had an additional arm with 160 participants who received metformin plus weekly exenatide, and none were reported to have pancreatitis during the study.188 Again, two of 165 participants had pancreatitis in the metformin plus thiazolidinedione arm; pancreatitis was not actively ascertained, and criteria for diagnosis were unspecified. This study had large losses to followup across the arms (21% in both the metformin plus thiazolidinedione and metformin plus exenatide arms).188 (SOE: Low; Combination of metformin and GLP-1 receptor agonist favored for short-term risk of pancreatitis)

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

We identified four RCTs which compared the incidence of pancreatitis for the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor.193-195, 197 Event rates were low in both arms across studies. Results were inconsistent across the studies of longer duration (104 weeks) and across the shorter studies (52 weeks) (Table 101, Figure 88). Only one study reported active ascertainment of pancreatitis,197 and losses to followup were substantial in all four studies.193-195, 197 (SOE: Insufficient for long-term and short-term risk)

Table 101 Randomized controlled trials comparing the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor for pancreatitis

Author, Year | Study Size (Total N) | Followup | SU | DPP-4 Inhibitor | Definition of Pancreatitis | SU Events/N (%) | DPP-4 Inhibitor Events/N
Del Prato, 2014^197^ | 2620 | 104 weeks | Glipizide 5 mg mean daily dose | Alogliptin 12.5 or 25 mg arms | Confirmed by laboratory and imaging tests (not defined) | 3/869 (0.3%) | Alogliptin 12.5 mg: 0/873 (0%) Alogliptin 25 mg: 1/878 (0.1%)
Goke, 2010^195^ | 858 | 52 weeks | Glipizide 14.7 mg mean daily dose | Saxagliptin 5 mg daily | Not defined | 1/428 (0.2%) | 0/430 (0%)
Gallwitz, 2012^194^ | 1552 | 104 weeks | Glimepiride 3 mg mean daily dose | Linagliptin 5 mg daily | Not defined | 0/775 (0%) | 1/776 (0.1%)
Schernthaner, 2015^193^ | 718 | 52 weeks | Glimepiride 3.3 mg mean daily dose | Saxagliptin 5 mg daily | Not defined | 0/359 (0%) | 0/359 (0%)

DPP-4 = dipeptidyl peptidase-4; mg = milligrams; SU = sulfonylurea

Figure 88 Odds ratio of pancreatitis comparing the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor

CI = confidence interval; DPP-4 = dipeptidyl peptidase-4; Group 1 = metformin plus a sulfonylurea; Group 2 = metformin plus a DPP-4 inhibitor; Met = metformin; OR = odds ratio; SU = sulfonylurea

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Pooled odds ratio of pancreatitis comparing the combination of metformin plus a sulfonylurea with the combination of metformin plus a DPP-4 inhibitor.

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

We identified two relevant RCTs.53, 204 A 104-week RCT comparing metformin plus glimepiride (N=508) versus metformin plus exenatide (N = 511) reported one case of pancreatitis in each arm (0.2% in each arm).53 A 16-week RCT comparing metformin plus glimepiride (N=231) versus metformin plus liraglutide (N = 467) reported no cases of pancreatitis in either arm.204 Studies did not report active ascertainment of pancreatitis, and the criteria for pancreatitis diagnosis were unspecified. (SOE: Low; Neither favored)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

A single RCT (N=355), with 24 weeks of followup, reported no cases of pancreatitis for metformin plus saxagliptin or metformin plus dapagliflozin.209 Pancreatitis was not defined, and the method of ascertainment was not described.

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Receptor Agonist

The 26-week DURATION-2 RCT reported no cases of pancreatitis in either the metformin plus weekly exenatide (n=160) or metformin plus sitagliptin arm (n=166). Pancreatitis was not actively ascertained, and criteria for diagnosis of pancreatitis were unspecified. This study had differential losses to followup across the arms (metformin plus GLP-1 receptor agonist, 21%; metformin plus DPP-4 inhibitor, 13%).188 (SOE: Low; Neither favored for short-term pancreatitis risk)

#### Strength of Evidence for Pancreatitis

The published evidence on the comparative safety of the medications of interest was of low-strength or insufficient (Table 102, Table 103, and Table 104). The evidence was mainly limited by a lack of studies and further limited by the short duration of studies and low (expected) event rates. All evidence came from RCTs but tended to be at medium to high risk of bias, mainly because of the availability of only a few fair- to poor-quality studies for each comparison. Consistency tended to be indeterminate because of a lack of more than one study for many comparisons. All evidence was direct, although active ascertainment and definitions were not usually provided in studies. The small number of studies and their small sample sizes contributed to the evidence being imprecise for all comparisons for which we had studies. We identified unpublished studies which could have affected our grading of the evidence, but the evidence would likely only have been strengthened to a rating of low. One unpublished study confirmed the findings of the single published study that thiazolidinediones are favored over GLP-1 receptor agonists for pancreatitis. Two unpublished studies with long-term followup would have likely supported a conclusion of metformin plus a DPP-4 inhibitor being favored over metformin plus a sulfonylurea regarding long-term pancreatitis risk with low strength of evidence. One of these unpublished studies with long-term followup suggested increased risk of pancreatitis (long-term) for metformin plus a GLP-1 receptor agonist compared with metformin plus a DPP-4 inhibitor; this was in contrast to the single published study that suggested no difference in short-term risk of pancreatitis.

Table 102 Strength of evidence domains for monotherapy comparisons in terms of pancreatitis among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. DPP-4 inhibitors | 1 (784) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. GLP-1 receptor agonists | 1 (495) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
TZD vs. GLP-1 receptor agonists | 1 (278) | High | Unknown | Direct | Imprecise | Suspected | Low | TZD favored
SU vs. DPP-4 inhibitors | 1 (227) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
SU vs. GLP-1 receptor agonists | 2 (1210) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | SU favored
DPP-4 inhibitors vs. GLP-1 receptor agonists | 1 (661) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

Table 103 Strength of evidence domains for metformin monotherapy versus metformin-based combination comparisons in terms of pancreatitis among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + SU (long-term study) | 1 (1049) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin vs. metformin + DPP-4 inhibitors (long-term and short-term studies) | 11 (6327) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored for long-term or short-term pancreatitis risk
Metformin vs. metformin + GLP-1 receptor agonists | 3 (2377) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Metformin favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

Table 104 Strength of evidence domains for metformin-based combination comparisons in terms of pancreatitis among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin + TZD vs. metformin + DPP-4 inhibitors | 1 (491) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin + DPP-4 inhibitor favored for short-term risk of pancreatitis
Metformin + TZD vs. metformin + GLP-1 receptor agonists | 1 (491) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Metformin + GLP-1 receptor agonist favored for short-term risk of pancreatitis
Metformin + SU vs. metformin + DPP-4 inhibitors (longer duration studies) | 2 (4172) | High | Inconsistent | Direct | Imprecise | Suspected | Insufficient | Unable to determine for long-term risk of pancreatitis
Metformin + SU vs. metformin + DPP-4 inhibitors (shorter duration study) | 2 (1576) | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + SU vs. metformin + GLP-1 receptor agonists | 2 (2481) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors (shorter duration study) | 1 (355) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored
Metformin + DPP-4 inhibitors vs. metformin + GLP-1 receptor agonists (short duration study) | 1 (491) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither treatment favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† Unless otherwise specified, the estimates are the pooled odds ratio (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

We identified an unpublished study comparing thiazolidinediones to DPP-4 inhibitors, a comparison for which we had no published evidence.

### Evidence for Severe Allergic Reactions

#### Monotherapy Comparisons

##### Metformin Versus GLP-1 Receptor Agonists

A single 52-week RCT (N=495) that compared metformin with dulaglutide reported no systemic hypersensitivity reaction in either arm.91 (SOE: Low; Neither favored)

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

A single RCT (N=278) that compared pioglitazone with exenatide reported no systemic hypersensitivity reaction in either arm at 48 weeks of followup.105 (SOE: Low; Neither favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Four RCTs compared the incidence of severe allergic reactions between metformin and the combination of metformin plus a DDP-4 inhibitor (Table 105).146, 151, 152, 164 Heterogeneity in definitions of severe allergic reactions and duration of followup precluded a meta-analysis. Three of the four RCTs reported slightly higher rates of hypersensitivity reaction events in the metformin plus DPP-4 inhibitor versus the metformin monotherapy arms.

Table 105 Randomized controlled trials comparing metformin with a combination of metformin plus a DPP-4 inhibitor on severe allergic reactions

Author, Year | Sample Size (Total N) | Followup | DPP-4 Inhibitor | Definition of Severe Allergic Reaction | Active Asc. | Metformin Events/N (%) | DPP-4 Inhibitor Events/N (%)
Haak, 2013^164^ | 567 | 54 weeks | Linagliptin 5 mg | Hypersensitivity reactions (e.g., angioedema, anaphylaxis) | Yes | 1/170 (0.6%)^*^ | 2/171 (1.2%)^*^
Haak, 2013^164^ | 567 | 54 weeks | Linagliptin 5 mg | Severe cutaneous reactions | Yes | 0/170 | 0/171
White, 2014^151^ | 160 | 12 weeks | Saxagliptin 5 mg | Hypersensitivity reactions | NR | 0/78 | 0/66
Yang, 2011^146^ | 570 | 24 weeks | Saxagliptin 5 mg | Hypersensitivity reactions | Yes | 0/287 | 3/283 (1.1%)
Ross, 2012^152^ | 491 | 12 weeks | Linagliptin | Hypersensitivity reactions (angioedema, anaphylaxis, angioedema-like) | Yes | 0/44 | 5 mg: 1/224 (0.4%) 2.5 mg: 0/223

Asc = ascertainment; DPP-4 = dipeptidyl peptidase-4; mg = milligrams

* Data are shown for the metformin 2000 mg monotherapy arm and the metformin 2000 mg plus linagliptin 5 mg combination arm; there were no events reported in the metformin 1000 mg plus linagliptin combination arm.

The longest RCT was a 54-week extension study164 in which the arms included participants from the initial 6-month study86 and participants who were re-randomized for the extension study. Among participants who were newly randomized for the 54-week extension study, hypersensitivity reactions occurred in 0 percent of the metformin 2000 mg arm, 0 percent of the metformin 1000 mg plus linagliptin 5 mg arm, and in 1.7 percent of the metformin 2000 mg plus linagliptin 5 mg arm. (SOE: Low; Metformin favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

A single 52-week RCT compared metformin plus glipizide with metformin plus saxagliptin and reported on hypersensitivity adverse events.195 The authors reported a hypersensitivity adverse event in one participant in the metformin plus saxagliptin arm and in two participants in the metformin plus glipizide arm. One of the events in the metformin plus glipizide arm was noted to be related to ciprofloxacin. This study did not provide information on the method of ascertainment or definition of hypersensitivity. This RCT also had high rates of discontinuation based partly on increasingly strict glycemic control criteria for maintaining eligibility in the study.195 (SOE: Low; Neither favored)

#### Strength of Evidence for Severe Allergic Reactions

We identified evidence for three comparisons for the outcome of allergic reactions (Table 106). The published studies were on comparisons that included GLP-1 receptor agonists and DPP-4 inhibitors. All evidence was low or insufficient for this outcome. Because of the limited numbers of studies and their samples sizes, evidence was imprecise. We did not detect reporting bias, but our assessment of this was also limited by the small number of studies.

Table 106 Strength of evidence domains for comparisons in terms of severe allergic reactions among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. GLP-1 receptor agonists | 1 (495) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
TZD vs. GLP-1 receptor agonists | 1 (278) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + DPP-4 inhibitors | 4 (1788) | Low | Consistent | Direct | Imprecise | Undetected | Low | Metformin favored
Metformin + SU vs. metformin + DPP-4 inhibitors | 1 (858) | High | Unknown | Direct | Imprecise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating the outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Macular Edema or Decreased Vision

#### Monotherapy Comparisons

##### Thiazolidinediones Versus GLP-1 Receptor Agonists

A single RCT examined blurred vision.105 Three of 136 participants (2.2%) treated with pioglitazone and two of 142 participants (1.4%) treated with exenatide had blurred vision over 48 weeks of followup. (SOE: Low; Neither favored)

##### Sulfonylureas Versus GLP-1 Receptor Agonists

One 104-week RCT compared glimepiride with liraglutide at two different doses (1.2 and 1.8 mg) and reported on decreased vision.113 At the end of the study, the incidence of decreased vision was comparable in all arms, with 7 percent of the glimepiride participants (n=248) having decreased vision compared with 6 percent of the liraglutide participants (n=251 for liraglutide at 1.2 mg and n=247 for liraglutide at 1.8 mg). (SOE: Low; Neither favored)

#### Strength of Evidence for Macular Edema or Decreased Vision

We identified only two studies for the outcomes of macular edema or decreased vision which evaluated different comparisons. Therefore, the evidence on these outcomes was insufficient because of a lack of studies (Table 107).

Table 107 Strength of evidence domains for monotherapy comparisons in terms of macular edema or decreased vision among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
TZD vs. GLP-1 receptor agonists | 1 (278) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
SU vs. GLP-1 receptor agonists (long-term study) | 1 (746) | Medium | Unknown | Direct | Imprecise | Undetected | Low | Neither favored

GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the safety outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Urinary Tract Infections

#### Monotherapy Comparisons

##### Metformin Versus SGLT-2 Inhibitors

Three short RCTs (published in two articles), 12 to 24 weeks in duration, compared dapagliflozin with metformin and reported on UTIs.88, 89 Since ORs did not appear to vary by gender in these short-term studies, we present results for men and women combined. We found significant statistical heterogeneity using a random effects meta-analysis (pooled OR, 1.54; 95% CI, 0.56 to 4.22; I-squared, 61.1%). Exclusion of any one study did not change the inference of the meta-analysis. We found similar non-significant increased odds for SGLT-2 inhibitors versus metformin for UTIs (pooled OR, 1.5; 95% CI, 0.5 to 5.0 (Figure 89) using the profile likelihood method. One of the RCTs used a lower dose of dapagliflozin of 5 mg88 relative to 10 mg in the other two RCTs.

Figure 89 Pooled odds ratio of urinary tract infections comparing metformin with SGLT-2 inhibitors

CI = confidence interval; Group 1 = metformin; Group 2 = sodium-glucose co-transporter-2 inhibitors; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of urinary tract infections comparing metformin with SGLT-2 inhibitors.

We did not include one RCT in the meta-analysis because it was longer (78 weeks) than the other three studies.90 This study compared metformin to 10 mg of empagliflozin and 25 mg of empagliflozin and reported similar overall incidences of UTIs with both doses of empagliflozin. UTI rates among men receiving 25 mg of empagliflozin (4/57; 7.0%) were non-significantly higher than among those receiving 10 mg of empagliflozin (0/49; 0%) and metformin (0/28; 0%) and approached UTI rates among women [empagliflozin 10 mg: 4/57 (7.0%), empagliflozin 25 mg: 3/52 (5.8%), and metformin: 2/28 (7.1%)].90 (SOE: Low; Neither favored)

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

One 24-week RCT compared 100 mg of sitagliptin with 10 mg and 25 mg of empagliflozin and reported UTI events separately by gender.114 UTI occurrences among men were similar in those receiving sitagliptin (4/141; 3%) versus 10 mg of empagliflozin (3/142; 2%) and 25 mg of empagliflozin (2/144; 1%).114 UTI events were non-significantly lower in women receiving sitagliptin (7/82; 9%) versus 10 mg of empagliflozin (12/82; 15%) and 25 mg of empagliflozin (10/78; 13%). The study did not test for an interaction by gender. (SOE: Low; Neither favored in men, DPP-4 inhibitors favored in women)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Nine short-term RCTs (published in six articles) compared metformin with the combination of metformin plus an SGLT-2 inhibitor and showed similar rates of UTIs for the combination compared to metformin (pooled OR, 1.2; 95% CI, 0.7 to 1.9) (Figure 90).88, 153, 156, 165, 166, 168 No single study markedly influenced the results, and we did not find evidence of substantial statistical heterogeneity (I^2^ = 0.0%). One study also reported that no events of urosepsis or pyelonephritis occurred in either arm.166 The definitions for UTIs varied across studies (Table 108).

Figure 90 Pooled odds ratio of short-term risk of urinary tract infections comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio short-term risk of urinary tract infections comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

Table 108 Definitions of urinary tract infections used in randomized controlled trials comparing metformin with a combination of metformin and SGLT-2 inhibitor

Author, Year | Definition of UTI Outcome (Actively Ascertained Unless Otherwise Noted)
Bailey, 2013^170^ | UTI (does not include events suggestive of UTI)
Rosenstock, 2012^156^ | UTI, not otherwise specified
Henry, 2012^88^ | Events suggestive of UTI
Bolinder, 2014^267^ | MedDRA definition of UTI
Rosenstock, 2013^153^ | UTI, not otherwise specified
Qiu, 2014^165^ | UTI, not otherwise specified
Haring, 2014 (a)166 | MedDRA definition for UTI
Henry, 2012 (b)88 | Based on a predefined list of signs, symptoms and other events suggestive of UTI
Schumm-Draeger, 2015^168^ | MedDRA definition of UTI

MedDRA = Medical Dictionary for Regulatory Activities; UTI = urinary tract infection

Based on three studies providing gender-stratified results, meta-analyses stratified by gender showed that women had non-significantly increased odds of UTIs for the combination of metformin plus an SGLT-2 inhibitor versus metformin (pooled OR, 1.4; 95% CI, 0.8 to 2.3) and no difference in UTI odds between treatment groups for men (pooled OR, 1.0; 95% CI, 0.4 to 2.8).88, 166

We did not include two moderately-sized RCTs (total sample size, 182 to 546) in the meta-analysis because they were longer (102 weeks).170, 267 One compared metformin with metformin plus dapagliflozin and reported UTI rates of 5.8 percent and 11.9 percent in the metformin and metformin plus dapagliflozin arms, respectively.170 The other had similar UTI rates across arms (metformin, 4.4% and dapagliflozin, 3.3%).267 Of note, the former had very high losses to followup with 47 percent losses in the metformin arm compared with 30 percent to 40 percent in the other arms.170 (SOE: Low; Neither favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs compared metformin plus a sulfonylurea with metformin plus an SGLT-2 inhibitor and reported inconsistent results regarding UTIs (Table 109).54, 200, 201 We did not combine these studies in a meta-analysis because of the heterogeneity in the definition of UTI and study durations. Two 104-week RCTs compared metformin plus glimepiride to metformin plus an SGLT-2 inhibitor and found similar incidences of UTIs across arms.200, 201 A 208-week RCT reported more UTIs in the metformin plus dapagliflozin arm compared to the metformin plus glipizide arm.54 This study reported high withdrawal rates of greater than 60 percent in each arm.54 UTI rates were lower among men compared to women when reported by gender.54, 200 (SOE: Low; Neither favored)

Table 109 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor on urinary tract infections

Author, Year | Definition of UTI Outcome^*^ | Results Events/N (%)
Leiter, 2015^201^ | Cystitis, pyelonephritis chronic, and UTI198 | Metformin + glimepiride: 33/482 (7%) Metformin + canagliflozin 100 mg: 51/483 (11%) Metformin + canagliflozin 300 mg: 42/485 (9%)
Del Prato, 2015^54^ | Confirmed UTI, not otherwise defined | Female Metformin + glipizide: 25/408 (13.5%) Metformin + dapagliflozin: 35/406 (19.4%) Male Metformin + glipizide: 13/408 (5.8%) Metformin + dapagliflozin: 20/406 (8.8%)
Ridderstrale, 2014^200^ | MedDRA definition of UTI (passive ascertainment) | Female Metformin + glimepiride: 81/359 (23%) Metformin + empagliflozin: 74/333 (22%) Male Metformin + glimepiride: 21/421 (5%) Metformin + empagliflozin: 31/432 (7%)

MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams; UTI = urinary tract infections

* Outcomes are actively ascertained unless otherwise noted.

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Five RCTs compared metformin plus DPP-4 with metformin plus an SGLT-2 inhibitor and reported inconsistent results (Table 110). We did not combine these studies because of differences in study duration and dosing.90, 153, 156, 158, 209

Table 110 Randomized controlled trials comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus an SGLT-2 inhibitor on urinary tract infections

Author, Year | Followup | Definition of UTI Outcome^*^ | Results Events/N (%)
Rosenstock, 2012^156^ | 12 weeks | UTI, not otherwise specified | Metformin + sitagliptin 100 mg: 1/65 (2%) Metformin + canagliflozin 100 mg: 2/64 (3%) Metformin + canagliflozin 200 mg: 6/65 (9%) Metformin + canagliflozin 300 mg: 2/64 (3%)
Rosenstock, 2013^153^ | 12 weeks | UTIs, including cystitis, excluding signs and symptoms | Metformin + sitagliptin 100 mg: 4.2% Metformin + empagliflozin 10 mg: 4.2% Metformin + empagliflozin 25 mg: 5.7%
Rosenstock, 2015^209^ | 24 weeks | UTI, not otherwise specified | Metformin + saxagliptin 5 mg: 9/176 (5%) Metformin + dapagliflozin 10 mg: 7/179 (5%)
Lavalle-Gonzalez, 2013^158^ | 52 weeks | UTI, not otherwise specified | Metformin + sitagliptin 100 mg: 23/366 (6.3%) Metformin + canagliflozin 100 mg: 29/368 (7.9%) Metformin + canagliflozin 300 mg: 18/367 (4.9%)
Ferrannini, 2013^90^ | 78 weeks | MedDRA definition of UTI | Female Metformin + sitagliptin 100 mg: 4/27 (14.8%) Metformin + empagliflozin 10 mg: 13/83 (15.7%) Metformin + empagliflozin 25 mg: 18/78 (23.1%) Male Metformin + sitagliptin 100 mg: 3/29 (10.3%) Metformin + empagliflozin 10 mg: 2/83 (2.4%) Metformin + empagliflozin 25 mg: 3/88 (3.4%)

MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams; UTI = urinary tract infections

* Outcomes are actively ascertained unless otherwise noted.

The longest RCT (78 weeks) was of low quality and reported UTI rates stratified by sex. Among women, UTI rates were higher for the metformin plus empagliflozin 25 mg arm relative to the other arms; among men, UTI rates were highest in the metformin plus sitagliptin arm relative to the other arms.90 A medium-quality, 52-week RCT compared metformin plus sitagliptin to metformin plus canagliflozin at doses of 100 mg and 300 mg and reported slightly lower UTI rates in the highest-dose (300 mg) canagliflozin arm and slightly higher rates in the lower-dose (100 mg) canagliflozin arm.158

Three short-term studies also conflicted. One medium-quality study reported a higher UTI rate with metformin plus 200 mg of canagliflozin compared with the other arms.156 Two high-quality short-term RCTs found similar UTI rates in the metformin plus DPP-4 inhibitor arms and metformin plus SGLT-2 inhibitor arms.153, 209 The evidence was graded as being at medium risk of bias because of failure to report clearly on the randomization scheme. (SOE: Low; Neither favored)

#### Strength of Evidence for Urinary Tract Infections

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 111 and summarized in the key points. All studies were RCTs. Study limitations for all the comparisons were low or medium. Although evidence of gender differences in UTI rates was limited, the data suggest that there may be higher rates of UTIs among females (particularly noted in the comparisons of metformin versus metformin plus SGLT-2 inhibitor). In general, we did not find strong differences in outcomes in the lower- versus higher-quality studies. We did not find any evidence of publication bias in any of the comparisons for UTI. The grey literature was consistent with our findings in the metformin plus SU vs. metformin plus SGLT-2 inhibitor comparison, with one unpublished study that found no UTIs in either arm.

Table 111 Strength of evidence domains for monotherapy and metformin-based combination comparisons in terms of urinary tract infections among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SGLT-2 inhibitors | 4 (2,292) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored for short-term UTI risk
DPP-4 inhibitors vs. SGLT-2 inhibitors | 1 (899) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored in men DPP-4 inhibitors favored in women
Metformin vs. metformin + SGLT-2 inhibitors | 9 (4,035) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored for short-term UTI risk
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer studies) | 3 (3,815) | Low | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored for long-term risk of UTI
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 5 (3,423) | Medium | Inconsistent | Direct | Precise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Impaired Renal Function

#### Monotherapy Comparisons

##### Metformin Versus SGLT-2 Inhibitors

Three RCTs compared metformin with SGLT-2 inhibitors and reported on impaired renal function (Table 112).89, 90, 239 We did not combine the results of these RCTs in a meta-analysis because they varied greatly in their definitions of impaired renal function.

Table 112 Randomized controlled trials comparing metformin with SGLT-2 inhibitors on impaired renal function

Author, Year | Followup | Definition of Impaired Renal Function^*^ | Results
List, 2009^89^ | 12 weeks | eGFR | NR for any arm Qualitative statement of no difference across groups
Ferrannini, 2013^90^ | 90 weeks | eGFR (ml/min/1.73 m^2^) | Metformin vs. empagliflozin 10 mg: between-group difference from baseline to final, 0.13 (95% CI, -4.5 to 4.7) Metformin vs. empagliflozin 25 mg: between-group difference from baseline to final, 2.66 (95% CI, -1.8 to 7.1)
Ferrannini, 2013^239^ | 12 weeks | Microalbuminuria, not further defined | Metformin: 1.3% Empagliflozin 10 mg: 3.7% Empagliflozin 25 mg: 0%
Ferrannini, 2013^239^ | 12 weeks | Diabetic nephropathy (unclear if actively ascertained) | Metformin: 1.3% Empagliflozin 10 mg: 2.5% Empagliflozin 25 mg: 1.2%
Ferrannini, 2013^239^ | 12 weeks | Urinary albumin to creatinine ratio (mg/mmol) | Metformin vs. empagliflozin 10 mg: between-group difference from baseline to final, 0.08 mg/mmol Metformin vs. empagliflozin 25 mg: between-group difference 0.6 mg/mmol

CI = confidence interval; eGFR = estimated glomerular filtration rate; mg = milligrams; mg/mmol = milligrams per millimole; mil/min *1.73 m^2^ = milliliters per minute per 1.73 meters squared; NR = not reported

* Outcomes are actively ascertained unless otherwise noted.

Two trials evaluated the change in estimated glomerular filtration rate (eGFR) and found no substantial differences between the arms.89, 90

One 12-week trial (N=408) evaluated incident microalbuminuria, change in the urine albumin-to-creatinine ratio, and incident diabetic nephropathy.239 The investigators did not find substantial differences in urine albumin-to-creatinine ratio across arms, and those in the low-dose empagliflozin arm had more incident microalbuminuria and diabetic nephropathy compared with the metformin and high-dose empagliflozin arm. (SOE: Low; Neither favored)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Six RCTs comparing metformin with a combination of metformin plus SGLT-2 inhibitor reported on albuminuria and eGFR (Table 113).153, 165, 166, 168, 170, 267

Table 113 Randomized controlled trials comparing metformin with a combination of metformin plus an SGLT-2 inhibitor on impaired renal function

Author, Year | Followup | Definition of Impaired Renal Function^*^ | Results
Rosenstock, 2013^153^ | 12 weeks | Creatinine clearance, microalbuminuria | NR for any arm Qualitative statement of no difference across groups
Schumm-Draeger, 2015^168^ | 16 weeks | Renal impairment/failure as specified in protocol | Metformin: 4/101 (4%) Metformin + dapagliflozin 5 mg twice daily: 3/100 (3%) Metformin + dapagliflozin 10 mg daily: 3/99 (3%)
Schumm-Draeger, 2015^168^ | 16 weeks | eGFR (ml/min/1.73 m^2^) | Metformin vs. metformin + dapagliflozin 5 mg twice daily: between-group difference from baseline to final, 4.0 (95%CI, 1.6 to 4.4) Metformin vs. metformin + dapagliflozin 10 mg: between-group difference from baseline to final, 0.8 (95%CI, -1.5 to 4.1)
Haring, 2014^166^ | 24 weeks | eGFR (ml/min/1.73 m^2^) | Metformin vs. metformin + empagliflozin 10 mg: between-group difference from baseline to final, 0.9 (95% CI, -1.5 to 3.3) Metformin vs. metformin + empagliflozin 25 mg: between-group difference from baseline to final, 2.7 (95% CI, 0.6 to 4.8)
Qiu, 2014^165^ | 18 weeks | eGFR | % reduction in eGFR Metformin: 0.3% Metformin + canagliflozin 50 mg twice daily: 0.7% Metformin + canagliflozin 150 mg twice daily: 3.8%
Bailey, 2013^170^ | 102 weeks | Renal impairment or failure, not otherwise specified | Metformin: 2/137 (1.5%) Metformin + dapagliflozin 5 mg: 4/137 (2.9%) Metformin + dapagliflozin 10 mg: 2/135 (1.5%)
Bolinder, 2014^267^ | 102 weeks | MedDRA definition of renal impairment, renal failure | Metformin: 0/91 (0%) Metformin + dapagliflozin 10 mg: 3/91 (3.3%)

CI = confidence interval; eGFR = estimated glomerular filtration rate; MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams; mil/min *1.73 m^2^ = milliliters per minute per 1.73 meters squared; NR = not reported

* Outcomes are actively ascertained unless otherwise noted.

Two 102-week trials evaluated renal impairment or failure as a categorical outcome, with conflicting results.170, 267 One found slightly more events of renal impairment in the metformin plus SGLT-2 inhibitor arm compared to metformin (3.3% vs. 0%),267 and the other RCT did not find a clear pattern of differences across arms.170 A 16-week RCT also evaluated renal impairment or failure events and reported similar rates of events across arms both arms.168

Three short-term trials evaluated eGFR and found no meaningful differences between the metformin and metformin plus SGLT-2 inhibitor arms.165, 166, 168 One 12-week RCT compared metformin with metformin plus empagliflozin and stated qualitatively that treatment with empagliflozin did not significantly change creatinine clearance or urine albumin compared with metformin.153 (SOE: Low; Neither favored)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs with long-term followup compared the effects of metformin plus a sulfonylurea to metformin plus a SGLT-2 inhibitor on renal impairment or failure, changes in eGFR, and albuminuria (Table 114).54, 200, 201 One 208-week trial evaluated reduced creatinine clearance and renal impairment and found similar rates of events between arms.54 Three trials evaluated changes in eGFR and found no meaningful differences in eGFR changes across arms.54, 200, 201 Two trials evaluated albuminuria and found no differences between arms.200, 201 (SOE: Low; Neither favored)

Table 114 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor on impaired renal function

Author, Year | Followup | Definition of Impaired Renal Function^*^ | Results | Notes
Leiter, 2015^201^ | 104 weeks | eGFR (ml/min/1.73 m^2^) | Metformin + glimepiride vs. metformin + canagliflozin 100 mg: between-group difference from baseline to final, -2.4 (95%CI, -6.3 to 1.5) Metformin + glimepiride vs. metformin + canagliflozin 300 mg: between-group difference from baseline to final, -4.2 (95%CI, -8.1 to -0.3) | Subjects meeting eGFR withdrawal criteria: n=6 in glimepiride arm, n=5 in canagliflozin 100 mg arm, and n=6 for canagliflozin 300 mg arm Unclear if included in analysis
Ridderstrale, 2014^200^ | 104 weeks | eGFR (ml/min/1.73 m^2^) | Metformin + glipizide vs. metformin + empagliflozin 25 mg; between-group difference, 3.5 (95% CI, 2.2 to 4.8)
Del Prato, 2015^54^ | 208 weeks | MedDRA defined decreased eGFR | Metformin + glipizide: 4/408 (1.0 %) Metformin + dapagliflozin: 2/406 (0.5 %)
Del Prato, 2015^54^ | 208 weeks | MedDRA defined reduced creatinine clearance | Metformin + glipizide: 13/408 (3.2 %) Metformin + dapagliflozin: 20/406 (4.9%)
Del Prato, 2015^54^ | 208 weeks | MedDRA defined renal impairment | Metformin + glipizide: 11/408 (2.7 %) Metformin + dapagliflozin: 10/406 (2.5%)
Leiter, 2015^201^ | 104 weeks | Renal failure leading to medication discontinuation | Metformin + glimepiride: NR Metformin + canagliflozin 100 mg: NR Metformin + canagliflozin 300 mg: 3/385 (0.6%)
Leiter, 2015^201^ | 104 weeks | Urine albumin-to-creatinine ratio (mg/g) | Metformin + glimepiride vs. metformin + canagliflozin 100 mg: between-group difference, 13.9 mg/g Metformin plus glimepiride vs. metformin plus canagliflozin 300 mg: between-group difference, 16.1 mg/g
Ridderstrale, 2014^200^ | 104 weeks | Urine albumin-to-creatinine ratio (mg/g) | Metformin + glimepiride vs. metformin + empagliflozin 25 mg: between-group difference, 1.9 mg/g (95% CI, -5.1 to 8.9 mg/g) | Subgroup with no albuminuria at baseline

CI = confidence interval; eGFR = estimated glomerular filtration rate; MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams; mg/g = milligrams per gram; mil/min *1.73 m^2^ = milliliters per minute per 1.73 meters squared; NR = not reported

* Outcomes are actively ascertained unless otherwise noted.

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Four RCTs compared metformin plus a DPP-4 inhibitor with metformin plus a SGLT-2 inhibitor on renal outcomes (Table 115).90, 153, 158, 209 Three trials evaluated changes in eGFR and found no substantial differences across arms.90, 158, 209 One 12-week RCT evaluated changes in creatinine clearance and microalbuminuria comparing metformin plus sitagliptin and metformin plus empagliflozin and found no significant differences between arms.153 (SOE: Low; Neither favored)

Table 115 Randomized controlled trials comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus an SGLT-2 inhibitor on impaired renal function

Author, Year | Followup | Definition of Impaired Renal Function^*^ | Results
Ferrannini, 2013^90^ | 90 weeks | eGFR (ml/min/1.73 m^2^) | Metformin + sitagliptin vs. metformin + empagliflozin 10 mg: between-group difference, 4.1 (95% CI, 0.3 to 8.6) Metformin + sitagliptin vs. metformin + empagliflozin 25 mg: between-group difference, 2.8 (95% CI, -1.5 to 7.1)
Lavalle-Gonzalez, 2013^158^ | 52 weeks | Decreased eGFR | Metformin + sitagliptin vs. metformin + canagliflozin 100 mg: between-group difference, 1.0% Metformin + sitagliptin vs. metformin + canagliflozin 300 mg: between-group difference, 0.9%
Rosenstock, 2013^153^ | 12 weeks | Creatinine clearance, microalbuminuria | NR for any arm Qualitative statement of no difference across groups
Rosenstock, 2015^209^ | 24 weeks | GFR decrease, not otherwise defined | Metformin + saxagliptin: 1/176 (0.6%) Metformin + dapagliflozin: 0/179 (0%)

CI = confidence interval; eGFR = estimated glomerular filtration rate; mg = milligrams; mil/min *1.73 m^2^ = milliliters per minute per 1.73 meters squared; NR = not reported

* Outcomes are actively ascertained unless otherwise noted.

#### Strength of Evidence for Impaired Renal Function

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 116 and summarized in the key points. All studies were RCTs. Study limitations for all the comparisons were low or medium. The evidence was generally imprecise because of small event rates and sample sizes. In general, we did not find strong differences in outcomes in the lower- versus higher-quality studies. We did not find any evidence of publication bias in any of the comparisons for renal outcomes. We also did not find any evidence of publication bias or reporting bias in the grey literature review.

Table 116 Strength of evidence domains for monotherapy and metformin-based combination comparisons in terms of impaired renal function among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SGLT-2 inhibitors | 3 (1,456) | High | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
DPP-4 inhibitors vs. SGLT-2 inhibitors | 2 (1,394) | Medium | Consistent | Direct | Precise | Undetected | Low | Neither favored
Metformin vs. metformin + SGLT-2 inhibitors | 6 (2,340) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer studies) | 3 (3,815) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 4 (2,972) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Genital Mycotic Infections

#### Monotherapy Comparisons

##### Metformin Versus SGLT-2 Inhibitors

Three medium- to high-quality, short RCTs (reported in two articles) compared metformin with SGLT-2 inhibitors and found more genital infections in the SGLT-2 inhibitor vs. metformin arms (pooled OR, 4.1; 95% CI, 2.0 to 8.3) (Figure 91).88, 89 ORs did appear to vary by gender. No single study markedly influenced the results, and we did not find significant statistical heterogeneity (I^2^ = 0.0%).

Figure 91 Pooled odds ratio of genital or mycotic infections comparing metformin with SGLT-2 inhibitors

CI = confidence interval; Group 1 = metformin; Group 2 = sodium-glucose co-transporter-2 inhibitors; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of genital or mycotic infections comparing metformin with SGLT-2 inhibitors.

We did not include a low-quality, 78-week RCT in the meta-analysis because of its longer duration.90 This study compared metformin with empagliflozin and reported slightly higher rates of genital infections among females for SGLT-2 inhibitor therapy [1/28 (3.6%) with metformin versus 3/57 (5.3%) with metformin plus low-dose empagliflozin and 3/52 (5.8%) with metformin plus high-dose empagliflozin] and more genital infections among males with SGLT-2 inhibitors [0/28 (0%) with metformin versus 2/49 (4.1%) with metformin plus low dose empagliflozin and 3/57 (5.3%) with metformin plus high- dose empagliflozin]. (SOE: Moderate; Metformin favored)

##### DPP-4 Inhibitors Versus SGLT-2 Inhibitors

Two RCTs (24 to 26 weeks) compared outcomes from use of 100 mg of sitagliptin daily to an SGLT-2 inhibitor, by gender.114, 240 Both trials reported higher rates of genital infections among both women and men with use of SGLT-2 inhibitors compared with sitagliptin, with some of the comparisons statistically significant (Table 117).114, 240 (SOE: Low; DPP-4 inhibitors favored)

Table 117 Randomized controlled trials comparing DPP-4 inhibitors with SGLT-2 inhibitors on genital infections

Author, Year | Medication Dose | Women Events/N (%) | Men Events/N (%)
Stenlof, 2014^240^ | Sitagliptin 100 mg Canagliflozin 100 mg Canagliflozin 300 mg | 1/155 (1.2) 3/170 (3) 3/170 (3.2) | 0/155 (0) 3/170 (3) 5/170 (6.5)
Roden, 2013^114^ | Sitagliptin 100 mg Empagliflozin 10 mg Empagliflozin 25 mg | 1/82 (1) 3/82 (4) 7/79 (9) | 1/141 (1) 4/142 (3) 2/144 (1)

mg = milligrams

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Seven RCTs (reported in six articles) compared metformin with metformin plus a SGLT-2 inhibitor and found increased odds of genital infections for combination therapy over metformin monotherapy with no clear differences by gender: pooled OR, 3.0 (95% CI, 1.2 to 7.2) for women and pooled OR, 2.7 (95% CI, 0.8 to 9.0) for men (Figure 92).88, 156, 165, 166, 168 No single study markedly influenced the results, and we did not find significant statistical heterogeneity (I^2^ = 15.4% for women and I^2^ = 0.0% for men). An additional 12-week RCT did not provide sex-stratified analyses so was not included in the meta-analysis.153 This study reported more genital infection events in one of the groups receiving empagliflozin compared with the other two arms (metformin plus sitagliptin 100 mg: 0%; metformin plus empagliflozin 10 mg: 9.9%; metformin plus empagliflozin 25 mg: 0%).

Figure 92 Pooled odds ratio of genital or mycotic infections comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of genital or mycotic infections comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

We excluded two RCTs from the meta-analysis because of their longer durations.170, 267 The results of those RCTs are included in Table 118 and are consistent with the findings from the short-term studies. (SOE: High; Metformin favored)

Table 118 Randomized controlled trials comparing metformin with a combination of metformin plus an SGLT-2 inhibitor on genital infections

Author, Year | Followup | Genital Infection Outcome^*^ | Results (Metformin Versus Metformin + SGLT-2 Inhibitor)
Rosenstock, 2012^156^ | 12 weeks | Symptomatic of genital infections | Metformin: 1/65 (2%) Metformin + canagliflozin 100 mg: 4/64 (6%) Metformin + canagliflozin 200 mg: 2/65 (3%) Metformin + canagliflozin 300 mg: 2/64 (3%)
Rosenstock, 2013^153^ | 12 weeks | MedDRA definition | Metformin: 0% Metformin + empagliflozin 10 mg: 9.9% Metformin + empagliflozin 25 mg: 0%
Schumm-Draeger, 2015^168^ | 16 weeks | MedDRA definition | Metformin: 1/101 (1%) Metformin + dapagliflozin 5 mg twice daily: 5/100 (5%) Metformin + dapagliflozin 10 mg: 3/99 (3%)
Qiu, 2014^165^ | 18 weeks | Males: balanitis candida and genital infection fungal. Females: vaginal infection, vulvovaginal candidiasis, vulvovaginal mycotic infection, and vulvovaginitis | [underlined: Males] Metformin: 1/46 (2.2%) Metformin + canagliflozin 100 mg: 1/40 (2.5%) Metformin + canagliflozin 300 mg: 0/44 (0%) [underlined: Females] Metformin: 2/47 (4.3%) Metformin + canagliflozin 100 mg: 6/53 (11.3%) Metformin + canagliflozin 300 mg: 1/49 (2.0%)
Henry, 2012 (a)88 | 24 weeks | Events suggestive of vulvovaginitis, balanitis, and related genital infection | [underlined: Males] Metformin: 0% Metformin + dapagliflozin 5 mg: 5.1% [underlined: Females] Metformin: 3.8% Metformin + dapagliflozin 5 mg: 7.8%
Haring, 2014^166^ | 24 weeks | MedDRA definition | [underlined: Males] Metformin: 0/116 (0%) Metformin + empagliflozin 10 mg: 1/125 (0.8%) Metformin + empagliflozin 25 mg: 1/120 (0.8%) [underlined: Females] Metformin: 0/91 (0%) Metformin + empagliflozin 10 mg: 7/92 (7.6%) Metformin + empagliflozin 25 mg: 9/93 (9.7%)
Henry, 2012 (b)88 | 24 weeks | Based on a predefined list of signs, symptoms and other events suggestive of genital infection | [underlined: Males] Metformin: 2/97 (2.1%) Metformin + dapagliflozin 10 mg: 6/106 (5.7%) [underlined: Females] Metformin: 3/111 (2.7%) Metformin + dapagliflozin 10 mg: 12/105 (11.4%)
Bolinder, 2014^267^ | 102 weeks | Genital infections | Metformin: 1/91 (1.1%) Metformin + dapagliflozin 10 mg: 2/91 (2.2%)
Bailey, 2013^170^ | 102 weeks | Events suggestive of genital infection | Metformin: 7/137 (5.1%) Metformin + dapagliflozin 2.5 mg: 16/137 (11.7%) Metformin + dapagliflozin 5 mg: 20/137 (14.6%) Metformin + dapagliflozin 10 mg: 17/135 (12.6%)

MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams

* Outcomes are actively ascertained unless otherwise noted.

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs compared metformin plus a sulfonylurea with metformin plus a SGLT-2 inhibitor, suggesting increased odds of genital infections for metformin plus SGLT-2 inhibitors and differences in relative odds by gender: pooled OR, 5.2 (95% CI, 3.4 to 7.8) for women and pooled OR, 7.6 (95% CI, 4.0 to 14.4) for men (Figure 93).200, 201, 219 No single study markedly influenced the results, and we did not find significant statistical heterogeneity (I^2^ = 0.0% for women and I^2^ = 0.0% for men). A 208-week extension of Nauck, 2014 et al.219 also reported higher rates of genital infection in the SGLT-2 inhibitor combination arm and among women compared with men (Table 119).54 Losses to followup were high (>60% in both arms).54 (SOE: High; Combination of metformin plus a sulfonylurea favored)

Figure 93 Pooled odds ratio of genital or mycotic infections comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; Met = metformin; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of genital or mycotic infections comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor.

Table 119 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor on genital infections

Author, Year | Definition | Medication Dose | Women Events/N (%) | Men Events/N (%)
Ridderstrale, 2014^200^ | MedDRA definition of genital infection | Metformin + glimepiride Metformin + empagliflozin 25 mg | 12/359 (3%) 49/333 (15%) | 5/421 (1%) 41/432 (9%)
Leiter, 2015^201^ | Males: balanitis, balanitis candida, balanoposthitis, genital candidiasis, genital infection fungal, and posthitis Females: genital infection fungal, vaginal infection, vulvitis, vulvovaginal candidiasis, vulvovaginal mycotic infection, and vulvovaginitis | Metformin + glimepiride Metformin + canagliflozin 300 mg | 6/219 (2.7%) 38/244 (15.6%) | 5/263 (1.9%) 22/241 (9.1%)
Nauck, 2014^219^ | MedRA definition of genital infection | Metformin + glipizide Metformin + dapagliflozin | 11/185 (5.9) 42/180 (23.3) | 1/223 (0.4) 18/226 (8.0)
Del Prato, 2015^54,*^ | Confirmed genital infection | Metformin + glipizide Metformin + dapagliflozin | 11/408 (5.9%) 41/406 (22.8%) | 1/408 (0.4%) 17/406 (7.5%)

MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams

* Del Prato, 2015 is the 208-week extension study of Nauck, 2014.

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Five RCTs compared metformin plus a DPP-4 inhibitor with metformin plus a SGLT-2 inhibitor and generally found more genital infections with the SGLT-2 inhibitor arms.90, 153, 156, 158, 209 These studies were not pooled owing to differences in study duration. Two of the studies stratified outcomes by gender (Table 120).90, 158 (SOE: Moderate; Combination of metformin plus a DPP-4 inhibitor favored)

Table 120 Randomized controlled trials comparing a combination of metformin plus a DPP-4 inhibitor with a combination of metformin plus an SGLT-2 inhibitor on genital infections

Author, Year | Followup (Weeks) | Medication Dose | Women Events/N (%) | Men Events/N (%) | Total Events/N (%)^*^ | Comments
Rosenstock, 2012^156^ | 12 weeks | Metformin + sitagliptin | 1/27 (3.7) | NR | NR
Rosenstock, 2012^156^ | 12 weeks | Metformin + canagliflozin 100 mg | 2/28 (7.1) | NR | NR
Rosenstock, 2012^156^ | 12 weeks | Metformin + canagliflozin 200 mg | 4/32 (12.5) | NR | NR
Rosenstock, 2012^156^ | 12 weeks | Metformin + canagliflozin 300 mg | 1/28 (3.6) | NR | NR
Rosenstock, 2013^153^ | 12 weeks | Metformin + sitagliptin | NR | NR | 2/71 (2.8)
Rosenstock, 2013^153^ | 12 weeks | Metformin + empagliflozin 10 mg | NR | NR | 7/71 (9.9)
Rosenstock, 2013^153^ | 12 weeks | Metformin + empagliflozin 25 mg | NR | NR | 0/70 (0)
Rosenstock, 2015^209^ | 24 weeks | Metformin + saxagliptin | NR | NR | 1/176 (0.6)
Rosenstock, 2015^209^ | 24 weeks | Metformin + dapagliflozin 10 mg | NR | NR | 10/179 (6.0)
Lavalle-Gonzalez, 2013^158^ | 52 weeks | Metformin + sitagliptin | 5/194 (2.6) | 2/172 (1.2) | NR | ITT analysis not performed
Lavalle-Gonzalez, 2013^158^ | 52 weeks | Metformin + canagliflozin 100 mg | 22/194 (11.3) | 9/174 (5.2) | NR | ITT analysis not performed
Lavalle-Gonzalez, 2013^158^ | 52 weeks | Metformin + canagliflozin 300 mg | 20/202 (9.9) | 4/165 (2.4) | NR | ITT analysis not performed
Ferrannini, 2013^90^ | 78 weeks | Metformin + sitagliptin | 0/29 (0) | 0/27 (0) | NR | ITT analysis not performed
Ferrannini, 2013^90^ | 78 weeks | Metformin + empagliflozin 10 mg | 2/83 (2.4) | 3/83 (3.6) | NR | ITT analysis not performed
Ferrannini, 2013^90^ | 78 weeks | Metformin + empagliflozin 25 mg | 3/88 (3.4) | 3/78 (3.8) | NR | ITT analysis not performed

DPP-4 = dipeptidyl peptidase-4; ITT = intention-to-treat; mg = milligrams; NR = not reported; SGLT-2 = sodium-glucose co-transporter-2

* Results for both genders provided if sex-stratified results not reported

#### Strength of Evidence for Genital Mycotic Infections

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 121 and summarized in the key points. All studies were RCTs. Study limitations for all the comparisons were low or medium. In general, we did not find strong differences in outcomes in the lower- versus higher-quality studies. We did not find any evidence of publication bias in any of the comparisons for genital infections. We also did not find any evidence of publication bias or reporting bias in the grey literature review.

Table 121 Strength of evidence domains for monotherapy and metformin-based combination comparisons in terms of genital mycotic infections among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SGLT-2 inhibitors | 4 (2,292) | Medium | Consistent | Direct | Imprecise | Undetected | Moderate | Metformin favored; 4.1 (2.0 to 8.3) for SGLT-2 inhibitors vs. metformin
DPP-4 inhibitors vs. SGLT-2 inhibitors | 2 (1,394) | Medium | Consistent | Direct | Imprecise | Undetected | Low | DPP-4 inhibitors favored
Metformin vs. metformin + SGLT-2 inhibitors | 9 (4,035) | Low | Consistent | Direct | Precise | Undetected | High | Metformin favored; 3.0 (1.2 to 7.2) for females and 2.7 (0.8 to 9.0) for males
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer studies) | 3 (3,815) | Medium | Consistent | Direct | Precise | Undetected | High | Metformin + SU favored; 5.2 (3.4 to 8.0) for females and 7.6 (4.0 to 14.4) for males
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 5 (3,423) | Medium | Consistent | Direct | Imprecise (n for metformin insufficient) | Undetected | Moderate | Metformin + DPP-4 inhibitors favored; range in OR, 1.0 to 10.4; range in RD, -3% to 9%

CI = confidence interval; DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; OR = odds ratio; RD = risk difference; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Fracture

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three RCTs compared metformin with metformin plus an SGLT-2 inhibitor and found no differences in fractures.168, 170, 267 Two of these had followup for longer than one year: One 102-week RCT compared metformin with metformin plus dapagliflozin and reported a slightly higher incidence of fractures in the highest-dose dapagliflozin arm [2/137 (1.5%) for metformin versus 2/137 (1.5%) for dapagliflozin 2.5 mg, 2/137 (1.5%) for dapagliflozin 5 mg, and 3/135 (2.2%) for dapagliflozin 10 mg]. There was a high loss to followup in this study, ranging from 30 percent to 47 percent across arms.170 Another 102-week RCT compared metformin with metformin plus 10 mg of dapagliflozin and reported one fracture (1.1%) in each treatment arm (n=91 for both arms).267 A single 16-week RCT compared metformin with metformin plus dapagliflozin and reported no fractures in either arm.168 (SOE: Low; Neither favored for shorter studies; SOE: Low; Neither favored for longer studies)

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Two studies compared metformin plus a GLP-1 receptor agonist with metformin plus a SGLT-2 inhibitor, showing no differences in fracture risk.200, 219 One 104-week RCT compared metformin plus glipizide with metformin plus dapagliflozin and showed a slightly higher incidence of fractures in the metformin plus glipizide arm [9/408 (2.2%) for metformin plus glipizide versus 6/406 (1.5%) for metformin plus dapagliflozin].219 Another 104-week RCT compared metformin plus glimepiride to metformin plus empagliflozin showing similar incidences of fractures in both arms (2%).200 (SOE: Insufficient)

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

One 24-week RCT compared metformin plus a DPP-4 inhibitor with metformin plus a SGLT-2 inhibitor and reported a slightly higher risk of fracture in the metformin arm [2/176 (1.0%) for metformin plus saxagliptin versus 1/179 (0.6%) for metformin plus dapagliflozin].209 (SOE: Low; Metformin plus SGLT-2 inhibitor favored short-term fracture risk)

#### Strength of Evidence for Fracture

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 122 and summarized in the key points. All studies were RCTs. Study limitations for all the comparisons were low. We did not find any evidence of publication bias in any of the comparisons for fractures. A single 52-week, unpublished trial reported no fractures in either arm (NCT01368081), which is consistent with the other studies. We also did not find any evidence of publication bias or reporting bias in the grey literature review.

Table 122 Strength of evidence domains for monotherapy and metformin-based combination comparisons in terms of fracture among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. metformin + SGLT-2 inhibitors (shorter studies) | 1 (200) | Low | Unknown | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + SGLT-2 inhibitors (longer studies) | 2 (728) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer studies) | 2 (2,363) | Medium | Inconsistent | Direct | Imprecise | Undetected | Insufficient | Unable to determine
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors (shorter study) | 1 (534) | Low | Unknown | Direct | Imprecise | Undetected | Low | Metformin + SGLT-2 inhibitor favored

SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† We only include estimates for comparisons with high or moderate strength of evidence.

### Evidence for Volume Depletion

#### Monotherapy Comparisons

##### Metformin Versus SGLT-2 Inhibitors

Two moderately-sized, short RCTs compared metformin with SGLT-2 inhibitors and reported inconsistent results.88, 89 One 12-week RCT comparing metformin with dapagliflozin reported a higher incidence of hypotensive events with metformin (4% for metformin versus 0% for dapagliflozin 5 mg and 10 mg).89 One 24-week RCT comparing metformin with dapagliflozin 5 mg reported significantly more events of hypotension or syncope with dapagliflozin [0/201 (0%) for metformin versus 4/203 (2%) for dapagliflozin 5 mg].88 (SOE: Low; Conflicting results)

#### Metformin Versus Metformin-Based Combination Comparisons

##### Metformin Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Six RCTs compared metformin with the combination of metformin plus an SGLT-2 inhibitor for this outcome.88, 156, 165, 168, 170, 267 We did not combine these in a meta-analysis because of differences in study duration and definition of volume depletion events (Table 123, Figure 94). The two RCTs with long-term followup had large losses to followup and were conflicting with one suggesting a higher risk of hypotension in the SGLT-2 inhibitor-based arm267 and the other suggesting similar rates of volume depletion across arms.170 Volume depletion events were rare in the four short-duration RCTs (Figure 94).88, 156, 165, 168 (SOE: Low; Neither favored for shorter studies; SOE: Low; Neither Favored for longer studies)

Table 123 Randomized controlled trials comparing metformin with a combination of metformin plus an SGLT-2 inhibitor on volume depletion

Author, Year | Followup | Definition of Volume Depletion Outcome | Results (Metformin Versus Metformin + SGLT2 Inhibitor) | Comments
Rosenstock, 2012^156^ | 12 weeks | Adverse events possibly related to hypovolemia (dizziness, dizziness postural, heart rate increased, tachycardia, and urine output decreased) | Metformin: 1/65 (2%) Metformin + canagliflozin 100 mg: 4/64 (6%) Metformin + canagliflozin 200 mg: 3/65 (5%) Metformin + canagliflozin 300 mg: 1/64 (2%) | Included in meta-analysis
Schumm-Draeger, 2015^168^ | 16 weeks | MedDRA definition for hypotension, dehydration, or hypovolemia | Metformin: 0/101 (0%) Metformin + dapagliflozin 5 mg twice daily: 0/100 (0%) Metformin + dapagliflozin 10 mg: 0/99 (0%) | Included in meta-analysis
Qiu, 2014^165^ | 18 weeks | Orthostatic hypotension, postural dizziness | Metformin: 0/93 (0%) Metformin + canagliflozin 100 mg: 0/93 (0%) Metformin + canagliflozin 300 mg: 0/93 (0%) | Included in meta-analysis
Henry, 2012^88^ | 24 weeks | Hypotension or syncope | Metformin: 0/201 (0%) Dapagliflozin 5 mg: 1/194 (0.5%) | No ITT analysis performed Included in meta-analysis
Bolinder, 2014^267^ | 102 weeks | Hypotension | Metformin: 0/91 (0%) Metformin + dapagliflozin 10 mg: 1/91 (1.1%) | Unclear if ITT analysis performed High losses to follow up
Bailey, 2013^170^ | 102 weeks | MedDRA definition for hypotension, dehydration, or hypovolemia | Metformin: 2/137 (1.5%) Metformin + dapagliflozin 2.5 mg: 0/137 (0%) Metformin + dapagliflozin 5 mg: 3/137 (2.2%) Metformin + dapagliflozin 10 mg: 2/135 (1.5%) | High losses to follow up

ITT = intention-to-treat; MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams; SGLT-2 = sodium-glucose co-transporter-2

Figure 94 Pooled odds ratio of volume depletion comparing metformin with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = metformin; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Studies were excluded because they did not contribute any events.

Pooled odds ratio of volume depletion comparing metformin with a combination of metformin plus a SGLT-2 inhibitor.

#### Metformin-Based Combination Comparisons

##### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Three 104-week RCTs compared metformin plus a sulfonylurea to metformin plus a SGLT-2 inhibitor and described volume depletion events, with varying definitions in each study. The evidence suggested little difference between arms (pooled OR for metformin plus sulfonylurea versus metformin plus SGLT-2 inhibitor, 1.0; 95% CI, 0.6 to 1.7) (Figure 95 and Table 124).200, 201, 219 No single study markedly influenced the results, and we did not detect substantial heterogeneity (I^2^ = 0.0%). (SOE: Low; Neither favored)

Figure 95 Pooled odds ratio of volume depletion comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor

CI = confidence interval; Group 1 = combination of metformin plus a sulfonylurea; Group 2 = combination of metformin plus a sodium-glucose co-transporter-2 inhibitor; OR = odds ratio; SGLT-2 = sodium-glucose co-transporter-2

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Pooled odds ratio of volume depletion comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus a SGLT-2 inhibitor.

Table 124 Randomized controlled trials comparing a combination of metformin plus a sulfonylurea with a combination of metformin plus an SGLT-2 inhibitor on volume depletion

Author, Year | Followup | Definition of Volume Depletion Outcome | Results Events/N (%)
Leiter, 2015^201^ | 104 weeks | Decreased blood pressure, dehydration, postural dizziness, hypotension, orthostatic hypotension, presyncope, and syncope | Metformin + glimepiride: 11/482 (2.3%) Metformin + canagliflozin 100 mg: 8/483 (1.7%) Metformin + canagliflozin 300 mg: 12/485 (2.5%)
Ridderstrale, 2014^200^ | 104 weeks | MedDRA definition | Metformin + glimepiride: 8/780 (1%) Metformin + empagliflozin 25 mg: 11/765 (1%)
Nauck, 2014^219^ | 104 weeks | Hypotension, dehydration, hypovolemia | Metformin + glipizide: 7/408 (1.7%) Metformin + dapagliflozin 10 mg: 6/406 (1.5%)

MedDRA = Medical Dictionary for Regulatory Activities; mg = milligrams

##### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus an SGLT-2 Inhibitor

Two RCTs compared metformin plus a DPP-4 inhibitor with metformin plus a SGLT-2 inhibitor and showed no clear differences in volume depletion outcomes.156, 158 Both studies reported active ascertainment of the outcome. One 52-week RCT comparing metformin plus sitagliptin with metformin plus canagliflozin 100 mg and 300 mg reported similar incidences in orthostatic hypotension (0% to 0.3% across all three arms).158 One 12-week RCT comparing metformin plus sitagliptin with metformin plus canagliflozin reported slightly more events related to hypovolemia in the arms receiving the lower doses of canagliflozin [1/65 (2%) for metformin plus sitagliptin versus 4/64 (6%) for metformin plus canagliflozin 100 mg, 3/65 (5%) for metformin plus canagliflozin 200 mg, and 1/64 (2%) for metformin plus canagliflozin 300 mg].156 (SOE: Low; Neither favored)

#### Strength of Evidence for Volume Depletion

The strength of evidence for the comparative effects of monotherapy and metformin-based combinations are presented in Table 125 and summarized in the key points. All studies were RCTs. Study limitations for all the comparisons were low. Where quality influences results, we describe that under the appropriate comparisons. In general, we did not find strong differences in outcomes in the lower- versus higher-quality studies. We did not find any evidence of publication bias in any of the comparisons for volume depletion. We also did not find any evidence of publication bias or reporting bias in the grey literature review.

Table 125 Strength of evidence domains for monotherapy and metformin-based combination comparisons in terms of volume depletion among adults with type 2 diabetes

Comparison^*^ | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary^†^
Metformin vs. SGLT-2 inhibitors | 2 (992) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Conflicting results from 2 RCTs
Metformin vs. metformin + SGLT-2 inhibitors (shorter studies) | 4 (1533) | Medium | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin vs. metformin + SGLT-2 inhibitors (longer studies) | 2 (728) | Low | Consistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + SU vs. metformin + SGLT-2 inhibitors (longer studies) | 3 (3,815) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored
Metformin + DPP-4 inhibitors vs. metformin + SGLT-2 inhibitors | 2 (1,735) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low | Neither favored

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; SGLT-2 inhibitors = sodium-glucose co-transporter 2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione

* We only list comparisons that were evaluated by at least one randomized controlled trial. All other comparisons were considered to have insufficient evidence because of a lack of available evidence. Unless otherwise specified, conclusions for the intermediate outcomes are short-term (1 year or shorter) because there are few longer-duration studies evaluating this outcome.

† Unless otherwise specified, the estimates are the pooled odds ratios (95 percent confidence intervals) from randomized controlled trials. We only include estimates for comparisons with high or moderate strength of evidence.

## Key Question 4 Subgroups

Although thirty-two studies reported on the comparative effectiveness and safety for sub-populations relevant to Key Question 4 (Appendix D, Table D14), few studies had sufficient power to assess comparative effectiveness or safety by subgroup. The evidence favoring one medication over another across subgroups is unclear.

We included 29 RCTs and five cohort studies that addressed this Key Question. The majority of these trials (n=22) evaluated subgroup effects on the outcome of HbA1c.54, 77, 80, 82, 84, 104, 107, 118, 126, 139, 141, 142, 145, 149, 151, 154, 160, 193 41,187, 194, 241, 268, 269 RCTs also included subgroup results on weight gain,77, 169, 241, 270, 271 hypoglycemia,190, 195, 272 and fractures.273 The cohort studies included subgroup results for mortality,234 cardiovascular events,245, 246 fractures,274 and kidney disease progression.249

We were unable to draw conclusions about the differential effects of medications in the specified sub-populations because of the small number of studies available for any one outcome for the included comparisons.

### Subgroups Defined by Age

#### Hemoglobin A1c

Sixteen RCTs, out of the 21 reporting on subgroups for this outcome, did not find differences in the effects of diabetes medications on HbA1c by age.

#### Cardiovascular Mortality and Morbidity

We included two retrospective cohort studies which reported on cardiovascular outcomes by age. One study compared metformin users, glimepiride users, and glyburide users.245 Metformin use was associated with lower risk of nonfatal CVD events compared with glyburide use among older participants (>51 years old) (Adjusted HR for metformin vs. glyburide among those age 51 to 70 years, 0.28; 95% CI, 0.20 to 0.39; adjusted HR among those age 71 years or older, 0.30; 95% CI, 0.18 to 0.48). In the younger age group, only metformin was associated with a decreased risk of cardiovascular events (adjusted HR for metformin vs. glyburide, 0.39; 95% CI, 0.21 to 0.73). Another retrospective cohort study compared metformin with sulfonylureas and found no difference in the incidence of death or cardiovascular events across age groups.246

#### Hypoglycemia

Two RCTs evaluating the risk of hypoglycemia by age reported no differences by age for the combination of metformin and a sulfonylurea versus the combination of metformin and a DPP-4 inhibitor.190, 195

#### Kidney Function Decline

A retrospective cohort study compared the effect of metformin, rosiglitazone and sulfonylureas on kidney function and found no differences by age for kidney disease progression.249

### Subgroups Defined by Sex

#### Hemoglobin A1c

Seventeen RCTs examined the impact of sex on glycemic control (HbA1c) for the comparisons of interest and found no differences by sex.77, 80, 82, 84, 104, 107, 118, 126, 139, 141, 142, 145, 149, 151, 154, 194, 268

#### Weight

One trial reported a greater weight reduction among men compared with women for the combination of metformin plus dapagliflozin versus metformin; the mean decrease at 24 weeks attributable to the addition of dapagliflozin was 2.76 kg for men and 1.22 kg for women, p for interaction = 0.048).169 A second study comparing metformin with pioglitazone reported that while both men and women in the metformin arm had a slight but not significant weight loss, those in the pioglitazone arm differentially gained weight; the mean increase at 12 weeks was 1.78 kg for women (p = 0.039) and 0.86 kg for men (p=0.151).77 Another trial that compared metformin with metformin plus pioglitazone over 24 weeks reported no treatment differences by sex.270

#### Long-Term Clinical Outcomes

The two retrospective cohort studies described above comparing the effect of metformin and different sulfonylureas on cardiovascular risk found no association between treatments and cardiovascular outcomes by sex.245, 246 However, a retrospective cohort study of new monotherapy users found that compared with those on metformin, women on rosiglitazone had a higher risk of death (RR, 6.21; 95% CI, 1.22 to 19.65) than men (RR, 1.76; 95% CI, 1.41 to 2.18).234 The p-value for the interaction between treatment and sex was 0.034.

#### Hypoglycemia

Two studies that compared the combination of metformin and sulfonylureas with the combination of metformin and a DPP-4 inhibitor found no differences by gender for this outcome.190, 272

#### Fractures

A retrospective analysis of the ADOPT trial found that women treated with rosiglitazone had an increased risk of fracture relative to those treated with metformin or glyburide (HR, 1.57 and 1.61, respectively); the investigators did not find an increased risk of fracture among men in this study with a median of 4 years of followup.273 One cohort study reported that women have a higher risk of peripheral fractures when treated with pioglitazone than with sulfonylureas (adjusted HR, 1.77; 95% CI, 1.32 to 2.38).274 However, the study did not find a statistically significant increased risk of peripheral fractures for women treated with rosiglitazone compared with sulfonylureas (adjusted HR, 1.17; 95% CI 0.91 to 1.50). Men treated with thiazolidinediones had an increased risk compared with men treated with sulfonylureas (adjusted HR, 1.61; 95% CI, 1.18 to 2.20).

### Subgroups Defined by Race/Ethnicity

#### Hemoglobin A1c

Thirteen RCTs examined the impact of race on HbA1c reduction, and found no differences by race for the comparisons studied.82, 84, 104, 107, 126, 139, 141, 145, 151, 154, 160, 194

#### Kidney Function Decline

A single retrospective cohort evaluating the effects of metformin, glyburide, and glimepiride on progression of chronic kidney disease found no differences by race for this outcome.249

### Subgroups Defined by Body Mass Index

#### Hemoglobin A1c

Sixteen RCTs found no differences by baseline BMI on the effects of diabetes medications on HbA1c reduction for the comparisons studied.54, 80, 82, 84, 104, 107, 118, 126, 139, 141, 145, 154, 194, 241, 269

#### Weight

Two studies reported on effects of weight in a subgroup of obese patients, but they did not report on this outcome in the non-obese patients.241, 271 One RCT found that obese patients treated with metformin lost an average of 1.3 kg, but those treated with sulfonylureas gained an average of 3.7 kg.271 In another RCT, obese patients allocated to metformin lost an average of 0.9 kg but those allocated to a combination of metformin plus rosiglitazone gained an average of 2.5 kg.241