# References

1 Centers for Disease Control and Prevention. (2014). National Diabetes Statistics Report: Estimates of Diabetes and Its Burden in the United States, 2014.
2 Lee JW, Brancati FL, Yeh HC. (2011). Trends in the prevalence of type 2 diabetes in Asians versus whites: results from the United States National Health Interview Survey, 1997-2008. Diabetes Care.
3 Nichols GA, Schroeder EB, Karter AJ, et al. (2015). Trends in diabetes incidence among 7 million insured adults, 2006-2011: the SUPREME-DM project. Am J Epidemiol.
4 Maruthur NM. (2013). The growing prevalence of type 2 diabetes: increased incidence or improved survival?. Curr Diab Rep.
5 Centers for Disease Control and Prevention. (2013). Diabetes Public Health Resource: Incidence ang Age at Diagnosis.
6 (2008). Economic costs of diabetes in the U.S. In 2007. Diabetes Care.
7 (2014). Standards of medical care in diabetes-2014. Diabetes Care.
8 Inzucchi SE, Bergenstal RM, Buse JB, et al. (2012). Management of hyperglycemia in type 2 diabetes: A patient-centered approach: Position statement of the American Diabetes Association (ADA) and the European Association for the Study of Diabetes (EASD). Diabetes Spectrum.
9 (1998). Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet.
10 (1998). Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet.
11 Duckworth W, Abraira C, Moritz T, et al. (2009). Glucose control and vascular complications in veterans with type 2 diabetes. The New England journal of medicine.
12 Gerstein HC, Miller ME, Byington RP, et al. (2008). Effects of intensive glucose lowering in type 2 diabetes. The New England journal of medicine.
13 Papademetriou V, Lovato L, Doumas M, et al. (2014). Chronic kidney disease and intensive glycemic control increase cardiovascular risk in patients with type 2 diabetes. Kidney Int.
14 Saremi A, Schwenke DC, Bahn G, et al. (2015). The effect of intensive glucose lowering therapy among major racial/ethnic groups in the Veterans Affairs Diabetes Trial. Metabolism.
15 Bolen S, Wilson L, Vassy J, et al. (2007). Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults with Type 2 Diabetes.
16 Bennett WL, Wilson LM, Bolen S, et al. (2011). Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update.
17 Bolen S, Feldman L, Vassy J, et al. (2007). Systematic review: comparative effectiveness and safety of oral medications for type 2 diabetes mellitus. Ann Intern Med.
18 Bennett WL, Maruthur NM, Singh S, et al. (2011). Comparative effectiveness and safety of medications for type 2 diabetes: an update including new drugs and 2-drug combinations. Ann Intern Med.
19 Garber A, Abrahamson M, Barzilay J, et al. (2013). American association of clinical endocrinologists' comprehensive diabetes management algorithm 2013 consensus statement. Endocrine Practice.
20 Inzucchi SE, Bergenstal RM, Buse JB, et al. (2015). Management of Hyperglycemia in Type 2 Diabetes, 2015: A Patient-Centered Approach: Update to a position statement of the american diabetes association and the european association for the study of diabetes. Diabetes Care.
21 (2008). Type 2 Diabetes: National Clinical Guideline for Management in Primary and Secondary Care (Update).
22 Colhoun HM, Livingstone SJ, Looker HC, et al. (2012). Hospitalised hip fracture risk with rosiglitazone and pioglitazone use compared with other glucose-lowering drugs. Diabetologia.
23 Lu CJ, Sun Y, Muo CH, et al. (2013). Risk of stroke with thiazolidinediones: a ten-year nationwide population-based cohort study. Cerebrovasc Dis.
24 Mahaffey KW, Hafley G, Dickerson S, et al. (2013). Results of a reevaluation of cardiovascular outcomes in the RECORD trial. Am Heart J.
25 Mamtani R, Haynes K, Bilker WB, et al. (2012). Association between longer therapy with thiazolidinediones and risk of bladder cancer: a cohort study. J Natl Cancer Inst.
26 (2015). (7) Approaches to glycemic treatment. Diabetes Care.
27 Turner LW, Nartey D, Stafford RS, et al. (2014). Ambulatory treatment of type 2 diabetes in the U.S., 1997-2012. Diabetes Care.
28 Raebel MA, Xu S, Goodrich GK, et al. (2013). Initial antihyperglycemic drug therapy among 241 327 adults with newly identified diabetes from 2005 through 2010: a surveillance, prevention, and management of diabetes mellitus (SUPREME-DM) study. Ann Pharmacother.
29 Stone NJ, Robinson JG, Lichtenstein AH, et al. (2014). 2013 ACC/AHA Guideline on the Treatment of Blood Cholesterol to Reduce Atherosclerotic Cardiovascular Risk in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Circulation.
30 (2015). (8) Cardiovascular disease and risk management. Diabetes Care.
31 Tsertsvadze A, Maglione M, Chou R, et al. (2011). Updating comparative effectiveness reviews: current efforts in AHRQ's Effective Health Care Program. J Clin Epidemiol.
32 Higgins JPT. (2011). S. G. Cochrane handbook for systemic reviews of interventions Version 5.1.0.
33 Jadad AR, Moore RA, Carroll D, et al. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
34 Downs SH, Black N. (1998). The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health.
35 Institute of Medicine. (2011). Finding What Works in Health Care: Standards for Systematic Reviews.
36 Gaede P, Lund-Andersen H, Parving HH, Pedersen O. (2008). Effect of a multifactorial intervention on mortality in type 2 diabetes. The New England journal of medicine.
37 Higgins JP, Thompson SG, Deeks JJ, Altman DG. (2003). Measuring inconsistency in meta-analyses. BMJ.
38 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
39 Cornell JE, Mulrow CD, Localio R, et al. (2014). Random-Effects Meta-analysis of Inconsistent Effects: A Time for Change. Ann Intern Med.
40 Balshem H, Stevens A, Ansari M, et al. (2008). Finding Grey Literature Evidence and Assessing for Outcome and Analysis Reporting Biases When Comparing Medical Interventions: AHRQ and the Effective Health Care Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
41 Begg CB, Mazumdar M. (1994). Operating characteristics of a rank correlation test for publication bias. Biometrics.
42 Egger M, Davey Smith G, Schneider M, Minder C. (1997). Bias in meta-analysis detected by a simple, graphical test. BMJ.
43 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective healthcare program. J Clin Epidemiol.
44 Singh N. (2002). Diabetes, heart rate, and mortality. J Cardiovasc Pharmacol Ther.
45 Lenters-Westra E, Schindhelm RK, Bilo HJ, et al. (2014). Differences in interpretation of haemoglobin A1c values among diabetes care professionals. Neth J Med.
46 Dupont WD, Plummer WD. (1990). Power and sample size calculations. A review and computer program. Control Clin Trials.
47 Tosi F, Muggeo M, Brun E, et al. (2003). Combination treatment with metformin and glibenclamide versus single-drug therapies in type 2 diabetes mellitus: a randomized, double-blind, comparative study. Metabolism.
48 Alba M, Ahren B, Inzucchi SE, et al. (2013). Sitagliptin and pioglitazone provide complementary effects on postprandial glucose and pancreatic islet cell function. Diabetes Obes Metab.
49 Home PD, Pocock SJ, Beck-Nielsen H, et al. (2009). Rosiglitazone evaluated for cardiovascular outcomes in oral agent combination therapy for type 2 diabetes (RECORD): a multicentre, randomised, open-label trial. Lancet.
50 Kahn SE, Haffner SM, Heise MA, et al. (2006). Glycemic durability of rosiglitazone, metformin, or glyburide monotherapy. The New England journal of medicine.
51 Bergenstal RM, Forti A, Chiasson JL, et al. (2012). Efficacy and safety of taspoglutide versus sitagliptin for type 2 diabetes mellitus (T-emerge 4 trial). Diabetes Ther.
52 Tolman KG, Freston JW, Kupfer S, Perez A. (2009). Liver safety in patients with type 2 diabetes treated with pioglitazone: results from a 3-year, randomized, comparator-controlled study in the US. Drug Saf.
53 Gallwitz B, Guzman J, Dotta F, et al. (2012). Exenatide twice daily versus glimepiride for prevention of glycaemic deterioration in patients with type 2 diabetes with metformin failure (EUREXA): an open-label, randomised controlled trial. Lancet.
54 Del Prato S, Nauck M, Duran-Garcia S, et al. (2015). Long-term glycaemic response and tolerability of dapagliflozin versus a sulphonylurea as add-on therapy to metformin in type 2 diabetes patients: 4-year data. Diabetes Obes Metab.
55 Derosa G, Maffioli P, Salvadeo SA, et al. (2009). Direct comparison among oral hypoglycemic agents and their association with insulin resistance evaluated by euglycemic hyperinsulinemic clamp: the 60's study. Metabolism.
56 Gupta AK, Smith SR, Greenway FL, Bray GA. (2009). Pioglitazone treatment in type 2 diabetes mellitus when combined with portion control diet modifies the metabolic syndrome. Diabetes Obes Metab.
57 Erdem G, Dogru T, Tasci I, et al. (2008). The effects of pioglitazone and metformin on plasma visfatin levels in patients with treatment naive type 2 diabetes mellitus. Diabetes Res Clin Pract.
58 Iliadis F, Kadoglou NP, Hatzitolios A, et al. (2007). Metabolic effects of rosiglitazone and metformin in Greek patients with recently diagnosed type 2 diabetes. In Vivo.
59 Rosenstock J, Rood J, Cobitz A, et al. (2006). Initial treatment with rosiglitazone/metformin fixed-dose combination therapy compared with monotherapy with either rosiglitazone or metformin in patients with uncontrolled type 2 diabetes. Diabetes Obes Metab.
60 Yamanouchi T, Sakai T, Igarashi K, et al. (2005). Comparison of metabolic effects of pioglitazone, metformin, and glimepiride over 1 year in Japanese patients with newly diagnosed Type 2 diabetes. Diabet Med.
61 Ramachandran A, Snehalatha C, Salini J, Vijay V. (2004). Use of glimepiride and insulin sensitizers in the treatment of type 2 diabetes--a study in Indians. J Assoc Physicians India.
62 Schernthaner G, Matthews DR, Charbonnel B, et al. (2004). Efficacy and safety of pioglitazone versus metformin in patients with type 2 diabetes mellitus: a double-blind, randomized trial. J Clin Endocrinol Metab.
63 Lawrence JM, Reid J, Taylor GJ, et al. (2004). Favorable effects of pioglitazone and metformin compared with gliclazide on lipoprotein subfractions in overweight patients with early type 2 diabetes. Diabetes Care.
64 Pavo I, Jermendy G, Varkonyi TT, et al. (2003). Effect of pioglitazone compared with metformin on glycemic control and indicators of insulin sensitivity in recently diagnosed patients with type 2 diabetes. J Clin Endocrinol Metab.
65 Hallsten K, Virtanen KA, Lonnqvist F, et al. (2002). Rosiglitazone but not metformin enhances insulin- and exercise-stimulated skeletal muscle glucose uptake in patients with newly diagnosed type 2 diabetes. Diabetes.
66 Kiyici S, Ersoy C, Kaderli A, et al. (2009). Effect of rosiglitazone, metformin and medical nutrition treatment on arterial stiffness, serum MMP-9 and MCP-1 levels in drug naive type 2 diabetic patients. Diabetes Research and Clinical Practice.
67 Perez A, Zhao Z, Jacks R, Spanheimer R. (2009). Efficacy and safety of pioglitazone/metformin fixed-dose combination therapy compared with pioglitazone and metformin monotherapy in treating patients with T2DM. Curr Med Res Opin.
68 Kato T, Sawai Y, Kanayama H, et al. (2009). Comparative study of low-dose pioglitazone or metformin treatment in Japanese diabetic patients with metabolic syndrome. Exp Clin Endocrinol Diabetes.
69 Esteghamati A, Ghasemiesfe M, Mousavizadeh M, et al. (2014). Pioglitazone and metformin are equally effective in reduction of chemerin in patients with type 2 diabetes. J Diabetes Investig.
70 Erem C, Ozbas HM, Nuhoglu I, et al. (2014). Comparison of effects of gliclazide, metformin and pioglitazone monotherapies on glycemic control and cardiovascular risk factors in patients with newly diagnosed uncontrolled type 2 diabetes mellitus. Exp Clin Endocrinol Diabetes.
71 Genovese S, De Berardis G, Nicolucci A, et al. (2013). Effect of pioglitazone versus metformin on cardiovascular risk markers in type 2 diabetes. Adv Ther.
72 Taslimi S, Esteghamati A, Rashidi A, et al. (2013). Treatment with pioglitazone is associated with decreased preprandial ghrelin levels: a randomized clinical trial. Peptides.
73 Russell-Jones D, Cuddihy RM, Hanefeld M, et al. (2012). Efficacy and safety of exenatide once weekly versus metformin, pioglitazone, and sitagliptin used as monotherapy in drug-naive patients with type 2 diabetes (DURATION-4): a 26-week double-blind study. Diabetes Care.
74 Yoon KH, Shin JA, Kwon HS, et al. (2011). Comparison of the efficacy of glimepiride, metformin, and rosiglitazone monotherapy in korean drug-naive type 2 diabetic patients: the practical evidence of antidiabetic monotherapy study. Diabetes Metab J.
75 Fidan E, Onder Ersoz H, Yilmaz M, et al. (2011). The effects of rosiglitazone and metformin on inflammation and endothelial dysfunction in patients with type 2 diabetes mellitus. Acta Diabetol.
76 Esposito K, Maiorino MI, Di Palo C, et al. (2011). Effects of pioglitazone versus metformin on circulating endothelial microparticles and progenitor cells in patients with newly diagnosed type 2 diabetes--a randomized controlled trial. Diabetes Obes Metab.
77 Esteghamati A, Azizi R, Ebadi M, et al. (2015). The Comparative Effect of Pioglitazone and Metformin on Serum Osteoprotegerin, Adiponectin and Intercellular Adhesion Molecule Concentrations in Patients with Newly Diagnosed Type 2 Diabetes: a Randomized Clinical Trial. Exp Clin Endocrinol Diabetes.
78 Turkmen Kemal Y, Guvener Demirag N, Yildirir A, et al. (2007). Effects of rosiglitazone on plasma brain natriuretic peptide levels and myocardial performance index in patients with type 2 diabetes mellitus. Acta Diabetol.
79 Gupta RK, Rehan HS, Rohatagi A, et al. (2010). The effect of glipizide, metformin and rosiglitazone on nontraditional cardiovascular risk factors in newly diagnosed patients with type 2 diabetes mellitus. International journal of diabetes in developing countries.
80 Goldstein BJ, Feinglos MN, Lunceford JK, et al. (2007). Effect of initial combination therapy with sitagliptin, a dipeptidyl peptidase-4 inhibitor, and metformin on glycemic control in patients with type 2 diabetes. Diabetes Care.
81 Williams-Herman D, Johnson J, Teng R, et al. (2009). Efficacy and safety of initial combination therapy with sitagliptin and metformin in patients with type 2 diabetes: a 54-week study. Curr Med Res Opin.
82 Aschner P, Katzeff HL, Guo H, et al. (2010). Efficacy and safety of monotherapy of sitagliptin compared with metformin in patients with type 2 diabetes. Diabetes Obes Metab.
83 Jadzinsky M, Pfutzner A, Paz-Pacheco E, et al. (2009). Saxagliptin given in combination with metformin as initial therapy improves glycaemic control in patients with type 2 diabetes compared with either monotherapy: a randomized controlled trial. Diabetes Obes Metab.
84 Pratley RE, Fleck P, Wilson C. (2014). Efficacy and safety of initial combination therapy with alogliptin plus metformin versus either as monotherapy in drug-naive patients with type 2 diabetes: a randomized, double-blind, 6-month study. Diabetes Obes Metab.
85 Williams-Herman D, Johnson J, Teng R, et al. (2010). Efficacy and safety of sitagliptin and metformin as initial combination therapy and as monotherapy over 2 years in patients with type 2 diabetes. Diabetes Obes Metab.
86 Haak T, Meinicke T, Jones R, et al. (2012). Initial combination of linagliptin and metformin improves glycaemic control in type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab.
87 Pfutzner A, Paz-Pacheco E, Allen E, et al. (2011). Initial combination therapy with saxagliptin and metformin provides sustained glycaemic control and is well tolerated for up to 76 weeks. Diabetes Obes Metab.
88 Henry RR, Murray AV, Marmolejo MH, et al. (2012). Dapagliflozin, metformin XR, or both: initial pharmacotherapy for type 2 diabetes, a randomised controlled trial. Int J Clin Pract.
89 List JF, Woo V, Morales E, et al. (2009). Sodium-glucose cotransport inhibition with dapagliflozin in type 2 diabetes. Diabetes Care.
90 Ferrannini E, Berk A, Hantel S, et al. (2013). Long-term safety and efficacy of empagliflozin, sitagliptin, and metformin: An active-controlled, parallel-group, randomized, 78-week open-label extension study in patients with type 2 diabetes. Diabetes Care.
91 Umpierrez G, Povedano ST, Manghi FP, et al. (2014). Efficacy and Safety of Dulaglutide Monotherapy Versus Metformin in Type 2 Diabetes in a Randomized Controlled Trial (AWARD-3). Diabetes Care.
92 Yuan GH, Song WL, Huang YY, et al. (2012). Efficacy and tolerability of exenatide monotherapy in obese patients with newly diagnosed type 2 diabetes: a randomized, 26 weeks metformin-controlled, parallel-group study. Chin Med J (Engl).
93 Teramoto T, Yamada N, Shirai K, Saito Y. (2007). Effects of pioglitazone hydrochloride on Japanese patients with type 2 diabetes mellitus. J Atheroscler Thromb.
94 Hanefeld M, Patwardhan R, Jones NP. (2007). A one-year study comparing the efficacy and safety of rosiglitazone and glibenclamide in the treatment of type 2 diabetes. Nutr Metab Cardiovasc Dis.
95 Jain R, Osei K, Kupfer S, et al. (2006). Long-term safety of pioglitazone versus glyburide in patients with recently diagnosed type 2 diabetes mellitus. Pharmacotherapy.
96 Nakamura T, Matsuda T, Kawagoe Y, et al. (2004). Effect of pioglitazone on carotid intima-media thickness and arterial stiffness in type 2 diabetic nephropathy patients. Metabolism.
97 Nakamura T, Ushiyama C, Shimada N, et al. (2000). Comparative effects of pioglitazone, glibenclamide, and voglibose on urinary endothelin-1 and albumin excretion in diabetes patients. J Diabetes Complications.
98 Bakris G, Viberti G, Weston WM, et al. (2003). Rosiglitazone reduces urinary albumin excretion in type II diabetes. J Hum Hypertens.
99 Pfutzner A, Marx N, Lubben G, et al. (2005). Improvement of cardiovascular risk markers by pioglitazone is independent from glycemic control: results from the pioneer study. J Am Coll Cardiol.
100 Tan MH, Johns D, Strand J, et al. (2004). Sustained effects of pioglitazone vs. glibenclamide on insulin sensitivity, glycaemic control, and lipid profiles in patients with Type 2 diabetes. Diabet Med.
101 Tan M, Johns D, Gonzalez Galvez G, et al. (2004). Effects of pioglitazone and glimepiride on glycemic control and insulin sensitivity in Mexican patients with type 2 diabetes mellitus: A multicenter, randomized, double-blind, parallel-group trial. Clin Ther.
102 Nakamura T, Sugaya T, Kawagoe Y, et al. (2006). Effect of pioglitazone on urinary liver-type fatty acid-binding protein concentrations in diabetes patients with microalbuminuria. Diabetes Metab Res Rev.
103 Shihara N, Kitaoka M, Inagaki N, et al. (2011). Randomized controlled trial of single-agent glimepiride and pioglitazone in Japanese patients with type 2 diabetes: A comparative study. J Diabetes Investig.
104 Rosenstock J, Inzucchi SE, Seufert J, et al. (2010). Initial combination therapy with alogliptin and pioglitazone in drug-naive patients with type 2 diabetes. Diabetes Care.
105 Xu W, Bi Y, Sun Z, et al. (2015). Comparison of the effects on glycaemic control and beta-cell function in newly diagnosed type 2 diabetes patients of treatment with exenatide, insulin or pioglitazone: a multicentre randomized parallel-group trial (the CONFIDENCE study). J Intern Med.
106 Barnett AH, Patel S, Harper R, et al. (2012). Linagliptin monotherapy in type 2 diabetes patients for whom metformin is inappropriate: an 18-week randomized, double-blind, placebo-controlled phase III trial with a 34-week active-controlled extension. Diabetes Obes Metab.
107 Arjona Ferreira JC, Marre M, Barzilai N, et al. (2013). Efficacy and safety of sitagliptin versus glipizide in patients with type 2 diabetes and moderate-to-severe chronic renal insufficiency. Diabetes Care.
108 Scott R, Wu M, Sanchez M, Stein P. (2007). Efficacy and tolerability of the dipeptidyl peptidase-4 inhibitor sitagliptin as monotherapy over 12 weeks in patients with type 2 diabetes. Int J Clin Pract.
109 Seino Y, Rasmussen MF, Nishida T, Kaku K. (2010). Efficacy and safety of the once-daily human GLP-1 analogue, liraglutide, vs glibenclamide monotherapy in Japanese patients with type 2 diabetes. Curr Med Res Opin.
110 Kaku K, Rasmussen MF, Nishida T, Seino Y. (2011). Fifty-two-week, randomized, multicenter trial to compare the safety and efficacy of the novel glucagon-like peptide-1 analog liraglutide vs glibenclamide in patients with type 2 diabetes. J Diabetes Investig.
111 Madsbad S, Schmitz O, Ranstam J, et al. (2004). Improved glycemic control with no weight increase in patients with type 2 diabetes after once-daily treatment with the long-acting glucagon-like peptide 1 analog liraglutide (NN2211): a 12-week, double-blind, randomized, controlled trial. Diabetes Care.
112 Garber A, Henry R, Ratner R, et al. (2009). Liraglutide versus glimepiride monotherapy for type 2 diabetes (LEAD-3 Mono): a randomised, 52-week, phase III, double-blind, parallel-treatment trial. Lancet.
113 Garber A, Henry RR, Ratner R, et al. (2011). Liraglutide, a once-daily human glucagon-like peptide 1 analogue, provides sustained improvements in glycaemic control and weight for 2 years as monotherapy compared with glimepiride in patients with type 2 diabetes. Diabetes Obes Metab.
114 Roden M, Weng J, Eilbracht J, et al. (2013). Empagliflozin monotherapy with sitagliptin as an active comparator in patients with type 2 diabetes: A randomised, double-blind, placebo-controlled, phase 3 trial. The Lancet Diabetes and Endocrinology.
115 Suzuki K, Tanaka S, Aoki C, et al. (2014). Greater efficacy and improved endothelial dysfunction in untreated type 2 diabetes with liraglutide versus sitagliptin. Dokkyo Journal of Medical Sciences.
116 Leiter LA, Harris SB, Chiasson J-L, et al. (2005). Efficacy and safety of Rosiglitazone as monotherapy or in combination with metformin in primary care settings. Can J Diabetes.
117 Kaku K. (2009). Efficacy and safety of therapy with metformin plus pioglitazone in the treatment of patients with type 2 diabetes: a double-blind, placebo-controlled, clinical trial. Curr Med Res Opin.
118 Scott R, Loeys T, Davies MJ, Engel SS. (2008). Efficacy and safety of sitagliptin when added to ongoing metformin therapy in patients with type 2 diabetes. Diabetes Obes Metab.
119 Weissman P, Goldstein BJ, Rosenstock J, et al. (2005). Effects of rosiglitazone added to submaximal doses of metformin compared with dose escalation of metformin in type 2 diabetes: the EMPIRE Study. Curr Med Res Opin.
120 Bailey CJ, Bagdonas A, Rubes J, et al. (2005). Rosiglitazone/metformin fixed-dose combination compared with uptitrated metformin alone in type 2 diabetes mellitus: a 24-week, multicenter, randomized, double-blind, parallel-group study. Clin Ther.
121 Gomez-Perez FJ, Fanghanel-Salmon G, Antonio Barbosa J, et al. (2002). Efficacy and safety of rosiglitazone plus metformin in Mexicans with type 2 diabetes. Diabetes Metab Res Rev.
122 Einhorn D, Rendell M, Rosenzweig J, et al. (2000). Pioglitazone hydrochloride in combination with metformin in the treatment of type 2 diabetes mellitus: a randomized, placebo-controlled study. The Pioglitazone 027 Study Group. Clin Ther.
123 Fonseca V, Rosenstock J, Patwardhan R, Salzman A. (2000). Effect of metformin and rosiglitazone combination therapy in patients with type 2 diabetes mellitus: a randomized controlled trial. JAMA.
124 Kadoglou NP, Kapelouzou A, Tsanikidis H, et al. (2011). Effects of rosiglitazone/metformin fixed-dose combination therapy and metformin monotherapy on serum vaspin, adiponectin and IL-6 levels in drug-naive patients with type 2 diabetes. Exp Clin Endocrinol Diabetes.
125 Genovese S, Passaro A, Brunetti P, et al. (2013). Pioglitazone Randomised Italian Study on Metabolic Syndrome (PRISMA): effect of pioglitazone with metformin on HDL-C levels in Type 2 diabetic patients. J Endocrinol Invest.
126 DeFronzo RA, Burant CF, Fleck P, et al. (2012). Efficacy and tolerability of the DPP-4 inhibitor alogliptin combined with pioglitazone, in metformin-treated patients with type 2 diabetes. J Clin Endocrinol Metab.
127 Borges JL, Bilezikian JP, Jones-Leone AR, et al. (2011). A randomized, parallel group, double-blind, multicentre study comparing the efficacy and safety of Avandamet (rosiglitazone/metformin) and metformin on long-term glycaemic control and bone mineral density after 80 weeks of treatment in drug-naive type 2 diabetes mellitus patients. Diabetes Obes Metab.
128 Feinglos M, Dailey G, Cefalu W, et al. (2005). Effect on glycemic control of the addition of 2.5 mg glipizide GITS to metformin in patients with T2DM. Diabetes Res Clin Pract.
129 Garber AJ, Donovan DSJ, Dandona P, et al. (2003). Efficacy of glyburide/metformin tablets compared with initial monotherapy in type 2 diabetes. J Clin Endocrinol Metab.
130 Goldstein BJ, Pans M, Rubin CJ. (2003). Multicenter, randomized, double-masked, parallel-group assessment of simultaneous glipizide/metformin as second-line pharmacologic treatment for patients with type 2 diabetes mellitus that is inadequately controlled by a sulfonylurea. Clin Ther.
131 Blonde L, Rosenstock J, Mooradian AD, et al. (2002). Glyburide/metformin combination product is safe and efficacious in patients with type 2 diabetes failing sulphonylurea therapy. Diabetes Obes Metab.
132 Marre M, Howlett H, Lehert P, Allavoine T. (2002). Improved glycaemic control with metformin-glibenclamide combined tablet therapy (Glucovance) in Type 2 diabetic patients inadequately controlled on metformin. Diabet Med.
133 Garber AJ, Larsen J, Schneider SH, et al. (2002). Simultaneous glyburide/metformin therapy is superior to component monotherapy as an initial pharmacological treatment for type 2 diabetes. Diabetes Obes Metab.
134 Hermann LS, Schersten B, Bitzen PO, et al. (1994). Therapeutic comparison of metformin and sulfonylurea, alone and in various combinations. A double-blind controlled study. Diabetes Care.
135 Hermann LS, Bitzen PO, Kjellstrom T, et al. (1991). Comparative efficacy of metformin and glibenclamide in patients with non-insulin-dependent diabetes mellitus. Diabete Metab.
136 Charpentier G, Fleury F, Kabir M, et al. (2001). Improved glycaemic control by addition of glimepiride to metformin monotherapy in type 2 diabetic patients. Diabet Med.
137 DeFronzo RA, Goodman AM. (1995). Efficacy of metformin in patients with non-insulin-dependent diabetes mellitus. The Multicenter Metformin Study Group. The New England journal of medicine.
138 Chien HH, Chang CT, Chu NF, et al. (2007). Effect of glyburide-metformin combination tablet in patients with type 2 diabetes. J Chin Med Assoc.
139 Forst T, Uhlig-Laske B, Ring A, et al. (2010). Linagliptin (BI 1356), a potent and selective DPP-4 inhibitor, is safe and efficacious in combination with metformin in patients with inadequately controlled Type 2 diabetes. Diabet Med.
140 Kim HS, Kim DM, Cha BS, et al. (2014). Efficacy of glimepiride/metformin fixed-dose combination vs metformin uptitration in type 2 diabetic patients inadequately controlled on low-dose metformin monotherapy: A randomized, open label, parallel group, multicenter study in Korea. Journal of Diabetes Investigation.
141 Ahren B, Johnson SL, Stewart M, et al. (2014). HARMONY 3: 104-Week Randomized, Double-Blind, Placebo- and Active-Controlled Trial Assessing the Efficacy and Safety of Albiglutide Compared With Placebo, Sitagliptin, and Glimepiride in Patients With Type 2 Diabetes Taking Metformin. Diabetes Care.
142 Raz I, Chen Y, Wu M, et al. (2008). Efficacy and safety of sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes. Curr Med Res Opin.
143 Charbonnel B, Karasik A, Liu J, et al. (2006). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes inadequately controlled with metformin alone. Diabetes Care.
144 DeFronzo RA, Hissa MN, Garber AJ, et al. (2009). The efficacy and safety of saxagliptin when added to metformin therapy in patients with inadequately controlled type 2 diabetes with metformin alone. Diabetes Care.
145 Reasner C, Olansky L, Seck TL, et al. (2011). The effect of initial therapy with the fixed-dose combination of sitagliptin and metformin compared with metformin monotherapy in patients with type 2 diabetes mellitus. Diabetes Obes Metab.
146 Yang W, Pan CY, Tou C, et al. (2011). Efficacy and safety of saxagliptin added to metformin in Asian people with type 2 diabetes mellitus: a randomized controlled trial. Diabetes Res Clin Pract.
147 Fonseca V, Zhu T, Karyekar C, Hirshberg B. (2012). Adding saxagliptin to extended-release metformin vs. uptitrating metformin dosage. Diabetes Obes Metab.
148 Yang W, Guan Y, Shentu Y, et al. (2012). The addition of sitagliptin to ongoing metformin therapy significantly improves glycemic control in Chinese patients with type 2 diabetes. J Diabetes.
149 Kadowaki T, Tajima N, Odawara M, et al. (2013). Addition of sitagliptin to ongoing metformin monotherapy improves glycemic control in Japanese patients with type 2 diabetes over 52 weeks. J Diabetes Investig.
150 Derosa G, Carbone A, D'Angelo A, et al. (2013). Variations in inflammatory biomarkers following the addition of sitagliptin in patients with type 2 diabetes not controlled with metformin. Intern Med.
151 White JL, Buchanan P, Li J, Frederich R. (2014). A randomized controlled trial of the efficacy and safety of twice-daily saxagliptin plus metformin combination therapy in patients with type 2 diabetes and inadequate glycemic control on metformin monotherapy. BMC Endocr Disord.
152 Ross SA, Rafeiro E, Meinicke T, et al. (2012). Efficacy and safety of linagliptin 25?mg twice daily versus 5?mg once daily in patients with type 2 diabetes inadequately controlled on metformin: a randomised, double-blind, placebo-controlled trial. Curr Med Res Opin.
153 Rosenstock J, Seman LJ, Jelaska A, et al. (2013). Efficacy and safety of empagliflozin, a sodium glucose cotransporter 2 (SGLT2) inhibitor, as add-on to metformin in type 2 diabetes with mild hyperglycaemia. Diabetes Obes Metab.
154 Nauck MA, Ellis GC, Fleck PR, et al. (2009). Efficacy and safety of adding the dipeptidyl peptidase-4 inhibitor alogliptin to metformin therapy in patients with type 2 diabetes inadequately controlled with metformin monotherapy: a multicentre, randomised, double-blind, placebo-controlled study. Int J Clin Pract.
155 Taskinen MR, Rosenstock J, Tamminen I, et al. (2011). Safety and efficacy of linagliptin as add-on therapy to metformin in patients with type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab.
156 Rosenstock J, Aggarwal N, Polidori D, et al. (2012). Dose-ranging effects of canagliflozin, a sodium-glucose cotransporter 2 inhibitor, as add-on to metformin in subjects with type 2 diabetes. Diabetes Care.
157 Seino Y, Miyata Y, Hiroi S, et al. (2012). Efficacy and safety of alogliptin added to metformin in Japanese patients with type 2 diabetes: a randomized, double-blind, placebo-controlled trial with an open-label, long-term extension study. Diabetes Obes Metab.
158 Lavalle-Gonzalez FJ, Januszewicz A, Davidson J, et al. (2013). Efficacy and safety of canagliflozin compared with placebo and sitagliptin in patients with type 2 diabetes on background metformin monotherapy: a randomised trial. Diabetologia.
159 Nauck M, Weinstock RS, Umpierrez GE, et al. (2014). Efficacy and Safety of Dulaglutide Versus Sitagliptin After 52 Weeks in Type 2 Diabetes in a Randomized Controlled Trial (AWARD-5). Diabetes Care.
160 Wang W, Yang J, Yang G, et al. (2015). Efficacy and safety of linagliptin in Asian patients with type 2 diabetes mellitus inadequately controlled by metformin: A multinational 24-week, randomized clinical trial. J Diabetes.
161 Hermans MP, Delibasi T, Farmer I, et al. (2012). Effects of saxagliptin added to sub-maximal doses of metformin compared with uptitration of metformin in type 2 diabetes: the PROMPT study. Curr Med Res Opin.
162 Ji L, Zinman B, Patel S, et al. (2015). Efficacy and safety of linagliptin co-administered with low-dose metformin once daily versus high-dose metformin twice daily in treatment-naive patients with type 2 diabetes: a double-blind randomized trial. Adv Ther.
163 Aaboe K, Knop FK, Vilsboll T, et al. (2010). Twelve weeks treatment with the DPP-4 inhibitor, sitagliptin, prevents degradation of peptide YY and improves glucose and non-glucose induced insulin secretion in patients with type 2 diabetes mellitus. Diabetes Obes Metab.
164 Haak T, Meinicke T, Jones R, et al. (2013). Initial combination of linagliptin and metformin in patients with type 2 diabetes: efficacy and safety in a randomised, double-blind 1-year extension study. Int J Clin Pract.
165 Qiu R, Capuano G, Meininger G. (2014). Efficacy and safety of twice-daily treatment with canagliflozin, a sodium glucose co-transporter 2 inhibitor, added on to metformin monotherapy in patients with type 2 diabetes mellitus. Journal of Clinical and Translational Endocrinology.
166 Haring HU, Merker L, Seewaldt-Becker E, et al. (2014). Empaglif lozin as add-on to metformin in patients with type 2 diabetes: A 24-week, randomized, double-blind, placebo-controlled trial. Diabetes Care.
167 Bailey CJ, Gross JL, Pieters A, et al. (2010). Effect of dapagliflozin in patients with type 2 diabetes who have inadequate glycaemic control with metformin: a randomised, double-blind, placebo-controlled trial. Lancet.
168 Schumm-Draeger PM, Burgess L, Koranyi L, et al. (2015). Twice-daily dapagliflozin co-administered with metformin in type 2 diabetes: a 16-week randomized, placebo-controlled clinical trial. Diabetes Obes Metab.
169 Bolinder J, Ljunggren O, Kullberg J, et al. (2012). Effects of dapagliflozin on body weight, total fat mass, and regional adipose tissue distribution in patients with type 2 diabetes mellitus with inadequate glycemic control on metformin. J Clin Endocrinol Metab.
170 Bailey CJ, Gross JL, Hennicken D, et al. (2013). Dapagliflozin add-on to metformin in type 2 diabetes inadequately controlled with metformin: a randomized, double-blind, placebo-controlled 102-week trial. BMC Med.
171 Derosa G, Cicero AF, Franzetti IG, et al. (2013). Effects of exenatide and metformin in combination on some adipocytokine levels: a comparison with metformin monotherapy. Can J Physiol Pharmacol.
172 Forst T, Michelson G, Ratter F, et al. (2012). Addition of liraglutide in patients with Type 2 diabetes well controlled on metformin monotherapy improves several markers of vascular function. Diabet Med.
173 Apovian CM, Bergenstal RM, Cuddihy RM, et al. (2010). Effects of exenatide combined with lifestyle modification in patients with type 2 diabetes. Am J Med.
174 DeFronzo RA, Ratner RE, Han J, et al. (2005). Effects of exenatide (exendin-4) on glycemic control and weight over 30 weeks in metformin-treated patients with type 2 diabetes. Diabetes Care.
175 Hamann A, Garcia-Puig J, Paul G, et al. (2008). Comparison of fixed-dose rosiglitazone/metformin combination therapy with sulphonylurea plus metformin in overweight individuals with Type 2 diabetes inadequately controlled on metformin alone. Exp Clin Endocrinol Diabetes.
176 Home PD, Jones NP, Pocock SJ, et al. (2007). Rosiglitazone RECORD study: glucose control outcomes at 18 months. Diabet Med.
177 Bakris GL, Ruilope LM, McMorn SO, et al. (2006). Rosiglitazone reduces microalbuminuria and blood pressure independently of glycemia in type 2 diabetes patients with microalbuminuria. J Hypertens.
178 Umpierrez G, Issa M, Vlajnic A. (2006). Glimepiride versus pioglitazone combination therapy in subjects with type 2 diabetes inadequately controlled on metformin monotherapy: results of a randomized clinical trial. Curr Med Res Opin.
179 Derosa G, Gaddi AV, Piccinni MN, et al. (2005). Antithrombotic effects of rosiglitazone-metformin versus glimepiride-metformin combination therapy in patients with type 2 diabetes mellitus and metabolic syndrome. Pharmacotherapy.
180 Garber A, Klein E, Bruce S, et al. (2006). Metformin-glibenclamide versus metformin plus rosiglitazone in patients with type 2 diabetes inadequately controlled on metformin monotherapy. Diabetes Obes Metab.
181 Maffioli P, Fogari E, D'Angelo A, et al. (2013). Ultrasonography modifications of visceral and subcutaneous adipose tissue after pioglitazone or glibenclamide therapy combined with rosuvastatin in type 2 diabetic patients not well controlled by metformin. Eur J Gastroenterol Hepatol.
182 Petrica L, Petrica M, Vlad A, et al. (2009). Nephro- and neuroprotective effects of rosiglitazone versus glimepiride in normoalbuminuric patients with type 2 diabetes mellitus: a randomized controlled trial. Wien Klin Wochenschr.
183 Comaschi M, Demicheli A, Di Pietro C, et al. (2007). Effects of pioglitazone in combination with metformin or a sulfonylurea compared to a fixed-dose combination of metformin and glibenclamide in patients with type 2 diabetes. Diabetes Technol Ther.
184 Schondorf T, Musholt PB, Hohberg C, et al. (2011). The fixed combination of pioglitazone and metformin improves biomarkers of platelet function and chronic inflammation in type 2 diabetes patients: results from the PIOfix study. J Diabetes Sci Technol.
185 Pfutzner A, Schondorf T, Tschope D, et al. (2011). PIOfix-study: effects of pioglitazone/metformin fixed combination in comparison with a combination of metformin with glimepiride on diabetic dyslipidemia. Diabetes Technol Ther.
186 Rigby SP, Handelsman Y, Lai YL, et al. (2010). Effects of colesevelam, rosiglitazone, or sitagliptin on glycemic control and lipid profile in patients with type 2 diabetes mellitus inadequately controlled by metformin monotherapy. Endocr Pract.
187 Chawla S, Kaushik N, Singh NP, et al. (2013). Effect of addition of either sitagliptin or pioglitazone in patients with uncontrolled type 2 diabetes mellitus on metformin: A randomized controlled trial. J Pharmacol Pharmacother.
188 Bergenstal RM, Wysham C, Macconell L, et al. (2010). Efficacy and safety of exenatide once weekly versus sitagliptin or pioglitazone as an adjunct to metformin for treatment of type 2 diabetes (DURATION-2): a randomised trial. Lancet.
189 DeFronzo RA, Triplitt C, Qu Y, et al. (2010). Effects of exenatide plus rosiglitazone on beta-cell function and insulin sensitivity in subjects with type 2 diabetes on metformin. Diabetes Care.
190 Arechavaleta R, Seck T, Chen Y, et al. (2011). Efficacy and safety of treatment with sitagliptin or glimepiride in patients with type 2 diabetes inadequately controlled on metformin monotherapy: a randomized, double-blind, non-inferiority trial. Diabetes Obes Metab.
191 Forst T, Anastassiadis E, Diessel S, et al. (2014). Effect of linagliptin compared to glimepiride on postprandial glucose metabolism, islet cell function, and vascular function parameters in patients with type 2 diabetes mellitus on ongoing metformin treatment. Diabetes Metab Res Rev.
192 Nauck MA, Meininger G, Sheng D, et al. (2007). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor, sitagliptin, compared with the sulfonylurea, glipizide, in patients with type 2 diabetes inadequately controlled on metformin alone: a randomized, double-blind, non-inferiority trial. Diabetes Obes Metab.
193 Schernthaner G, Duran-Garcia S, Hanefeld M, et al. (2015). Efficacy and tolerability of saxagliptin compared with glimepiride in elderly patients with type 2 diabetes: a randomized, controlled study (GENERATION). Diabetes Obes Metab.
194 Gallwitz B, Rosenstock J, Rauch T, et al. (2012). 2-year efficacy and safety of linagliptin compared with glimepiride in patients with type 2 diabetes inadequately controlled on metformin: a randomised, double-blind, non-inferiority trial. Lancet.
195 Goke B, Gallwitz B, Eriksson J, et al. (2010). Saxagliptin is non-inferior to glipizide in patients with type 2 diabetes mellitus inadequately controlled on metformin alone: a 52-week randomised controlled trial. Int J Clin Pract.
196 Seck T, Nauck M, Sheng D, et al. (2010). Safety and efficacy of treatment with sitagliptin or glipizide in patients with type 2 diabetes inadequately controlled on metformin: a 2-year study. Int J Clin Pract.
197 Del Prato S, Camisasca R, Wilson C, Fleck P. (2014). Durability of the efficacy and safety of alogliptin compared with glipizide in type 2 diabetes mellitus: a 2-year study. Diabetes Obes Metab.
198 Cefalu WT, Leiter LA, Yoon KH, et al. (2013). Efficacy and safety of canagliflozin versus glimepiride in patients with type 2 diabetes inadequately controlled with metformin (CANTATA-SU): 52 week results from a randomised, double-blind, phase 3 non-inferiority trial. Lancet.
199 Nauck MA, Del Prato S, Meier JJ, et al. (2011). Dapagliflozin versus glipizide as add-on therapy in patients with type 2 diabetes who have inadequate glycemic control with metformin: a randomized, 52-week, double-blind, active-controlled noninferiority trial. Diabetes Care.
200 Ridderstrale M, Andersen KR, Zeller C, et al. (2014). Comparison of empagliflozin and glimepiride as add-on to metformin in patients with type 2 diabetes: a 104-week randomised, active-controlled, double-blind, phase 3 trial. The Lancet Diabetes and Endocrinology.
201 Leiter LA, Yoon KH, Arias P, et al. (2015). Canagliflozin provides durable glycemic improvements and body weight reduction over 104 weeks versus glimepiride in patients with type 2 diabetes on metformin: a randomized, double-blind, phase 3 study. Diabetes Care.
202 Zhang H, Zhang X, Hu C, Lu W. (2012). Exenatide reduces urinary transforming growth factor-beta1 and type IV collagen excretion in patients with type 2 diabetes and microalbuminuria. Kidney Blood Press Res.
203 Derosa G, Putignano P, Bossi AC, et al. (2011). Exenatide or glimepiride added to metformin on metabolic control and on insulin resistance in type 2 diabetic patients. Eur J Pharmacol.
204 Yang W, Chen L, Ji Q, et al. (2011). Liraglutide provides similar glycaemic control as glimepiride (both in combination with metformin) and reduces body weight and systolic blood pressure in Asian population with type 2 diabetes from China, South Korea and India: a 16-week, randomized, double-blind, active control trial(*). Diabetes Obes Metab.
205 Derosa G, Maffioli P, Salvadeo SA, et al. (2010). Exenatide versus glibenclamide in patients with diabetes. Diabetes Technol Ther.
206 Moon JS, Ha KS, Yoon JS, et al. (2014). The effect of glargine versus glimepiride on pancreatic beta-cell function in patients with type 2 diabetes uncontrolled on metformin monotherapy: open-label, randomized, controlled study. Acta Diabetol.
207 Malone JK, Beattie SD, Campaigne BN, et al. (2003). Therapy after single oral agent failure: adding a second oral agent or an insulin mixture?. Diabetes Res Clin Pract.
208 Kvapil M, Swatko A, Hilberg C, Shestakova M. (2006). Biphasic insulin aspart 30 plus metformin: an effective combination in type 2 diabetes. Diabetes Obes Metab.
209 Rosenstock J, Hansen L, Zee P, et al. (2015). Dual Add-on Therapy in Type 2 Diabetes Poorly Controlled With Metformin Monotherapy: A Randomized Double-Blind Trial of Saxagliptin Plus Dapagliflozin Addition Versus Single Addition of Saxagliptin or Dapagliflozin to Metformin. Diabetes Care.
210 Pratley RE, Nauck M, Bailey T, et al. (2010). Liraglutide versus sitagliptin for patients with type 2 diabetes who did not have adequate glycaemic control with metformin: a 26-week, randomised, parallel-group, open-label trial. Lancet.
211 Aschner P, Chan J, Owens DR, et al. (2012). Insulin glargine versus sitagliptin in insulin-naive patients with type 2 diabetes mellitus uncontrolled on metformin (EASIE): a multicentre, randomised open-label trial. Lancet.
212 Diamant M, Van Gaal L, Stranks S, et al. (2010). Once weekly exenatide compared with insulin glargine titrated to target in patients with type 2 diabetes (DURATION-3): an open-label randomised trial. Lancet.
213 Gallwitz B, Bohmer M, Segiet T, et al. (2011). Exenatide twice daily versus premixed insulin aspart 70/30 in metformin-treated patients with type 2 diabetes: a randomized 26-week study on glycemic control and hypoglycemia. Diabetes Care.
214 Robbins DC, Beisswenger PJ, Ceriello A, et al. (2007). Mealtime 50/50 basal + prandial insulin analogue mixture with a basal insulin analogue, both plus metformin, in the achievement of target HbA1c and pre- and postprandial blood glucose levels in patients with type 2 diabetes: a multinational, 24-week, randomized, open-label, parallel-group comparison. Clin Ther.
215 Raskin PR, Hollander PA, Lewin A, et al. (2007). Basal insulin or premix analogue therapy in type 2 diabetes patients. Eur J Intern Med.
216 Davies MJ, Thaware PK, Tringham JR, et al. (2007). A randomized controlled trial examining combinations of repaglinide, metformin and NPH insulin. Diabet Med.
217 St John Sutton M, Rendell M, Dandona P, et al. (2002). A comparison of the effects of rosiglitazone and glyburide on cardiovascular function and glycemic control in patients with type 2 diabetes. Diabetes Care.
218 Derosa G, Cicero AF, Gaddi AV, et al. (2005). Long-term effects of glimepiride or rosiglitazone in combination with metformin on blood pressure control in type 2 diabetic patients affected by the metabolic syndrome: a 12-month, double-blind, randomized clinical trial. Clin Ther.
219 Nauck MA, Del Prato S, Duran-Garcia S, et al. (2014). Durability of glycaemic efficacy over 2 years with dapagliflozin versus glipizide as add-on therapies in patients whose type 2 diabetes mellitus was inadequately controlled with metformin. Diabetes Obes Metab.
220 Adler AI, Stratton IM, Neil HA, et al. (2000). Association of systolic blood pressure with macrovascular and microvascular complications of type 2 diabetes (UKPDS 36): prospective observational study. BMJ.
221 Holman RR, Paul SK, Bethel MA, et al. (2008). Long-term follow-up after tight control of blood pressure in type 2 diabetes. The New England journal of medicine.
222 Turnbull F, Neal B, Algert C, et al. (2005). Effects of different blood pressure-lowering regimens on major cardiovascular events in individuals with and without diabetes mellitus: results of prospectively designed overviews of randomized trials. Arch Intern Med.
223 Malone JK, Kerr LF, Campaigne BN, et al. (2004). Combined therapy with insulin lispro Mix 75/25 plus metformin or insulin glargine plus metformin: a 16-week, randomized, open-label, crossover study in patients with type 2 diabetes beginning insulin therapy. Clin Ther.
224 Malone JK, Bai S, Campaigne BN, et al. (2005). Twice-daily pre-mixed insulin rather than basal insulin therapy alone results in better overall glycaemic control in patients with Type 2 diabetes. Diabet Med.
225 Andersson C, Olesen JB, Hansen PR, et al. (2010). Metformin treatment is associated with a low risk of mortality in diabetic patients with heart failure: a retrospective nationwide cohort study. Diabetologia.
226 Horsdal HT, Sondergaard F, Johnsen SP, Rungby J. (2011). Antidiabetic treatments and risk of hospitalisation with myocardial infarction: a nationwide case-control study. Pharmacoepidemiol Drug Saf.
227 Mogensen UM, Andersson C, Fosbol EL, et al. (2014). Cardiovascular safety of combination therapies with incretin-based drugs and metformin compared with a combination of metformin and sulphonylurea in type 2 diabetes mellitus - a retrospective nationwide study. Diabetes Obes Metab.
228 Scheller NM, Mogensen UM, Andersson C, et al. (2014). All-cause mortality and cardiovascular effects associated with the DPP-IV inhibitor sitagliptin compared with metformin, a retrospective cohort study on the Danish population. Diabetes, obesity & metabolism.
229 Schramm TK, Gislason GH, Vaag A, et al. (2011). Mortality and cardiovascular risk associated with different insulin secretagogues compared with metformin in type 2 diabetes, with or without a previous myocardial infarction: a nationwide study. Eur Heart J.
230 Johnson JA, Simpson SH, Toth EL, Majumdar SR. (2005). Reduced cardiovascular morbidity and mortality associated with metformin use in subjects with Type 2 diabetes. Diabet Med.
231 Hong J, Zhang Y, Lai S, et al. (2013). Effects of metformin versus glipizide on cardiovascular outcomes in patients with type 2 diabetes and coronary artery disease. Diabetes Care.
232 Raskin P, Lewin A, Reinhardt R, Lyness W. (2009). Twice-daily dosing of a repaglinide/metformin fixed-dose combination tablet provides glycaemic control comparable to rosiglitazone/metformin tablet. Diabetes Obes Metab.
233 Pantalone KM, Kattan MW, Yu C, et al. (2009). The risk of developing coronary artery disease or congestive heart failure, and overall mortality, in type 2 diabetic patients receiving rosiglitazone, pioglitazone, metformin, or sulfonylureas: a retrospective analysis. Acta Diabetol.
234 Wheeler S, Moore K, Forsberg CW, et al. (2013). Mortality among veterans with type 2 diabetes initiating metformin, sulfonylurea or rosiglitazone monotherapy. Diabetologia.
235 Kahler KH, Rajan M, Rhoads GG, et al. (2007). Impact of oral antihyperglycemic therapy on all-cause mortality among patients with diabetes in the Veterans Health Administration. Diabetes Care.
236 Wang CP, Lorenzo C, Espinoza SE. (2014). Frailty Attenuates the Impact of Metformin on Reducing Mortality in Older Adults with Type 2 Diabetes. J Endocrinol Diabetes Obes.
237 Pantalone KM, Kattan MW, Yu C, et al. (2012). Increase in overall mortality risk in patients with type 2 diabetes receiving glipizide, glyburide or glimepiride monotherapy versus metformin: a retrospective analysis. Diabetes Obes Metab.
238 Corrao G, Romio SA, Zambon A, et al. (2011). Multiple outcomes associated with the use of metformin and sulphonylureas in type 2 diabetes: a population-based cohort study in Italy. Eur J Clin Pharmacol.
239 Ferrannini E, Seman L, Seewaldt-Becker E, et al. (2013). A Phase IIb, randomized, placebo-controlled study of the SGLT2 inhibitor empagliflozin in patients with type 2 diabetes. Diabetes, obesity & metabolism.
240 Stenlof K, Cefalu WT, Kim KA, et al. (2014). Long-term efficacy and safety of canagliflozin monotherapy in patients with type 2 diabetes inadequately controlled with diet and exercise: findings from the 52-week CANTATA-M study. Curr Med Res Opin.
241 Jones TA, Sautter M, Van Gaal LF, Jones NP. (2003). Addition of rosiglitazone to metformin is most effective in obese, insulin-resistant patients with type 2 diabetes. Diabetes Obes Metab.
242 Prentice JC, Conlin PR, Gellad WF, et al. (2014). Capitalizing on prescribing pattern variation to compare medications for type 2 diabetes. Value Health.
243 Hsiao FY, Huang WF, Wen YW, et al. (2009). Thiazolidinediones and cardiovascular events in patients with type 2 diabetes mellitus: a retrospective cohort study of over 473,000 patients using the National Health Insurance database in Taiwan. Drug Saf.
244 Brownstein JS, Murphy SN, Goldfine AB, et al. (2010). Rapid identification of myocardial infarction risk associated with diabetes medications using electronic medical records. Diabetes Care.
245 Hung YC, Lin CC, Wang TY, et al. (2013). Oral hypoglycaemic agents and the development of non-fatal cardiovascular events in patients with type 2 diabetes mellitus. Diabetes Metab Res Rev.
246 Roumie CL, Hung AM, Greevy RA, et al. (2012). Comparative effectiveness of sulfonylurea and metformin monotherapy on cardiovascular events in type 2 diabetes mellitus: a cohort study. Ann Intern Med.
247 Stewart MW, Cirkel DT, Furuseth K, et al. (2006). Effect of metformin plus roziglitazone compared with metformin alone on glycaemic control in well-controlled Type 2 diabetes. Diabet Med.
248 Goke B, Gallwitz B, Eriksson JG, et al. (2013). Saxagliptin vs. glipizide as add-on therapy in patients with type 2 diabetes mellitus inadequately controlled on metformin alone: long-term (52-week) extension of a 52-week randomised controlled trial. Int J Clin Pract.
249 Hung AM, Roumie CL, Greevy RA, et al. (2012). Comparative effectiveness of incident oral antidiabetic drugs on kidney function. Kidney Int.
250 Masica AL, Ewen E, Daoud YA, et al. (2013). Comparative effectiveness research using electronic health records: impacts of oral antidiabetic drugs on the development of chronic kidney disease. Pharmacoepidemiol Drug Saf.
251 Amador-Licona N, Guizar-Mendoza J, Vargas E, et al. (2000). The short-term effect of a switch from glibenclamide to metformin on blood pressure and microalbuminuria in patients with type 2 diabetes mellitus. Arch Med Res.
252 Hung AM, Roumie CL, Greevy RA, et al. (2013). Kidney function decline in metformin versus sulfonylurea initiators: assessment of time-dependent contribution of weight, blood pressure, and glycemic control. Pharmacoepidemiol Drug Saf.
253 Agarwal R, Saha C, Battiwala M, et al. (2005). A pilot randomized controlled trial of renal protection with pioglitazone in diabetic nephropathy. Kidney Int.
254 Lehman DM, Lorenzo C, Hernandez J, Wang CP. (2012). Statin use as a moderator of metformin effect on risk for prostate cancer among type 2 diabetic patients. Diabetes Care.
255 van Staa TP, Patel D, Gallagher AM, de Bruin ML. (2012). Glucose-lowering agents and the patterns of risk for cancer: a study with the General Practice Research Database and secondary care data. Diabetologia.
256 Skrivanek Z, Gaydos BL, Chien JY, et al. (2014). Dose-finding results in an adaptive, seamless, randomized trial of once-weekly dulaglutide combined with metformin in type 2 diabetes patients (AWARD-5). Diabetes Obes Metab.
257 Derosa G, Franzetti I, Gadaleta G, et al. (2004). Metabolic variations with oral antidiabetic drugs in patients with Type 2 diabetes: comparison between glimepiride and metformin. Diabetes Nutr Metab.
258 Wright AD, Cull CA, Macleod KM, Holman RR. (2006). Hypoglycemia in Type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications.
259 Weir MA, Gomes T, Mamdani M, et al. (2011). Impaired renal function modifies the risk of severe hypoglycaemia among users of insulin but not glyburide: a population-based nested case-control study. Nephrol Dial Transplant.
260 Gupta A, Ahmad Ansari N, Yadav N. (2013). Comparative efficacy and safety of sitagliptin and Glimepiride in patients of newly diagnosed type 2 diabetes mellitus. International Journal of Pharmaceutical Sciences Review and Research.
261 Nauck M, Frid A, Hermansen K, et al. (2009). Efficacy and safety comparison of liraglutide, glimepiride, and placebo, all in combination with metformin, in type 2 diabetes: the LEAD (liraglutide effect and action in diabetes)-2 study. Diabetes Care.
262 Lee YK, Song SO, Kim KJ, et al. (2013). Glycemic Effectiveness of Metformin-Based Dual-Combination Therapies with Sulphonylurea, Pioglitazone, or DPP4-Inhibitor in Drug-Naive Korean Type 2 Diabetic Patients. Diabetes Metab J.
263 Srivastava S, Saxena GN, Keshwani P, Gupta R. (2012). Comparing the efficacy and safety profile of sitagliptin versus glimepiride in patients of type 2 diabetes mellitus inadequately controlled with metformin alone. J Assoc Physicians India.
264 Davies M, Heller S, Sreenan S, et al. (2013). Once-weekly exenatide versus once- or twice-daily insulin detemir: randomized, open-label, clinical trial of efficacy and safety in patients with type 2 diabetes treated with metformin alone or in combination with sulfonylureas. Diabetes Care.
265 Derosa G, Gaddi AV, Ciccarelli L, et al. (2005). Long-term effect of glimepiride and rosiglitazone on non-conventional cardiovascular risk factors in metformin-treated patients affected by metabolic syndrome: a randomized, double-blind clinical trial. J Int Med Res.
266 Kowall B, Rathmann W, Kostev K. (2015). Are sulfonylurea and insulin therapies associated with a larger risk of cancer than metformin therapy? A retrospective database analysis. Diabetes Care.
267 Bolinder J, Ljunggren O, Johansson L, et al. (2014). Dapagliflozin maintains glycaemic control while reducing weight and body fat mass over 2 years in patients with type 2 diabetes mellitus inadequately controlled on metformin. Diabetes, obesity & metabolism.
268 Perez-Monteverde A, Seck T, Xu L, et al. (2011). Efficacy and safety of sitagliptin and the fixed-dose combination of sitagliptin and metformin vs. pioglitazone in drug-naive patients with type 2 diabetes. Int J Clin Pract.
269 Turner RC, Cull CA, Frighi V, Holman RR. (1999). Glycemic control with diet, sulfonylurea, metformin, or insulin in patients with type 2 diabetes mellitus: progressive requirement for multiple therapies (UKPDS 49). UK Prospective Diabetes Study (UKPDS) Group. JAMA.
270 Kawai T, Funae O, Shimada A, et al. (2008). Effects of pretreatment with low-dose metformin on metabolic parameters and weight gain by pioglitazone in Japanese patients with type 2 diabetes. Intern Med.
271 (1998). United Kingdom Prospective Diabetes Study 24: a 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. United Kingdom Prospective Diabetes Study Group. Ann Intern Med.
272 Gallwitz B, Rosenstock J, Patel S, et al. (2015). Regardless of the degree of glycaemic control, linagliptin has lower hypoglycaemia risk than all doses of glimepiride, at all time points, over the course of a 2-year trial. Diabetes Obes Metab.
273 Kahn SE, Zinman B, Lachin JM, et al. (2008). Rosiglitazone-associated fractures in type 2 diabetes: an Analysis from A Diabetes Outcome Progression Trial (ADOPT). Diabetes Care.
274 Dormuth CR, Carney G, Carleton B, et al. (2009). Thiazolidinediones and fractures in men and women. Arch Intern Med.
275 Schellhase KG, Koepsell TD, Weiss NS. (2005). Glycemic control and the risk of multiple microvascular diabetic complications. Fam Med.
276 Vijan S, Hofer TP, Hayward RA. (1997). Estimated benefits of glycemic control in microvascular complications in type 2 diabetes. Ann Intern Med.
277 Shyangdan DS, Royle P, Clar C, et al. (2011). Glucagon-like peptide analogues for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews.
278 Liu SC, Tu YK, Chien MN, Chien KL. (2012). Effect of antidiabetic agents added to metformin on glycaemic control, hypoglycaemia and weight change in patients with type 2 diabetes: A network meta-analysis. Diabetes, obesity & metabolism.
279 McIntosh B, Cameron C, Singh SR, et al. (2011). Second-line therapy in patients with type 2 diabetes inadequately controlled with metformin monotherapy: a systematic review and mixed-treatment comparison meta-analysis. Open Med.
280 Kahn BB, Flier JS. (2000). Obesity and insulin resistance. J Clin Invest.
281 Purnell TS, Joy S, Little E, et al. (2014). Patient preferences for noninsulin diabetes medications: a systematic review. Diabetes Care.
282 Vasilakou D, Karagiannis T, Athanasiadou E, et al. (2013). Sodium-glucose cotransporter 2 inhibitors for type 2 diabetes: a systematic review and meta-analysis. Ann Intern Med.
283 Richter B, Bandeira-Echtler E, Bergerhoff K, Lerch C. (2008). Dipeptidyl peptidase-4 (DPP-4) inhibitors for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews.
284 (1991). Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). SHEP Cooperative Research Group. JAMA.
285 (1998). Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. UK Prospective Diabetes Study Group. BMJ.
286 Wang JG, Staessen JA, Gong L, Liu L. (2000). Chinese trial on isolated systolic hypertension in the elderly. Systolic Hypertension in China (Syst-China) Collaborative Group. Arch Intern Med.
287 Sacks FM, Svetkey LP, Vollmer WM, et al. (2001). Effects on blood pressure of reduced dietary sodium and the Dietary Approaches to Stop Hypertension (DASH) diet. DASH-Sodium Collaborative Research Group. The New England journal of medicine.
288 Wu J, Kraja AT, Oberman A, et al. (2005). A summary of the effects of antihypertensive medications on measured blood pressure. Am J Hypertens.
289 Nauman J, Janszky I, Vatten LJ, Wisloff U. (2011). Temporal changes in resting heart rate and deaths from ischemic heart disease. JAMA.
290 Phung OJ, Schwartzman E, Allen RW, et al. (2013). Sulphonylureas and risk of cardiovascular disease: systematic review and meta-analysis. Diabet Med.
291 Monami M, Genovese S, Mannucci E. (2013). Cardiovascular safety of sulfonylureas: A meta-analysis of randomized clinical trials. Diabetes, obesity & metabolism.
292 Nissen SE, Wolski K. (2007). Effect of rosiglitazone on the risk of myocardial infarction and death from cardiovascular causes. The New England journal of medicine.
293 U.S. Food and Drug Administration. (2013). FDA Drug Safety Communication: Updated Risk Evaluation and Mitigation Strategy (REMS) to Restrict Acces to Rosiglitazone-containing Medicines including Avandia, Avandamet, and Avandaryl.
294 U.S. Food and Drug Administration. (2010). FDA significantly restricts access to the diabetes drug Avandia.
295 U.S. Food and Drug Administration. (2013). FDA requires removal of some prescribing and dispensing restrictions for rosiglitazone-containing diabetes medicines.
296 Goossen K, Graber S. (2012). Longer term safety of dipeptidyl peptidase-4 inhibitors in patients with type 2 diabetes mellitus: systematic review and meta-analysis. Diabetes Obes Metab.
297 Wu D, Li L, Liu C. (2014). Efficacy and safety of dipeptidyl peptidase-4 inhibitors and metformin as initial combination therapy and as monotherapy in patients with type 2 diabetes mellitus: a meta-analysis. Diabetes Obes Metab.
298 Karagiannis T, Paschos P, Paletas K, et al. (2012). Dipeptidyl peptidase-4 inhibitors for treatment of type 2 diabetes mellitus in the clinical setting: Systematic review and meta-analysis. BMJ (Online).
299 Monami M, Ahren B, Dicembrini I, Mannucci E. (2013). Dipeptidyl peptidase-4 inhibitors and cardiovascular risk: Ameta-analysis of randomized clinical trials. Diabetes, obesity & metabolism.
300 Johansen OE, Neubacher D, von Eynatten M, et al. (2012). Cardiovascular safety with linagliptin in patients with type 2 diabetes mellitus: a pre-specified, prospective, and adjudicated meta-analysis of a phase 3 programme. Cardiovasc Diabetol.
301 Iqbal N, Parker A, Frederich R, et al. (2014). Assessment of the cardiovascular safety of saxagliptin in patients with type 2 diabetes mellitus: pooled analysis of 20 clinical trials. Cardiovasc Diabetol.
302 Scirica BM, Bhatt DL, Braunwald E, et al. (2013). Saxagliptin and cardiovascular outcomes in patients with type 2 diabetes mellitus. The New England journal of medicine.
303 Green JB, Bethel MA, Armstrong PW, et al. (2015). Effect of Sitagliptin on Cardiovascular Outcomes in Type 2 Diabetes. The New England journal of medicine.
304 White WB, Cannon CP, Heller SR, et al. (2013). Alogliptin after acute coronary syndrome in patients with type 2 diabetes. The New England journal of medicine.
305 Monami M, Dicembrini I, Nardini C, et al. (2014). Effects of glucagon-like peptide-1 receptor agonists on cardiovascular risk: A meta-analysis of randomized clinical trials. Diabetes, obesity & metabolism.
306 Bonds DE, Miller ME, Bergenstal RM, et al. (2010). The association between symptomatic, severe hypoglycaemia and mortality in type 2 diabetes: retrospective epidemiological analysis of the ACCORD study. BMJ.
307 Holman RR, Farmer AJ, Davies MJ, et al. (2009). Three-year efficacy of complex insulin regimens in type 2 diabetes. The New England journal of medicine.
308 Budnitz DS, Shehab N, Kegler SR, Richards CL. (2007). Medication use leading to emergency department visits for adverse drug events in older adults. Ann Intern Med.
309 Franciosi M, Lucisano G, Lapice E, et al. (2013). Metformin therapy and risk of cancer in patients with type 2 diabetes: systematic review. PLoS One.
310 Zhang ZJ, Bi Y, Li S, et al. (2014). Reduced risk of lung cancer with metformin therapy in diabetic patients: a systematic review and meta-analysis. Am J Epidemiol.
311 Ferwana M, Firwana B, Hasan R, et al. (2013). Pioglitazone and risk of bladder cancer: a meta-analysis of controlled studies. Diabet Med.
312 Dormandy JA, Charbonnel B, Eckland DJ, et al. (2005). Secondary prevention of macrovascular events in patients with type 2 diabetes in the PROactive Study (PROspective pioglitAzone Clinical Trial In macroVascular Events): a randomised controlled trial. Lancet.
313 Erdmann E, Song E, Spanheimer R, et al. (2014). Observational follow-up of the PROactive study: a 6-year update. Diabetes Obes Metab.
314 U.S. Food and Drug Administration. (2013). Incretin Mimetic Drugs for Type 2 Diabetes: Early Communication - Reports of Possible Increased Risk of Pancreatitis and Pre-cancerous Findings of the Pancreas.
315 U.S. Food and Drug Administration. (2011). Highlights of Prescribing Information: Victoza (liraglutide [rDNA origin] injection, solution for subcutaneous use.
316 U.S. Food and Drug Administration. (2014). Highlights of Prescribing Information: Tanzeum (albiglutide) for injection, for subcutaneous use.
317 U.S. Food and Drug Administration. (2015). Highlights of Prescribing Information: Bydureon (exenatide extended-release) for injectable suspension.
318 U.S. Food and Drug Administration. (2015). Trulicity (dulaglutide) Injection, for Subcutaneous Use.
319 U.S. Food and Drug Administration. (2011). Victoza (liraglutide [rDNA origin]) Injection: REMS - Risk of Thyroid C-cell Tumors, Acute Pancreatitis.
320 Lago RM, Singh PP, Nesto RW. (2007). Congestive heart failure and cardiovascular death in patients with prediabetes and type 2 diabetes given thiazolidinediones: a meta-analysis of randomised clinical trials. Lancet.
321 Singh S, Loke YK, Furberg CD. (2007). Long-term risk of cardiovascular events with rosiglitazone: a meta-analysis. JAMA.
322 GlaxoSmithKline. (2014). Highlights of Prescribing Information: Avandia (rosiglitazone maleate) tablets.
323 Takeda Pharmaceuticals America. (2013). Highlights of Prescribing Information: Actos (pioglitazone) tables for oral use.
324 Zannad F, Cannon CP, Cushman WC, et al. (2015). Heart failure and mortality outcomes in patients with type 2 diabetes taking alogliptin versus placebo in EXAMINE: a multicentre, randomised, double-blind trial. Lancet.
325 U.S. Food and Drug Administration. FDA Panel Wants New DPP-4 Inhibitor Labels - Cardiovascular data warrant new risk information for saxagliptin and alogliptin, advisers say.
326 Clinicaltrials.gov. (2010). CAROLINA: Cardiovascular Outcome Study of Linagliptin Versus Glimepiride in Patients With Type 2 Diabetes.
327 Clinicaltrials.gov. (2013). Cardiovascular and Renal Microvascular Outcome Study With Linagliptin in Patients With Type 2 Diabetes Mellitus (CARMELINA).
328 (2015). NESINA (alogliptin) tablets.
329 (2013). ACTOS (pioglitazone) tablets for oral use.
330 Brown JB, Pedula K, Barzilay J, et al. (1998). Lactic acidosis rates in type 2 diabetes. Diabetes Care.
331 Misbin RI, Green L, Stadel BV, et al. (1998). Lactic acidosis in patients with diabetes treated with metformin. The New England journal of medicine.
332 Salpeter SR, Greyber E, Pasternak GA, Salpeter EE. (2010). Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev.
333 Inzucchi SE, Lipska KJ, Mayo H, et al. (2014). Metformin in patients with type 2 diabetes and kidney disease: a systematic review. JAMA.
334 Sethi BK, Viswanathan V, Kumar A, et al. (2010). Liraglutide in Clinical Practice: Insights from LEAD Programme. Supplement to JAPI.
335 Franks AS, Lee PH, George CM. (2012). Pancreatitis: a potential complication of liraglutide?. Ann Pharmacother.
336 Li L, Shen J, Bala MM, et al. (2014). Incretin treatment and risk of pancreatitis in patients with type 2 diabetes mellitus: systematic review and meta-analysis of randomised and non-randomised studies. BMJ.
337 Wang T, Wang F, Gou Z, et al. (2015). Using real-world data to evaluate the association of incretin-based therapies with risk of acute pancreatitis: a meta-analysis of 1,324,515 patients from observational studies. Diabetes Obes Metab.
338 Karagiannis T, Boura P, Tsapas A. (2014). Safety of dipeptidyl peptidase 4 inhibitors: A perspective review. Therapeutic Advances in Drug Safety.
339 U.S. Food and Drug Administration. (2014). Highlights of Prescribing Information: Byetta (exenatide) Injection.
340 U.S. Food and Drug Administration. (2013). Highlights of Prescribing Information: Victoza (liraglutide).
341 U.S. Food and Drug Administration. (2013). Summary Review: 125469Orig1s000.
342 U.S. Food and Drug Administration. (2013). Janumet (sitagliptin/metformin HCl) tablets.
343 Idris I, Warren G, Donnelly R. (2012). Association between thiazolidinedione treatment and risk of macular edema among patients with type 2 diabetes. Arch Intern Med.
344 Silva PS, Cavallerano JD, Sun JK, et al. (2010). Effect of systemic medications on onset and progression of diabetic retinopathy. Nature Reviews Endocrinology.
345 Singh S, Segal JB. (2012). Thiazolidinediones and macular edema. Archives of Internal Medicine.
346 Kawalec P, Mikrut A, Lopuch S. (2014). The safety of dipeptidyl peptidase-4 (DPP-4) inhibitors or sodium-glucose cotransporter 2 (SGLT-2) inhibitors added to metformin background therapy in patients with type 2 diabetes mellitus: a systematic review and meta-analysis. Diabetes Metab Res Rev.
347 U.S. Food and Drug Administration. (2015). FDA Drug Safety Communication: FDA revised label of diabetes drug canagliflozin (Invokana, Invokamet) to include updates on bone fracture risk and new information on decreased bone mineral density.
348 U.S. Food and Drug Administration. (2015). Highlights of Prescribing Information. Invokana (canagliflozin) tablets, for oral use.
349 Erondu N, Desai M, Ways K, Meininger G. (2015). Diabetic Ketoacidosis and Related Events in the Canagliflozin Type 2 Diabetes Clinical Program. Diabetes Care.
350 United States Renal Data System. (2012). 2012 Atlas of CKD & ESRD.
351 Centers for Disease Control and Prevention. (2015). Diabetic Retinopathy.
352 Centers for Disease Control and Prevention. (2014). New Diabetes Atlas.
353 The Henry J. Kaiser Family Foundation. (2015). Number of Diabetes Deaths per 100,000 Population by Race/Ethnicity.
354 Selvin E, Parrinello CM, Sacks DB, Coresh J. (2014). Trends in prevalence and control of diabetes in the United States, 1988-1994 and 1999-2010. Ann Intern Med.
355 Wong HK, Ong KL, Cheung CL, Cheung BM. (2014). Utilization of glucose, blood pressure, and lipid lowering medications among people with type II diabetes in the United States, 1999-2010. Ann Epidemiol.
356 Qaseem A, Humphrey LL, Sweet DE, et al. (2012). Oral pharmacologic treatment of type 2 diabetes mellitus: a clinical practice guideline from the American College of Physicians. Ann Intern Med.
357 Bristol-Myers Squibb. GLUCOPHAGE® (metformin hydrochloride) Tablets. GLUCOPHAGE® XR (metformin hydrochloride) Extended-Release Tablets.
358 Bailey RA, Wang Y, Zhu V, Rupnow MF. (2014). Chronic kidney disease in US adults with type 2 diabetes: an updated national estimate of prevalence based on Kidney Disease: Improving Global Outcomes (KDIGO) staging. BMC Res Notes.
359 Turner R, Murchison L, Wright AD, et al. (1998). United Kingdom prospective diabetes study 24: A 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. Ann Intern Med.
360 U.K. prospective diabetes study. (1985). II. Reduction in HbA1c with basal insulin supplement, sulfonylurea, or biguanide therapy in maturity-onset diabetes. A multicenter study. Diabetes.
361 United Kingdom Prospective Diabetes Study (UKPDS). (1995). 13: Relative efficacy of randomly allocated diet, sulphonylurea, insulin, or metformin in patients with newly diagnosed non-insulin dependent diabetes followed for three years. BMJ.
362 Patel A, MacMahon S, Chalmers J, et al. (2008). Intensive blood glucose control and vascular outcomes in patients with type 2 diabetes. The New England journal of medicine.
363 Nissen SE, Nicholls SJ, Wolski K, et al. (2008). Comparison of pioglitazone vs glimepiride on progression of coronary atherosclerosis in patients with type 2 diabetes: the PERISCOPE randomized controlled trial. JAMA.
364 Buse JB, Henry RR, Han J, et al. (2004). Effects of exenatide (exendin-4) on glycemic control over 30 weeks in sulfonylurea-treated patients with type 2 diabetes. Diabetes Care.
365 Blonde L, Klein EJ, Han J, et al. (2006). Interim analysis of the effects of exenatide treatment on A1C, weight and cardiovascular risk factors over 82 weeks in 314 overweight patients with type 2 diabetes. Diabetes Obes Metab.
366 Zinman B, Hoogwerf BJ, Duran Garcia S, et al. (2007). The effect of adding exenatide to a thiazolidinedione in suboptimally controlled type 2 diabetes: a randomized trial. Ann Intern Med.
367 Buse JB, Rosenstock J, Sesti G, et al. (2009). Liraglutide once a day versus exenatide twice a day for type 2 diabetes: a 26-week randomised, parallel-group, multinational, open-label trial (LEAD-6). Lancet.
368 Marre M, Shaw J, Brandle M, et al. (2009). Liraglutide, a once-daily human GLP-1 analogue, added to a sulphonylurea over 26 weeks produces greater improvements in glycaemic and weight control compared with adding rosiglitazone or placebo in subjects with Type 2 diabetes (LEAD-1 SU). Diabet Med.
369 Zinman B, Gerich J, Buse JB, et al. (2009). Efficacy and safety of the human glucagon-like peptide-1 analog liraglutide in combination with metformin and thiazolidinedione in patients with type 2 diabetes (LEAD-4 Met+TZD). Diabetes Care.
370 Li T, Hutfless S, Scharfstein DO, et al. (2014). Standards should be applied in the prevention and handling of missing data for patient-centered outcomes research: a systematic review and expert consensus. J Clin Epidemiol.
371 Patorno E, Patrick AR, Garry EM, et al. (2014). Observational studies of the association between glucose-lowering medications and cardiovascular outcomes: addressing methodological limitations. Diabetologia.