# Methods

## Topic Refinement and Review Protocol

This review updates the 2011 review on oral diabetes medications for adults with type 2 diabetes.16 We recruited a Technical Expert Panel (TEP) to review a draft of the protocol and a summary of the revisions from the 2011 review (see the Scope and Key Questions section from the Introduction). The TEP included endocrinologists, general internists, biostatisticians, and representatives from government agencies. The TEP reviewed our protocol and provided feedback on the proposed methods for addressing the Key Questions. With the feedback from the TEP and the Agency for Healthcare Research and Quality (AHRQ) representatives, we finalized the protocol and posted it on AHRQ Effective Health Care Program's Web site (www.effectivehealthcare.ahrq.gov).

## Literature Search Strategy

### Search Strategy

The 2011 review searched the following databases for the dates listed: MEDLINE^®^ (1966 to April 2010), Embase^®^ (1974 to April 2010), and the Cochrane Central Register of Controlled Trials (CENTRAL). Per AHRQ's guidance, our new search dates overlapped the prior search by more than 1 year.31 We ran the search developed for the 2011 review with the date restrictions of April 2009 through April 2015 (see Appendix A).

An additional expanded search included medical subject headings (MeSH) and text words for all of the new medications included in this updated report. The expanded search did not have any date restrictions.

We handsearched the reference lists of all newly included articles and relevant systematic reviews. Additionally, we searched ClinicalTrials.gov to identify relevant registered trials. We also reviewed the Web site of the Food and Drug Administration (FDA) for any unpublished additional studies relevant to the topic as part of our grey literature search. We also provided an opportunity for manufacturers of interventions to submit unpublished data.

### Study Selection

All of the review authors participated in the study selection. Two independent reviewers conducted title scans. For a title to be eliminated at this level, both reviewers needed to indicate that the study was ineligible. If the reviewers disagreed, the article was advanced to the next level, which was abstract review.

The abstract review phase was designed to identify studies reporting the effectiveness or safety of the medications and medication combinations of interest. Abstracts were reviewed independently by two investigators and were excluded if both investigators agreed that the article met one or more of the exclusion criteria (see the inclusion and exclusion criteria listed in Table 3). Differences between investigators regarding the inclusion or exclusion of abstracts were tracked and resolved through consensus adjudication.

Table 3 Inclusion and exclusion criteria

PICOTS | Inclusion Criteria | Exclusion Criteria
Population | - We included studies of adult humans with type 2 diabetes, non-insulin dependent diabetes mellitus, or adult-onset diabetes. | - We excluded studies of patients with type 1 diabetes, impaired glucose tolerance, metabolic syndrome, maturity onset diabetes of youth, and gestational diabetes.; - We excluded studies if they included only pregnant women or subjects 17 years of age or younger.; - We excluded studies where everyone was required to have at least one of the following comorbid conditions: ESLD, ESRD, cancer, new onset diabetes after organ transplant, or a recent cardiovascular event within the 3 months prior to study start.
Interventions | - We included studies that evaluated a diabetes medication of interest or drug combination of interest (see Table 2). | - We excluded studies that did not specify the adjunctive medications, such as those stating use of “any oral hypoglycemic,” or if the study listed several possible medications without stratification of the results by treatment.
Comparisons | - We included studies that evaluated a comparison of interest (see Table 2). | - We excluded studies that did not have a comparison group or that used a placebo comparison or non-pharmacological comparison.; - We excluded intraclass head-to-head comparisons.
Outcomes * | - We included studies addressing the following intermediate outcomes for KQ1:; ▪ Hemoglobin A1c^; ▪ Weight^†^; ▪ Systolic blood pressure^‡^; ▪ Heart rate^‡^; - We included studies addressing the following microvascular, macrovascular, and mortality outcomes for KQ2:; ▪ All-cause mortality; ▪ Cardiovascular and cerebrovascular morbidity and mortality; ▪ Retinopathy; ▪ Nephropathy; ▪ Neuropathy; - We included studies addressing the following safety outcomes for KQ3:; ▪ Liver injury^; ▪ Impaired renal function^§^; ▪ Lactic acidosis^; ▪ Pancreatitis^; ▪ Hypoglycemia^; ▪ Gastrointestinal side effects^; ▪ Congestive heart failure^; ▪ Cancer; ▪ Macular edema or decreased vision^; ▪ Fractures^§^; ▪ Urinary tract infections^§^; ▪ Genital mycotic infections^§^; ▪ Volume depletion^§^; - KQ4 included studies considering any of the above outcomes.
Type of study | - For KQ1, we included only RCTs.; - For KQ2 and KQ3, we included RCTs, non-randomized experimental studies with a comparison group, and high-quality observational studies with a comparison group.; - We included randomized trials utilizing a crossover design with some exceptions.ǁ | - We excluded studies not written in English^¶^ and excluded articles with no original data.; - We excluded meeting abstracts.
Timing and setting | | - We excluded studies in which the observed intervention or exposure period was less than 3 months, 12 weeks, or 90 days.

ESLD = end-stage liver disease; ESRD = end-stage renal disease; KQ = Key Question; PICOTS = populations, interventions, comparisons, outcomes, timing, and settings; RCT = randomized controlled trial

* Of note, some outcomes could be classified as either safety or long-term clinical outcomes (e.g., myocardial infarction and cancer).

^ We did not evaluate this outcome for metformin vs. sulfonylurea comparisons as the evidence was high from the prior report.

† We did not evaluate this outcome for metformin vs. thiazolidinedione or metformin vs. sulfonylurea comparisons as the evidence was high from the prior report.

‡ We evaluated this outcome only for comparisons that included a GLP-1 receptor agonist or a SGLT-2 inhibitor.

§ We evaluated this outcome only for comparisons that included a SGLT-2 inhibitor.

ǁ For crossover randomized trials, we abstracted data on all outcomes at the end of the first period prior to the crossover. If data were not presented at the end of the first period, then we excluded the article for the following outcomes where we would be unable to draw conclusions about causality: long-term outcomes (KQ2), fractures, cancer, intermediate outcomes in studies where there was a washout period of less than 3 months; and safety outcomes in studies where the washout period was less than a month except for hypoglycemia, gastrointestinal side effects, and liver injury.

¶ We decided to include non-English language articles through the full text article review phase of the updated search and assess the volume and content of these articles along with workload to determine if abstracting data from these articles would add value to the review.

Articles promoted on the basis of the abstract review underwent another independent parallel review to determine if they should be included in the final qualitative and quantitative systematic review and meta-analysis. The differences regarding article inclusion were tracked and resolved through consensus adjudication.

## Data Extraction

We used a systematic approach to extract all data to minimize the risk of bias in this process. We used standardized forms from the previous reviews as templates for data extraction and pilot tested them for the new medications and outcomes (Appendix B). By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

We double-reviewed all data abstracted from the studies. The second reviewer confirmed the first reviewer's abstracted data for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. A third reviewer audited a random sample of articles to ensure consistency in the data abstraction of the articles. Reviewers were not masked to the authors of the articles, their respective institutions, nor the journals in which their articles were published.

For all articles, the reviewers extracted information on the general study characteristics (e.g., study design, study period, and followup); study participants (e.g., age, sex, race, weight/body mass index [BMI], hemoglobin A1c levels, and duration of diabetes); interventions (e.g., initial, maximum, and mean doses, frequency of use, duration of use, and permissibility of treatment intensification with additional therapies), comparisons; the method of ascertainment of safety outcomes; and the outcome results, including measures of variability. We also collected data on outcomes for the subgroups of interest: age, sex, race/ethnicity, and BMI.

For continuous outcomes, we extracted the mean difference between groups and a measure of dispersion. If the between-group difference was not reported, we calculated the point estimate of the difference using the mean difference from baseline for each group. If the mean difference from baseline was not reported, we calculated this from the baseline and final values for each group.32 If there were no measures of dispersion for the mean difference from baseline for each group, we calculated the variance using the standard deviation of the baseline and final values, assuming a correlation between baseline and final values of 0.5.

We entered all information from the article review process into a DistillerSR database (Evidence Partners Inc., Ottawa, Canada). Reviewers entered comments into the system whenever applicable. The DistillerSR database was used to maintain the data and to create detailed evidence tables and summary tables. Data will later be uploaded into the Systematic Review Data Repository.

## Risk of Bias Assessment of Individual Studies

Two independent reviewers assessed study quality. We assessed the risk of bias in individual randomized controlled trials (RCTs) using the Jadad criteria consistent with the prior report.33 Although newer quality assessment tools exist, we felt that continuing to use the Jadad criteria would be adequate and consistent with our previous methods. We used the Downs and Black tool for assessment of risk of bias for non-randomized trials and observational studies.34 Given that observational studies with a high risk of bias add little value to a systematic review of effectiveness,35 we included only medium- and high-quality observational studies as determined by assessment of each study's risk of bias. For inclusion, we required that observational studies account for the following potential confounders: age, sex, either race or socioeconomic status, and co-morbid conditions (quantified with a co-morbidity scale or index, or by inclusion of other medical conditions or medications used by the patient, or with valid methods to adjust for confounding by indication or restricted to one race or age group making adjustment unnecessary). If the study met the confounding criteria, the observational study was considered eligible for inclusion in the review. We also applied the Downs and Black tool and other inclusion criteria for nonrandomized trials and observational studies to the non-randomized trials and observational studies that had been included in the prior report.16

## Data Synthesis

For each Key Question, we created a set of detailed evidence tables containing all information extracted from eligible studies, including those from the prior evidence reports. We included both the results of individual studies included in the prior report and the results of newly-identified studies. We conducted meta-analyses when there were sufficient data (at least three trials) and studies were sufficiently homogenous with respect to key variables (population characteristics, study duration, and drug dose). For trials having more than one dosing arm, we chose the arm for inclusion that had dosing most consistent with the other trials considered for inclusion in the meta-analysis. When more than one followup interval was reported, we used the data from the followup most similar to the other trials. While there is no definitive cut-point for long-term versus short-term, we considered trials lasting 2 years or longer to be “long-term” since a multifactorial intervention in adults with type 2 diabetes has shown changes in morbidity starting as early as 2 years.36

We tested the heterogeneity among the trials considered for quantitative pooling using a standard chi-squared test using a significance level of alpha less than or equal to 0.10. We also examined heterogeneity among studies with an I-squared statistic, which describes the variability in effect estimates that is due to heterogeneity rather than random chance. We considered a value greater than 50 percent to indicate substantial heterogeneity.37 We pooled the mean difference between groups using a random-effects model with the DerSimonian and Laird formula in settings of low heterogeneity (I-squared <50%).38 We pooled studies using the profile likelihood estimate when we detected high statistical heterogeneity (I-squared >50%).39 When data were insufficient or inappropriate to combine in a meta-analysis, we summarized the outcomes by reporting the ranges of values for mean differences from baseline or mean differences between groups, when available.

Since we anticipated that most drugs would have similar physiologic effects within a class, we combined studies of unique medications within classes when reporting outcomes except where known differences exist (e.g., the effects of pioglitazone and rosiglitazone on cardiovascular outcomes). If we saw substantial heterogeneity (I-squared >50%) in pooled estimates for any outcome, we stratified studies by medication within a class and repeated the pooled analyses and recalculated measures of heterogeneity. Additionally, when there were at least 10 studies for a given comparison and outcome and evidence of statistical heterogeneity, we attempted to determine other reasons for heterogeneity by evaluating study-level characteristics, such as baseline values of the outcome, study duration, quality measures, or dosing differences between study arms using metaregression techniques. We also conducted sensitivity analyses by omitting one study at a time to assess the influence of any single study on the pooled estimates.

For the outcome of hypoglycemia, we conducted separate analyses for: (a) severe hypoglycemia and (b) mild or moderate or total hypoglycemia. The categories were based on the definitions of hypoglycemia provided in the studies. For hypoglycemia and all other dichotomous outcomes, we calculated pooled odds ratios using a random-effects model with the DerSimonian and Laird formula in settings of low heterogeneity38 or the profile likelihood estimate in settings of high heterogeneity.39

### Reporting Bias Assessment

We assessed reporting biases in the included RCTs as follows:40

1. Publication bias was evaluated by:
  a. Using the Begg and Mazumdar41 and the Egger42 test to quantitatively assess for publication bias when there were at least 10 studies for a given comparison and outcome pair
  b. Comparing ClinicalTrials.gov entries and actual publications for evidence of absence of published literature
  c. Comparing FDA medical and statistical reviews and actual publications for evidence of absence of published literature (results are detailed in Appendix E).
2. Selective Outcomes Reporting bias was evaluated by comparing differences in reporting on the outcomes of hemoglobin A1c (HbA1c), hypoglycemia, and all-cause mortality in the actual publications to the FDA medical and statistical reviews.
3. Selective Analysis Reporting bias was evaluated by assessing the precision of outcome data reporting by determining the number of studies which reported on an outcome of interest (e.g., HbA1c) but did not report a measure of dispersion completely or at all. We assessed this for the outcomes of HbA1c, hypoglycemia, and all-cause mortality. For dichotomous outcomes (hypoglycemia and all-cause mortality), we evaluated the number of studies reporting the n of events uniformly across all arms. We reviewed this for the studies included for the update only.

## Strength of the Body of Evidence

At the completion of our review, two reviewers sequentially graded the available evidence addressing the Key Questions by adapting an evidence grading scheme recommended by the Guide for Conducting Comparative Effectiveness Reviews.43 We applied evidence grades to the bodies of evidence about each intervention comparison for each outcome that were addressed by at least one RCT or three observational studies. We separately assessed the strength of evidence for shorter and longer studies (2 years or greater); however, we only assessed strength of evidence for longer studies where we could draw a conclusion. We assessed the study limitations, consistency, directness, precision, and reporting bias.

We assessed the study limitations of individual studies using the tools described in the Risk of Bias of Individual Studies section. We started with the assumption that randomized controlled trials would have “low” study limitations and observational studies would have “medium” study limitations. We downgraded the study limitations score based on the items in the quality assessment tools.

We rated the body of evidence as “consistent” if most of the studies (about 75%) showed the same direction of effect. We rated the consistency of comparison-outcome dyads for which there was only a single study as “unknown.” All other bodies of evidence were rated as “inconsistent.”

We rated the bodies of evidence for all outcomes as “direct,” except for heart rate and liver injury. We rated the bodies of evidence for heart rate as “indirect,” because the association between heart rate and clinically important outcomes such as mortality is less strong in adults with diabetes.44 We rated the bodies of evidence for the outcome of liver injury as “indirect,” since most of the studies used liver injury enzyme elevation as the indicator of injury.

If we conducted a meta-analysis for a body of evidence, we relied on the results of the meta-analysis to rate precision and used the designated minimally important differences as a point of reference for precision. For continuous outcomes, we rated the body of evidence as “imprecise” if one-half of the width of the confidence interval for the meta-analysis was wider than the minimally important difference. We defined the minimally important difference to be 0.3% for HbA1c, 1 kg for weight, and 3 mmHg for systolic blood pressure. While there are no strict definitions of what should be considered clinically relevant differences, we used minimally important differences that clinical experts suggested are clinically relevant and that are supported, in part, in the literature.45 If there was no meta-analysis, we rated precision by evaluating the narrowness of the confidence intervals or the magnitude of the P-value. For dichotomous outcomes, we evaluated precision using the optimal information size for that outcome. If the total sample size across both arms of the studies was greater than the optimal information size, then we rated the body of evidence as “precise.” Otherwise, it was rated as “imprecise.” We estimated rough optimal information sizes using the Mantel Hanszel model for relative odds and incorporating the approximate baseline rate of the outcome and the desired minimum detectable relative odds (Table 4).46

Table 4 Optimal information size for one arm and classification of dichotomous outcomes for optimal information size

| “Low” Detectable OR, 1.05 | “Medium” Detectable OR, 1.5 | “High” Detectable OR, 2.0
“Low” baseline risk, 0.01 | 654,548 (All-cause mortality, cardiovascular mortality, cardiovascular morbidity, cancer, diabetic nephropathy) | 8,364 (Liver injury, pancreatitis, severe allergic reaction, renal impairment, congestive heart failure, microalbuminuria, volume depletion) | 2,597
“Medium” baseline risk, 0.15 | 51,168 (Severe hypoglycemia) | 690 (Urinary tract infections, genital infections) | 225
“High” baseline risk, 0.3 | 31,296 | 446 (Hypoglycemia) | 153 (Gastrointestinal events)

OR = odds ratio

We rated reporting bias by evaluating publication bias, selective outcomes reporting bias, and selective analysis reporting bias (described in the Reporting Bias Assessment section). If any of these domains was rated as “suspected,” then we rated the body of evidence as having “suspected” reporting bias. Otherwise, we rated reporting bias as “undetected.”

We classified evidence pertaining to the Key Questions into four categories: (1) “high” grade (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of the effect); (2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect but further research could change our confidence in the estimate of the effect and may change the estimate); (3) “low” grade (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate); and (4) “insufficient” grade (indicating evidence is unavailable or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion). We provided a conclusion regarding whether a given drug was favored over another (or if neither was favored) when the evidence permitted this. For all-cause mortality, cardiovascular mortality, cardiovascular morbidity, and safety outcomes, if we concluded that neither arm was favored (i.e., benefit or harm excluded), we did not rate the evidence as “moderate” in strength if the evidence was underpowered (rated as “imprecise”).

We graded the evidence separately for the RCTs and the observational studies.43 The final evidence grade and conclusion was typically based on the RCT grade and could be strengthened by evidence from the observational studies. We noted differences between RCT and observational evidence in the text, when present.

## Applicability

We discussed the applicability of studies in terms of the degree to which the study population (e.g., age, sex, race/ethnicity, and co-morbid conditions), interventions (e.g., dose, frequency, rescue therapy, and duration of exposure), outcomes (e.g., outcome definition and reporting), and settings are typical of the treatment of individuals with type 2 diabetes who are receiving treatment in a usual care setting (conceived as outpatient treatment by internists, family physicians, and endocrinologists).

## Peer Review and Public Commentary

Experts in endocrinologists, general internists, epidemiologists, biostatisticians, and representatives from government agencies were invited to provide external peer review of this systematic review; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a disposition of comments report that will be made available 3 months after the Agency posts the final systematic review on the EHC Web site.