# Introduction

## Background

Type 2 diabetes currently affects 9.3 percent of the US population, or 29.1 million people.1 The proportion of affected individuals in the US varies greatly by race and ethnicity: 16 percent of American Indian/ Alaska Natives, 13 percent of non-Hispanic black Americans and Hispanic Americans, 9 percent of Asian Americans, and 7 percent of non-Hispanic white Americans are afflicted with diabetes. The vast majority of these cases are type 2 diabetes.2 Within these racial categories, rates also vary substantially within sub-populations (e.g., South Asian-Americans and East Asian-Americans).2 Estimates of diabetes incidence that include laboratory-diagnosed diabetes, in addition to self-report, are higher than those reported by the US Centers for Disease Control and Prevention.3 Encouragingly, most reports in the US and Europe suggest that the incidence of disease has not been rising over the past decade.4 Similarly, the age at diagnosis has been relatively stable at 55 years in non-Hispanic whites, and 49 years in non-Hispanic blacks and Hispanics.5

Diabetes and its complications are a substantial public health burden, as they contribute significantly to mortality, morbidity, and health care costs.1, 6 Costs related to diabetes were approximately $245 billion in 2012.^1^ Complications of longstanding diabetes include the microvascular complications of retinopathy and blindness, neuropathy, nephropathy, and end-stage kidney disease. Diabetes is the most prevalent cause of new-onset blindness and new-onset end-stage renal disease in adults in the US. Diabetes also contributes importantly to macrovascular complications, including coronary artery disease, peripheral arterial disease, and carotid artery disease, and increases the risk of cardiovascular-related death nearly two-fold.7

Lifestyle modification and pharmacologic therapy are the cornerstones of the management of hyperglycemia for type 2 diabetes.8 Results from randomized controlled trials have established that the risk of microvascular complications, particularly retinopathy, can be reduced with glycemic control in patients with type 2 diabetes.9, 10 However, studies in the past decade have suggested that using diabetes medications to achieve intensive glycemic control [hemoglobin A1c (HbA1c) less than 7%] does not benefit cardiovascular morbidity and mortality11, 12 and may harm patients, including those with important co-morbid conditions.13 Recent work also suggests that the effects of intensive glucose lowering may vary across racial and ethnic groups.14 These mixed results on the benefits and safety of glycemic control through pharmacologic therapy suggest the need for further research, including investigation of the long-term impact of glucose lowering therapies.

Even if questions about intensity of control are resolved, clinicians and other stakeholders need to determine the optimal agent for glucose lowering. Given the ever-increasing literature about type 2 diabetes medications and the recent approval of many new medications, an updated systematic review evaluating the effects of these medications on intermediate and long-term effectiveness and safety outcomes will be valuable to clinicians, patients, investigators, funders, guideline developers, and payers. In this era of intensive, direct-to-consumer marketing of new drugs, clinicians need a trustworthy source of comprehensive information about the comparative effectiveness and safety of medications. This review seeks to provide information about treatment options to a diverse set of clinicians, including family practitioners, general internists, nurse practitioners, physician assistants, nurses, pharmacists, endocrinologists, cardiologists, nephrologists, and others. Guideline developers may also find this review to be informative for clinical practice guideline preparation. Patients and patient advocates will find the information valuable when making decisions about treatment options. Finally, investigators will be able to use the results of this review to identify gaps in the literature and formulate original research questions to fill these knowledge gaps.

## Rationale for Update of Review on Comparative Effectiveness of Diabetes Medications

The Effective Health Care (EHC) Program of the Agency for Healthcare Research and Quality (AHRQ) has published two systematic reviews comparing monotherapies and medication combinations for adults with type 2 diabetes.15, 16 In 2007, the AHRQ published its first systematic review, including 216 studies, on this topic.15 This review concluded that most diabetes medications approved by the U.S. Food and Drug Administration (FDA) had similar effects on reducing HbA1c, and most drugs, except for metformin and acarbose, caused at least modest increases in body weight. The sulfonylurea class was associated with an increased risk of hypoglycemia, metformin with gastrointestinal problems, and the thiazolidinediones with heart failure. Importantly, the literature was too sparse to support any conclusions about differential effects of the oral diabetes medications on all-cause mortality, cardiovascular mortality and morbidity, and microvascular complications. When asked by AHRQ to update that review in 2011, we identified an additional 140 randomized controlled trials and 26 observational studies.16 We found that most medications lowered HbA1c by 1 absolute percentage point, on average, but metformin was more effective for HbA1c-lowering than the dipeptidyl-peptidase 4 (DPP-4) inhibitors, a newer class of diabetes medications approved since the initial report. Mostly, the two-drug combinations had similar effects on HbA1c reduction. Compared with metformin, thiazolidinediones and sulfonylureas contributed to more weight gain. Sulfonylureas had a fourfold higher risk of mild/moderate hypoglycemia compared with metformin alone, and, in combination with metformin, had more than a five-fold increased risk of hypoglycemia when compared with metformin plus thiazolidinediones. The risk of congestive heart failure was higher with thiazolidinediones than with sulfonylureas, and the risk of bone fractures was higher with thiazolidinediones than with metformin. Thus, the evidence continued to support use of metformin as a first line agent, based on its effects on HbA1c and weight and side effect profile. The risk of adverse effects was the main determinant of the risk-benefit balance for the two-drug combinations.

Despite the addition of important evidence on the HbA1c-lowering and adverse effects of the FDA-approved diabetes medications in 2011, data on the then recently-approved medication classes (glucagon-like peptide-1 (GLP-1) agonists and DPP-4 inhibitors) were sparse, and data on long-term outcomes for both older and newer medications were still lacking.17, 18 Based on these prior systematic reviews, metformin has strong evidence to support its use as an initial pharmacologic treatment for most patients with type 2 diabetes;7 It's use as a first-line therapy has been widely promoted by clinical practice guidelines.19-21 Not all patients, however, can successfully use metformin due to contraindications to its use or intolerance of its side effects. The evidence base regarding alternative monotherapies for these patients continues to evolve.

Since January 2010, one new medication class [the sodium-glucose cotransporter 2 (SGLT-2) inhibitors, with three new medications] and several new DPP-4 inhibitors and GLP-1 receptor agonists have been approved by the FDA. Also since 2010, additional data on previously-approved medications have emerged that could change the balance of benefit and risk attributable to these drugs or could alter the strength of evidence about some of the drug comparisons previously reviewed.22-25 Including insulin, there are 10 medication classes with approval by the FDA for treatment of type 2 diabetes. We limited the add-on insulins to premixed or basal insulins in the 2011 report since these are often used as a second line agent after metformin. We have included most, although not all medication classes, in this updated systematic review (Table 1).

Table 1 Characteristics of medications included in this report

Class | Main Mechanism of Action | Drug | Trade Name | Dosing
Biguanides | Inhibit glucose production by the liver | Metformin | Glucophage®, Glucophage XR® | Oral: 500 to 2550 mg divided doses (qd to tid) Max dose: 2550 mg; 2000 mg for XR
Thiazolidinediones | Increase glucose uptake by skeletal muscle | Pioglitazone | Actos® | Oral: 15 to 30 mg qd Max dose: 45 mg qd
Thiazolidinediones | Increase glucose uptake by skeletal muscle | Rosiglitazone | Avandia® | Oral: 4 to 8 mg qd or 2 to 4 mg bid Max dose: 8 mg qd or 4 mg qd with insulin or sulfonylurea
Sulfonylureas | Increase insulin secretion by pancreatic beta cells | Glimepiride | Amaryl® | Oral: 1 to 8 mg qd Max dose: 8 mg qd
Sulfonylureas | Increase insulin secretion by pancreatic beta cells | Glipizide | Glucotrol®, Glucotrol XL® | Oral: 5 to 15 mg qd or 5 to 20 mg bid Max dose: 20 mg bid, 20 mg qd for XL
Sulfonylureas | Increase insulin secretion by pancreatic beta cells | Glyburide or glibenclamide | DiaBeta®, Glynase® PresTab®, Micronase® | Oral: 2.5 to 20 mg qd or bid Max dose: 20 mg qd
DPP-4 inhibitors | Increase incretin hormone activity which increases insulin release and decreases inappropriate glucagon production by the pancreatic islet cells^*^ | Alogliptin | Nesina® | Oral: 6.25 to 25 mg qd Recommended dose: 25 mg qd
DPP-4 inhibitors | Increase incretin hormone activity which increases insulin release and decreases inappropriate glucagon production by the pancreatic islet cells^*^ | Linagliptin | Tradjenta® | Oral: 5 mg qd Recommended dose: 5 mg qd
DPP-4 inhibitors | Increase incretin hormone activity which increases insulin release and decreases inappropriate glucagon production by the pancreatic islet cells^*^ | Saxagliptin | Onglyza® | Oral: 2.5 to 5 mg qd Recommended dose: 2.5 or 5 mg qd
DPP-4 inhibitors | Increase incretin hormone activity which increases insulin release and decreases inappropriate glucagon production by the pancreatic islet cells^*^ | Sitagliptin | Januvia® | Oral: 25 to 100 mg qd Recommended dose: 100 mg qd
SGLT-2 inhibitors | Increases urinary excretion of glucose | Canagliflozin | Invokana® | Oral: 100 to 300 mg Max dose: 300 mg
SGLT-2 inhibitors | Increases urinary excretion of glucose | Dapagliflozin | Farxiga® | Oral: 5 to 10 mg qd Max dose: 10 mg qd
SGLT-2 inhibitors | Increases urinary excretion of glucose | Empagliflozin | Jardiance® | Oral: 10 to 25 mg qd Max dose: 25 mg qd
GLP-1 receptor agonists | Increase glucose-dependent insulin release and decrease inappropriate glucagon production by the pancreatic islet cells^*^ | Albiglutide injection | Tanzeum® | SC injection: 30 mg qw Max dose: 50 mg qw
GLP-1 receptor agonists | Increase glucose-dependent insulin release and decrease inappropriate glucagon production by the pancreatic islet cells^*^ | Dulaglutide injection | Trulicity® | SC injection: 0.75 to 1.5 mg/0.5 mL Max dose: 1.5 mg/0.5 mL
GLP-1 receptor agonists | Increase glucose-dependent insulin release and decrease inappropriate glucagon production by the pancreatic islet cells^*^ | Exenatide injection | Byetta® | SC injection: 5 to 10 mcg SC bid
GLP-1 receptor agonists | Increase glucose-dependent insulin release and decrease inappropriate glucagon production by the pancreatic islet cells^*^ | Liraglutide injection | Victoza® | SC injection: 1.6 to 1.8 mg SC qd
Basal insulin | Increases long-acting insulin | NPH insulin | Humulin N®, Novolin N® | NA
Basal insulin | Increases long-acting insulin | Insulin detemir | Levemir® | NA
Basal insulin | Increases long-acting insulin | Insulin glargine | Lantus® | NA
Premixed insulin | Increases short and long-acting insulin | 50% NPH and 50% regular insulin | Humulin® 50/50 | NA
Premixed insulin | Increases short and long-acting insulin | 70% NPH and 30% regular insulin | Humulin® 70/30 Novolin® 70/30 | NA
Premixed insulin | Increases short and long-acting insulin | 50% lispro protamine suspension and 50% lispro | Humalog Mix® 50/50 | NA
Premixed insulin | Increases short and long-acting insulin | 75% lispro protamine suspension and 25% lispro | Humalog Mix® 75/25 | NA
Premixed insulin | Increases short and long-acting insulin | 70% aspart protamine suspension and 30% aspart | NovoLog Mix® 70/30 | NA

bid = twice daily; DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; mcg = microgram; mg = milligrams; mL = milliliter; NA = not applicable since there is no maximum dose for these insulins; NPH = neutral protamine Hagedorn; qd = once daily; qw = once weekly; SC = subcutaneous; SGLT-2 = sodium-glucose co-transporter-2; tid = three-times daily; XL = extended release; XR = extended release.

* Decreased glucagon production decreases glucose production by the liver.

## Analytic Framework

Our analytic framework describes the decisions that patients and their providers face when managing type 2 diabetes pharmacologically (Figure 1). It highlights the comparisons and outcomes of interest that correspond to each of the Key Questions in our review. When beginning medical treatment, patients usually start with one of five drug classes (Table 1), which have all been FDA-approved for monotherapy. These include biguanides, thiazolidinediones, sulfonylureas, DPP-4 inhibitors, SGLT-2 inhibitors, and GLP-1 receptor agonists. Clinical guidelines of the American Diabetes Association recommend monitoring HbA1c to determine the need for changing the medication dose or adding another agent to improve glycemic control.26 If the HbA1c is not adequately controlled, clinicians typically add an additional oral diabetes medication, or they may add insulin or a noninsulin injectable medication like a GLP-1 receptor agonist. Clinicians also monitor other intermediate outcomes, such as weight and short-term and long-term safety and adverse effects of the drugs, which vary by drug class. The ultimate goal is to improve long-term outcomes while maximizing quality of life.

Figure 1 Analytic framework

BMI = body mass index; DPP-4 = dipeptidyl peptidase-4; GLP1 = glucagon-like peptide-1; HbA1c = hemoglobin A1c; KQ=Key Question; NPH = neutral protamine Hagedorn; SGLT-2 inhibitor = sodium-glucose co-transporter 2

Analytic framework for monotherapies, combination therapy with metformin and outcomes.

## Scope

This review updates the 2011 review on oral diabetes medications for adults with type 2 diabetes.16 In this review, we have chosen to focus on head-to-head drug class comparisons for which there are evidence gaps (see Table 2). We have included a new FDA-approved class of oral diabetes medications, the SGLT-2 inhibitors, including empagliflozin, dapagliflozin, and canagliflozin. We have included new DPP-4 inhibitors approved since the last review, linagliptin and alogliptin, and GLP-1 receptor agonists approved since the last review, albiglutide and dulaglutide. After discussion with our technical expert panel, we excluded head-to-head intraclass drug comparisons and excluded placebo-controlled trials since these comparisons were considered lower priority given the large number of head-to-head studies. Since most guidelines recommend metformin as first-line therapy,19-21 we have chosen to focus Key Questions 1b, 2b, and 3b on metformin-based combination comparisons to assess second-line therapy options after metformin.

Table 2 Priority medication comparisons included for each Key Question

Intervention | Main Intervention Class (Generic Individual Drug Names) | Comparisons
Monotherapy as main intervention | Biguanides (metformin) | - Thiazolidinediones^*^; - Sulfonylureas^†^; - DPP-4 inhibitors; - SGLT-2 inhibitors; - GLP-1 receptor agonists^‡^; - Combination of metformin plus thiazolidinedione; - Combination of metformin plus sulfonylurea; - Combination of metformin plus DPP-4 inhibitor; - Combination of metformin plus SGLT-2 inhibitor; - Combination of metformin plus GLP-1 receptor agonist
Monotherapy as main intervention | Thiazolidinediones (rosiglitazone, or pioglitazone) | - Sulfonylureas; - DPP-4 inhibitors; - SGLT-2 inhibitors; - GLP-1 receptor agonists
Monotherapy as main intervention | Sulfonylureas (glimepiride, glyburide^¶^, glibenclamide^¶^, or glipizide) | - DPP-4 inhibitors; - SGLT-2 inhibitors; - GLP-1 receptor agonists
Monotherapy as main intervention | DPP-4 inhibitors (alogliptin, linagliptin, saxagliptin, or sitagliptin) | - SGLT-2 inhibitors; - GLP-1 receptor agonists
Monotherapy as main intervention | SGLT-2 inhibitors (canagliflozin, dapagliflozin, or empagliflozin) | - GLP-1 receptor agonists
Combination therapy as main intervention | Combination of metformin plus (thiazolidinedione or sulfonylurea or DPP-4 inhibitor or SGLT-2 inhibitor or GLP-1 receptor agonist or basal insulin) | - Combination of metformin plus (sulfonylurea or DPP-4 inhibitor or SGLT-2 inhibitor or GLP-1 receptor agonist or basal insulin^‡^ or premixed insulin^‡^)

DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; HbA1c = hemoglobin A1c; SGLT-2 = sodium-glucose co-transporter 2

* For studies comparing thiazolidinediones with metformin, we reviewed only HbA1c, long-term outcomes, and selected safety outcomes given the high strength of evidence from our prior Comparative Effectiveness Review for other outcomes (specifically fracture and weight).16

† For studies comparing sulfonylureas with metformin, we reviewed only the long-term outcomes and cancer given the high strength of evidence on the other outcomes from our prior Comparative Effectiveness Review.16

‡ The generic individual drug names for the GLP-1 receptor agonists are exenatide, liraglutide, dulaglutide, and albiglutide. The generic individual drug names for basal insulin are insulin glargine, insulin detemir, and neutral protamine Hagedorn (NPH) insulin. The generic individual drug names for premixed insulin are NPH/regular 50/50, NPH/regular 70/30, insulin lispro 50/50, insulin lispro 75/25, and insulin aspart 70/30.

¶ Glyburide and glibenclamide are the same drug.

Given the unique and emerging safety concerns of some of these medications, we have included additional safety outcomes in the review, including impaired renal function, urinary tract infections, genital infections, volume depletion, and bone fractures for studies that include a comparison with SGLT-2 inhibitors. We have also included systolic blood pressure and heart rate as intermediate outcomes for studies including either SGLT-2 inhibitors or GLP-1 receptor agonists.

We have chosen to exclude meglitinides as interventions of interest as they are uncommonly used in current clinical practice (<1% of hypoglycemic prescriptions).27, 28 We evaluated meglitinides in our two earlier systematic reviews and found that this class has similar effects on HbA1c and similar rates of hypoglycemia as sulfonylureas. The 2011 update included little new information on meglitinides, and we expected to find little additional evidence for this class of medication.

Similarly, we are no longer reporting on lipid levels as intermediate outcomes of interest. LDL targets are no longer universally the primary factor guiding the use of cholesterol-lowering therapy. Current guidelines suggest that 10-year global cardiovascular disease (CVD) risk should be used to determine statin usage and intensity, and this global risk score does not actually include low-density lipoprotein cholesterol.29 Furthermore, triglycerides and high-density lipoprotein are not usual targets of cholesterol therapy. Statin usage is recommended for all patients 40 years of age and older with diabetes in the US.30 Based on these new approaches to lipids, we did not feel that evidence of the impact of diabetes medications on lipid levels would be substantially informative to clinical care to warrant inclusion in this report.

## Key Questions

Key Question 1a: In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of the specified monotherapy FDA-approved diabetes medications (see Table 2) for the intermediate outcomes of hemoglobin A1c, weight, systolic blood pressure (for comparisons including SGLT-2 inhibitors or GLP-1 receptor agonists), and heart rate (for comparisons including SGLT-2 inhibitors or GLP-1 receptor agonists)?

Key Question 1b: In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of the specified metformin-based combinations of FDA-approved diabetes medications (see Table 2) for the intermediate outcomes of hemoglobin A1c, weight, systolic blood pressure (for comparisons including SGLT-2 inhibitors or GLP-1 receptor agonists), and heart rate (for comparisons including SGLT-2 inhibitors or GLP-1 receptor agonists)?

Key Question 2a: In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of the specified monotherapy FDA-approved diabetes medications (see Table 2) for the long-term clinical outcomes of all-cause mortality, cardiovascular and cerebrovascular morbidity and mortality, retinopathy, nephropathy, and neuropathy?

Key Question 2b: In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of the specified metformin-based combinations of FDA-approved diabetes medications (see Table 2) for the long-term clinical outcomes of all-cause mortality, cardiovascular and cerebrovascular morbidity and mortality, retinopathy, nephropathy, and neuropathy?

Key Question 3a: In adults age 18 or older with type 2 diabetes mellitus, what is the comparative safety of the specified monotherapy FDA-approved diabetes medications (see Table 2) regarding liver injury, lactic acidosis, pancreatitis, hypoglycemia, congestive heart failure, cancer, severe allergic reactions, macular edema or decreased vision, and gastrointestinal side effects; and for comparisons including SGLT-2 inhibitors, urinary tract infections, impaired renal function, genital mycotic infections, fracture, and volume depletion?

Key Question 3b: In adults age 18 or older with type 2 diabetes mellitus, what is the comparative safety of the specified metformin-based combinations of FDA-approved diabetes medications (see Table 2) regarding liver injury, lactic acidosis, pancreatitis, hypoglycemia, congestive heart failure, cancer, severe allergic reactions, macular edema or decreased vision, and gastrointestinal side effects; and for comparisons including SGLT-2 inhibitors, urinary tract infections, impaired renal function, genital mycotic infections, fracture, and volume depletion?

Key Question 4: Do the comparative safety and effectiveness of these treatments differ across subgroups defined by the age, sex, race/ethnicity, and body mass index (BMI) of adults with type 2 diabetes?