# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input into this report follows:

- John Anderson, M.D.
  The Frist Clinic
  Nashville, TN
- Vanita Aroda, M.D.^*^
  MedStar Health Research Institute
  Hyattsville, MD
- Michael Barry, M.D.^*^
  Massachusetts General Hospital
  Harvard Medical School
  Boston, MA
- Judith Fradkin, M.D.^*^
  National Institute of Diabetes and Digestive and Kidney Diseases
  Bethesda, MD
- Linda Humphrey, M.D., M.P.H.^*^
  Portland Veterans Affairs Medical Center
  Oregon Health & Science University
  Portland, OR
- Leonard Pogach, M.D., M.B.A.^*^
  Veterans Affairs Central Office
  Washington, D.C.
- Robert Ratner, M.D.
  American Diabetes Association
  Alexandria, VA
- Christopher Schmid, Ph.D.
  Brown University School of Public Health
  Providence, RI

* Provided input on Draft Report.