# Addendum and Errata

## Introduction

During report dissemination in a peer-reviewed journal, Annals of Internal Medicine requested an update of our search and evidence.

## Methods

### Search Strategy

We updated the MEDLINE search to identify randomized controlled trials indexed through December 31, 2015.

### Evidence Grading

We updated the evidence from the final Agency for Healthcare Research and Quality report with results from newly identified randomized trials if these results increased the strength of evidence from low or moderate to moderate or high.

## Results

From the updated MEDLINE search, we identified eight new studies (published in nine articles)1-9 which met our inclusion criteria, plus six additional publications that were either extensions or additional analyses of included studies.10-15 Of these, four studies contributed results which increased the strength of evidence to moderate or high strength; the results of these studies were incorporated in the publication (Appendix Figure 1).16 The updated strength of evidence is shown in Table 1. We report four new findings: (1) sulfonylureas had greater reductions in hemoglobin A1c than dipeptidyl peptidase-4 (DPP-4) inhibitors; (2) sulfonylureas had less beneficial effects on weight than DPP-4 inhibitors; (3) metformin plus glucagon-like peptide-1 receptor agonists had greater weight reductions than metformin plus premixed insulins; and (4) metformin plus thiazolidinediones had less diarrhea than metformin alone (Figures 1 and 4; Appendix Table 6 in the Annals of Internal Medicine manuscript16).

Table 1 Strength of evidence domains for the comparisons and outcomes that changed with the updated search

Comparison | Outcome | Number of Studies (Subjects) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence | Summary
SU vs. DPP-4 inhibitors | HbA1c | 4 (1659) | Medium | Consistent | Direct | Precise | Undetected | Moderate | SU favored; pooled mean between-group difference, -0.2% (95% CI, -0.3 to -0.1%)
SU vs. DPP-4 inhibitors | Weight | 4 (1659) | Low | Consistent | Direct | Precise | Undetected | Moderate | DPP-4 inhibitors favored; range in between-group differences of 0.7 to 1.8 kg
Metformin + GLP-1 receptor agonists vs. metformin + premixed insulin | Weight | 2 (426) | Medium | Consistent | Direct | Precise | Undetected | Moderate | Metformin + GLP-1 receptor agonists favored; range in between-group differences 1.9 to 5.1 kg
Metformin vs. metformin + TZD | GI side effects | 11 (4,271) 6 studies on diarrhea; 1-2 studies for other GI-related outcomes | Medium | Consistent | Direct | Imprecise | Undetected | Moderate for diarrhea; Low for other GI-related outcomes | Metformin + TZD favored for diarrhea; Neither favored for other GI-related outcomes

DPP-4 inhibitors = dipeptidyl-peptidase 4 inhibitors; GI = gastrointestinal; GLP-1 receptor agonists = glucagon-like peptide-1 agonists; GI = gastrointestinal; kg = kilograms; SU = sulfonylurea; TZD = thiazolidinedione

## Conclusions

These four new findings strengthen the overall conclusions from the main report.17

## References

1 Yang W, Han P, Min KW, et al. (2015). Efficacy and safety of dapagliflozin in Asian patients with type 2 diabetes after metformin failure: A randomized controlled trial. J Diabetes.
2 Lu Y, Rodriguez LA, Malgerud L, et al. (2015). New-onset type 2 diabetes, elevated HbA1c, anti-diabetic medications, and risk of pancreatic cancer. Br J Cancer.
3 Tanaka K, Saisho Y, Manesso E, et al. (2015). Effects of Liraglutide Monotherapy on Beta Cell Function and Pancreatic Enzymes Compared with Metformin in Japanese Overweight/Obese Patients with Type 2 Diabetes Mellitus: A Subpopulation Analysis of the KIND-LM Randomized Trial. Clin Drug Investig.
4 Ma Z, Chen R, Liu Y, et al. (2015). Effect of liraglutide vs. NPH in combination with metformin on blood glucose fluctuations assessed using continuous glucose monitoring in patients with newly diagnosed type 2 diabetes. Int J Clin Pharmacol Ther.
5 Hartley P, Shentu Y, Betz-Schiff P, et al. (2015). Efficacy and Tolerability of Sitagliptin Compared with Glimepiride in Elderly Patients with Type 2 Diabetes Mellitus and Inadequate Glycemic Control: A Randomized, Double-Blind, Non-Inferiority Trial. Drugs Aging.
6 Cai XL, Chen YL, Zhao JJ, et al. (2015). Efficacy and safety of avandamet or uptitrated metformin treatment in patients with type 2 diabetes inadequately controlled with metformin alone: a multicenter, randomized, controlled trial. Chin Med J (Engl).
7 Xiao CC, Ren A, Yang J, et al. (2015). Effects of pioglitazone and glipizide on platelet function in patients with type 2 diabetes. Eur Rev Med Pharmacol Sci.
8 Ross S, Thamer C, Cescutti J, et al. (2015). Efficacy and safety of empagliflozin twice daily versus once daily in patients with type 2 diabetes inadequately controlled on metformin: a 16-week, randomized, placebo-controlled trial. Diabetes Obes Metab.
9 Tanaka K, Saisho Y, Kawai T, et al. (2015). Efficacy and safety of liraglutide monotherapy compared with metformin in Japanese overweight/obese patients with type 2 diabetes. Endocr J.
10 Roden M, Merker L, Christiansen AV, et al. (2015). Safety, tolerability and effects on cardiometabolic risk factors of empagliflozin monotherapy in drug-naive patients with type 2 diabetes: a double-blind extension of a Phase III randomized controlled trial. Cardiovasc Diabetol.
11 Chirila C, Zheng Q, Davenport E, et al. (2015). Treatment satisfaction in type 2 diabetes patients taking empagliflozin compared with patients taking glimepiride. Qual Life Res.
12 Li D, Xu X, Zhang Y, et al. (2015). Liraglutide treatment causes upregulation of adiponectin and downregulation of resistin in Chinese type 2 diabetes. Diabetes Res Clin Pract.
13 Simo R, Guerci B, Schernthaner G, et al. (2015). Long-term changes in cardiovascular risk markers during administration of exenatide twice daily or glimepiride: results from the European exenatide study. Cardiovasc Diabetol.
14 Li R, Xu W, Luo S, et al. (2015). Effect of exenatide, insulin and pioglitazone on bone metabolism in patients with newly diagnosed type 2 diabetes. Acta Diabetol.
15 Weinstock RS, Guerci B, Umpierrez, et al. (2015). Safety and efficacy of once-weekly dulaglutide versus sitagliptin after 2 years in metformin-treated patients with type 2 diabetes (AWARD-5): a randomized, phase III study. Diabetes Obes Metab.
16 Maruthur NM, Tseng E, Hutfless S, et al. (2016). Diabetes Medications as Monotherapy or Metformin-Based Combination Therapy for Type 2 Diabetes: Systematic Review and Meta-Analysis. Ann Intern Med.
17 Bolen S, Tseng E, Hutfless S, et al. (2016). Diabetes Medications for Adults with Type 2 Diabetes: An Update.

## Errata

Upon closer review, we found that the primary outcome for Hong 2013 was indeed a composite cardiovascular outcome, which was not what we had stated and that the followup time was 5.0 years rather than 3.0 years. We also note that in the Executive Summary we stated that metformin and GLP-1 receptor agonists were similar for diarrhea, but this was of low and not moderate or high strength and therefore should have not appeared in that section.