# Acknowledgments

We would like to thank Jessica Gayleard for her help in reviewing articles, Emily Little for her assistance with the evidence tables, Jeanette Edelstein for copy editing, and Supriya Janakiraman. We would also like to thank the Technical Expert Panel, Peer Reviewers, Task Order Officers, and our Associate Editor.