# Discussion

This systematic review addresses the comparative effectiveness and safety of diabetes medications used most frequently in the United States as monotherapy and compares therapies in combination with metformin to each other. This review updates and adds to two previous comparative effectiveness reviews (CER) published in 2007^15^ and 2011,^16^ by focusing on the head-to-head comparisons of medications most relevant to clinicians and their patients (Table 2), particularly those for which evidence was previously lacking. We broadened the scope by including seven medications newly approved by Food and Drug Administration (FDA), including one new medication class, the sodium-glucose co-transporter-2 (SGLT-2) inhibitors. We identified 107 new studies, which included 87 trials and 20 observational studies, published since we completed our 2011 review. Our comprehensive review of the newer medication classes in comparison with other medications and comparisons of combination therapies is an important contribution to the literature, because it is the first to address this many comparisons for a wide range of outcomes in patients with type 2 diabetes mellitus.

## Key Findings in Context

### Intermediate Outcomes

One hundred sixty-two RCTs evaluated the intermediate outcomes of hemoglobin A1c (HbA1c), weight, systolic blood pressure, and heart rate. Studies mainly measured these intermediate outcomes at 1 year or less; only six studies were longer than 2 years. The few longer studies had results consistent with the results from the shorter-term studies. Rarely, results from a longer study conflicted with results from a short-term study, but the high losses to followup (generally >20%) made these uninterpretable. Therefore, short-term results are discussed below, unless otherwise specified in the figure or text.

#### Hemoglobin A1c

HbA1c is unequivocally linked to microvascular disease,10, 275, 276 making it a good proximal outcome to measure. Consistent with the prior 2011 report,16 most oral diabetes medications (thiazolidinediones, sulfonylureas, and metformin) had similar efficacy in reducing HbA1c when used as monotherapy (Figure 96). The one exception was that metformin yielded a greater reduction in HbA1c compared with DPP-4 inhibitors, consistent with the prior report.16 In the last report,16 metformin versus sulfonylurea was graded as having a high strength of evidence showing no significant between-group differences in HbA1c; therefore, it was not updated in this report. In this report, metformin versus GLP-1 receptor agonists and metformin versus SGLT-2 inhibitors also showed no clear between-group differences in HbA1c. They were graded as low strength of evidence, because the three studies in each comparison were imprecise and inconsistent. In this update, we found inconsistent findings in the studies of GLP-1 receptor agonists. It may be that the individual GLP-1 receptor agonists have different effects on HbA1c. A 2011 Cochrane systematic review showed small between-group differences in HbA1c, around 0.3%, for different GLP-1 receptor agonists.277 The strength of evidence was graded as insufficient for the other monotherapy comparisons of SGLT-2 inhibitors and GLP-1 receptor agonists, and this warrants further study.

Figure 96 Pooled between-group differences in hemoglobin A1c and strength of evidence for monotherapy and metformin-based combination comparisons

BL = baseline; CI = confidence interval; DPP4 = dipeptidyl peptidase-4 inhibitors; ES = effect size (mean between-group difference in HbA1c); GLP1 = glucagon-like peptide-1 agonists; HbA1c = hemoglobin A1c; Met = metformin; PLE = profile likelihood estimate; SGLT2 = sodium-glucose co-transporter-2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione; wks = weeks

The width of the horizontal lines represents the 95 percent confidence intervals for each pooled analysis.

Pooled between-group differences in hemoglobin A1c and strength of evidence for monotherapy and metformin-based combination comparisons.

All metformin combination therapies were better at reducing HbA1c than metformin monotherapy regimens, with between-group differences of around 0.7 to 1 absolute percentage points (Figure 96). While several moderate strength of evidence combination comparisons were significantly favored over the comparator combination (Figure 96), most between-group differences were small (<0.3%), with questionable clinical relevance. Only one combination comparison with moderate strength of evidence was favored by >0.3% over any other combination comparison: the combination of metformin plus a GLP-1 receptor agonist reduced HbA1c more than metformin plus a DPP-4 inhibitor. Despite the clinical interest in comparing metformin plus injectables, there was insufficient or low strength of evidence on glycemic control for the following comparisons: metformin plus the GLP-1 receptor agonists versus metformin plus basal or premixed insulin, and metformin plus premixed insulin versus metformin plus basal insulin. Two prior network meta-analyses278, 279 showed that most metformin-based combination comparisons had similar reductions in HbA1c. However, the results of the direct comparisons evaluated in this report are more precise allowing us to detect smaller between group differences than the results of the indirect comparisons found in the network meta-analyses.

#### Weight

Monotherapy and combination medication comparisons generally showed significant between-group differences when comparing medications anticipated to increase weight (sulfonylurea, thiazolidinediones, and insulin) with medications expected to maintain or decrease weight (metformin, DPP-4 inhibitors, GLP-1 receptor agonists, and SGLT-2 inhibitors) (Figure 97). In the prior report, metformin versus thiazolidinediones and metformin versus sulfonylureas were found to favor metformin, with differences of 2.5 kg, with high strength of evidence; therefore, these comparisons were not updated. In this report, metformin decreased weight more than DPP-4 inhibitors, while sulfonylureas caused slightly less weight gain than thiazolidinediones (Figure 97). Compared with metformin plus a DPP-4 inhibitor, the combinations of metformin plus GLP-1 receptor agonists and metformin plus SGLT-2 inhibitors were favored (Figure 97). Several comparisons discussed below had moderate strength of evidence but were unable to be pooled owing to differences among the studies. SGLT-2 inhibitors decreased weight more than metformin and more than DPP-4 inhibitors (between-group differences ranging from -1.3 kg to -2.7 kg). DPP-4 inhibitors and GLP-1 receptor agonists both decreased weight more than thiazolidinediones (between-group differences ranging from -2.3 kg to -3.5 kg). Lastly, metformin plus a sulfonylurea was favored over metformin plus a premixed or long-acting insulin (between-group difference ranging from -0.5 kg to -1.7 kg). Despite the clinical interest in comparing metformin plus injectables, there was low strength of evidence on weight for the comparisons of metformin plus the GLP-1 receptor agonists versus metformin plus basal or premixed insulin and metformin plus premixed insulin versus metformin plus basal insulin.

Figure 97 Pooled between-group differences in weight and strength of evidence for monotherapy and metformin-based combination comparisons

BL = baseline; CI = confidence interval; DPP4 = dipeptidyl peptidase-4 inhibitors; ES = effect size (mean between-group difference in weight); GLP1 = glucagon-like peptide-1 agonists; kg = kilograms; Met = metformin; PLE = profile likelihood estimate; SGLT2 = sodium-glucose co-transporter-2 inhibitors; SU = sulfonylurea; TZD = thiazolidinedione; wks = weeks; wt = weight

The width of the horizontal lines represents the 95 percent confidence intervals for each pooled analysis.

Pooled between-group differences in weight and strength of evidence for monotherapy and metformin-based combination comparisons. The width of the horizontal lines represent the 95 percent confidence intervals for each pooled analysis.

Notably, weight differences were small to moderate in these mainly short trials. However, even small to moderate amounts of weight gain (5 percent to 10 percent of body weight) may be associated with increased insulin resistance.280 In addition, weight loss and glycemic control were reported as the primary drivers of patient preferences for diabetes medications when compared with treatment burden and side effects in a recent systematic review.281 Drug effects on weight, therefore, have a strong impact on the choice of the drug added for second-line combination therapy in a patient not well controlled on a single agent. Our findings about diabetes medications effects on weight are similar to other prior systematic reviews.16, 277, 282 As monotherapy and in combination with metformin, thiazolidinediones, sulfonylureas, and basal or premixed insulin are associated with weight gain; DPP-4 inhibitors with weight maintenance; and SGLT-2 inhibitors and GLP-1 receptor agonists with weight loss.16, 277, 282, 283 Our systematic review builds on prior work by adding more direct comparative data about metformin combinations, which further confirm the known weight effects of the individual medications.

#### Systolic Blood Pressure and Heart Rate

Systolic blood pressure and heart rate were evaluated for the newer classes of medications, SGLT-2 inhibitors and GLP-1 receptor agonists, owing to suspected effects of these medications based on prior literature.277, 282 Blood pressure control is important in adults with diabetes.220, 284-286 The United Kingdom Prospective Diabetes Study (UKPDS) showed that for every 10 mmHg decrease in systolic blood pressure, there is a 15 percent decrease in diabetes-related deaths.285 Consistent with a prior systematic review on SGLT-2 inhibitors,282 the SGLT-2 inhibitors consistently reduced systolic blood pressure in all comparisons where there were sufficient studies (significant between-group differences of 3 to 5 mmHg when compared with other diabetes medications that have no effect on blood pressure). Our review builds on this work by evaluating direct comparisons of specific medication classes as comparators, as opposed to grouping all active comparators together. This is especially important, because thiazolidinediones and GLP-1 receptor agonists also have been associated with decreases in systolic blood pressure by 3 to 5 mmHg.15, 277 Metformin plus a GLP-1 receptor agonist had a greater reduction in systolic blood pressure compared with metformin alone (pooled between-group difference, 3.1 mmHg; 95% CI, 1.4 to 4.9 mmHg), with moderate strength of evidence. While the clinical relevance of these small differences is unclear, a change of 3-5 mmHg is about half the effect of a low sodium diet (around 7-11 mmHg) and about one-third the effect of blood pressure medications (around 10-15 mmHg).287, 288 Future research will be needed to determine whether there are any links between these small differences in blood pressure and micro- and macrovascular outcomes, given the prevalent use of effective medications to reduce cardiovascular risk (e.g., aspirin, blood pressure, and cholesterol medications).

Increased heart rate is associated with increased mortality.289 However, whether heart rate is an independent predictor of long-term clinical outcomes such as mortality is less clear.44 We opted to evaluate heart rate for the newer medications, SGLT-2 inhibitors and GLP-1 receptor agonists, given their association with mortality. In addition, we wanted to see if the benefits from blood pressure reduction might be offset by a concomitant increase in heart rate. We did not identify any prior systematic reviews that have evaluated this outcome for the diabetes comparisons of interest. Only two comparisons had sufficient data to grade the evidence as more than insufficient or low. The SGLT-2 inhibitors in combination with metformin were found to decrease heart rate by 1.5 bpm (95% CI, 0.6 bpm to 2.3 bpm) when compared with metformin plus a sulfonylurea; metformin and GLP-1 receptor agonist trials showed no between-group differences in heart rate. Therefore, these early findings support the findings of minimal to no effects on heart rate and no increase in heart rate for the newer medications.

### All-Cause Mortality and Macrovascular and Microvascular Outcomes

Ninety-six RCTs and 22 observational studies evaluated these clinical outcomes. Compared to the prior report,16 the evidence on mortality, cardiovascular mortality, and cardiovascular morbidity was strengthened for many comparisons, although most of this evidence was of low strength. The evidence regarding treatment effect on microvascular outcomes remains largely insufficient. Overall, the evidence base on these outcomes was limited by the short duration of RCTs (<2 years) and a lack of high-quality observational studies that would allow detection of treatment differences for infrequent outcomes. Also, none of the included RCTs were designed to evaluate these long-term outcomes.

#### All-Cause Mortality, Cardiovascular Mortality, and Cardiovascular Morbidity

This report builds on our prior results for the comparison of metformin and sulfonylurea monotherapy.16 In this update, we found moderate strength of evidence that sulfonylurea monotherapy was associated with a 50 percent to 70 percent increased relative risk (absolute risk difference, 0.1% to 2.9% in RCTs; number needed to treat, 34 to 1,000) of long-term cardiovascular mortality compared with metformin monotherapy. Our findings on all-cause mortality and cardiovascular morbidity were supportive of this conclusion, with low strength of evidence suggesting that metformin is favored over sulfonylurea monotherapy for both long-term mortality and cardiovascular morbidity. Our findings on sulfonylurea monotherapy enhance findings from meta-analyses published in 2012 and 2013, which relied more heavily on observational data or did not report explicitly on head-to-head comparisons of metformin and sulfonylurea monotherapy.290, 291 Importantly, we cannot know the absolute impact of individual drug classes on cardiovascular outcomes from this comparative effectiveness analysis. Our results suggest that cardiovascular mortality is lower in the metformin than sulfonylurea arms of the studies; however, we do not know if metformin actually decreases cardiovascular mortality or just increases cardiovascular mortality less than sulfonylureas, and likewise, we do not know if sulfonylureas actually increase cardiovascular mortality or just decrease cardiovascular mortality less than metformin.

We evaluated pioglitazone and rosiglitazone separately when they were compared with other drug classes for all-cause mortality and cardiovascular outcomes, given concerns about cardiovascular risk and mortality associated with rosiglitazone raised previously292 and acted upon by the FDA through recommendations regarding the prescription of this medication in 2010.^293, 294^ While the strength of evidence was low, metformin was favored over the combination of metformin plus rosiglitazone for short-term all-cause mortality, as well as cardiovascular mortality and cardiovascular morbidity; metformin was also favored, albeit with low strength of evidence, over rosiglitazone monotherapy for long-term mortality and long-term cardiovascular morbidity.

We had little evidence on the combination of metformin plus a sulfonylurea or metformin plus a thiazolidinedione. In The Rosiglitazone Evaluated for Cardiovascular Outcomes in oral agent combination therapy for type 2 Diabetes (RECORD) trial, 4,447 participants with diabetes were randomized to a rosiglitazone-based combination (with either metformin or sulfonylurea) or to the combination of metformin plus a sulfonylurea.49 We excluded this study from this outcome assessment, because it did not stratify results by a comparison of interest. This trial did not find a difference between rosiglitazone-based two-drug therapy and metformin plus a sulfonylurea for the primary endpoint, cardiovascular hospitalization or death. After 5.5 years, all-cause mortality, cardiovascular death, and stroke were slightly higher in the metformin plus sulfonylurea arm, and myocardial infarction rates were slightly (non-statistically significantly) higher in the rosiglitazone combination therapy arm. Of note, the FDA commissioned an independent re-adjudication and analysis of the data from RECORD and subsequently (in 2013) lifted their restrictions on rosiglitazone usage.295

Although strength of evidence was low, compared with the combination of metformin plus a sulfonylurea, the combination of metformin plus a DPP-4 inhibitor was associated with lower rates of long-term all-cause mortality and cardiovascular mortality and morbidity; an unpublished study with long-term followup was supportive of these conclusions. We also identified many new studies evaluating short-term all-cause mortality and cardiovascular outcomes for DPP-4 inhibitor comparisons, but most of this evidence was of low strength.

Several meta-analyses published since the 2011 report have evaluated DPP-4 inhibitors and all-cause mortality and cardiovascular outcomes; they tended to combine comparators (active, placebo, or both) against DPP-4 inhibitors so were not conclusive about specific direct comparisons.296-301 The conclusions of these reviews have been based mainly on trials with less than 2 years of followup and have reported mixed results on short-term mortality and cardiovascular risk.

Outside of these meta-analyses, three large RCTs have evaluated DPP-4 inhibitors compared with placebo, added to the standard diabetes treatment per routine clinical care, and cardiovascular outcomes.302-304 None of these RCTs evaluated direct head-to-head comparisons of interest, and none were included in this review. All of these trials designated a composite cardiovascular outcome as the primary outcome and reported non-inferiority (but not superiority) for the DPP-4 inhibitor addition compared with placebo addition for the composite cardiovascular outcome.302-304 Rates of the primary endpoint were lower in the DPP-4 inhibitor versus placebo arm in two of the three trials [risk difference (statistical comparison not provided): -0.5%,303 -0.2%,302 0.1%^302^]. Participants in all three trials were treated per clinical standards with diabetes and cardiovascular medications, and, in the two trials reporting on this, participants in the placebo arm were more likely to have an increase or addition of a diabetes medication and were more likely to start insulin.302, 303 There are several reasons that these RCTs demonstrating “non-inferiority” must be interpreted with caution: 1) differential diabetes medication use in the DPP-4 versus placebo arms raises the undeniable possibility that we are observing the effects of other diabetes medications (e.g., insulin) on the cardiovascular outcomes; 2) the assumptions for the non-inferiority sample size/power calculations are based on relative measures when an absolute risk difference may be quite relevant (e.g., an absolute risk difference of 0.1% corresponds to a number needed to harm of 1,000 – a number that has public health relevance given the potential population to be exposed); 3) effects of DPP-4 inhibitors versus placebo on individual outcomes (e.g., mortality, cardiovascular mortality) varied across the studies (Table 126); and 4) followup times of the studies were still short relative to the likely duration of use in actual clinical populations.

Table 126 Placebo-controlled RCTs evaluating DPP-4 inhibitors added to standard treatment with composite cardiovascular primary outcome

Trial | N | Study Population | Median Followup | All-Cause Mortality | CVD Death | Nonfatal MI
SAVOR-TIMI 53^302^ | 16,492 | CVD or risk factors | 2.1 years | HR, 1.11 (0.96 to 1.27; P=0.15) | HR, 1.03 (0.87 to 1.22; P=0.72) | HR, 0.95 (0.80 to 1.12; P=0.52)
SAVOR-TIMI 53^302^ | 16,492 | CVD or risk factors | 2.1 years | RD: 0.3% | RD: 0.3% | RD: -0.2%
EXAMINE304 | 5,380 | Recent CVD^*^ | 18 months | HR, 0.88 (0.71 to 1.09; P=0.23) | HR, 0.85 (0.66 to 1.10; P=0.21) | HR, 1.08 (0.88 to 1.33); P=0.47)
EXAMINE304 | 5,380 | Recent CVD^*^ | 18 months | RD: -0.8% | RD: -0.8% | RD: 0.4%
TECOS303 | 14,671 | CVD | 3.0 years | HR, 1.01 (0.90 to 1.14; P=0.88) | HR, 1.03 (0.89 to 1.19; P=0.71) | HR, NR
TECOS303 | 14,671 | CVD | 3.0 years | RD: 0.2% | RD: 0.2% | RD: 0.1%

CVD = cardiovascular disease; EXAMINE = Examination of Cardiovascular Outcomes with Alogliptin versus Standard of Care; HR = hazards ratio; MI = myocardial infarction; RD = risk difference; SAVOR-TIMI 53 = Saxagliptin Assessment of Vascular Outcomes Recorded in Patients with Diabetes Mellitus Thrombolysis in Myocardial Infarction; TECOS = Trial Evaluating Cardiovascular Outcomes with Sitagliptin

HR displayed with 95% CI and P value and RD with placebo arm as reference.

* Acute myocardial infarction or unstable angina in the past 15-90 days.

The evidence remains largely insufficient or of low strength regarding mortality and cardiovascular benefits or harms associated with GLP-1 receptor agonists. A meta-analysis suggested no difference in mortality rates for GLP-1 receptor agonists compared with other agents but did not make explicit monotherapy or combination comparisons.305

The evidence on all-cause mortality and cardiovascular mortality and morbidity for SGLT-2 inhibitor comparisons was limited. A meta-analysis of 25 studies comparing SGLT-2 inhibitor monotherapy with placebo or active monotherapy reported a non-statistically significant decrease in the risk of cardiovascular events for SGLT-2 inhibitors versus placebo or active monotherapy (OR, 0.90; 95% CI, 0.72 to 1.13); most studies were 52 weeks or shorter in duration.282

#### Retinopathy, Nephropathy, and Neuropathy

While we found more evidence on microvascular outcomes compared to the 2011 report,16 all evidence was of low strength or inconclusive, thereby limiting substantial conclusions. We did not identify any other evidence syntheses of these microvascular outcomes published since the prior report.

### Adverse Events

One hundred thirty-seven RCTs and eight observational studies evaluated adverse events. The RCTs mainly measured adverse events at 1 year or earlier. Five percent of RCTs were longer than 2 years. Of the few RCTs that evaluated longer time frames, most (75%) had at least 20 percent losses to followup, making it challenging to draw firm longer-term conclusions. Therefore, results discussed below are generally for the short term (less than 2 years) unless otherwise specified in the figure or text. As adverse events sometimes accrue over time, the mainly short-term differences in adverse events could be larger in the long-term. In addition, short-term studies measuring rare adverse events with no between-group differences could develop between-group differences when evaluated over the longer term or in those with higher baseline risk.

#### Hypoglycemia

Severe hypoglycemia is associated with increased morbidity (e.g., reduced cognition), increased avoidable health care use (e.g., emergency room visits for hypoglycemia), and increased mortality in clinical trials and observational studies.11, 306-308 We added new information on this important outcome in this report. We found moderate strength of evidence that sulfonylureas had an increased risk of severe hypoglycemia when compared with metformin (for RCTs: range in ORs, 1.4 to 2.0; range in RDs, 1% to 23%) or thiazolidinedione monotherapy (OR 8.1, RD, 0.5% from ADOPT).50 Similarly, in combination with metformin, sulfonylurea use had a greater risk of severe hypoglycemia when compared with the combination of metformin plus DPP-4 inhibitors or SGLT-2 inhibitors (for RCTs: range in ORs, 6 to 14; range in RDs, 0% to 3%).

In this report, we confirmed the elevated risk of mild, moderate, or total hypoglycemia associated with sulfonylureas, either alone or in combination, compared with both the older and newer hypoglycemic agents (Figure 98). Of the combination comparisons, we confirmed that metformin plus basal insulin had an 11 percent to 77 percent lower risk of hypoglycemia compared with the combination of metformin plus premixed insulin, with moderate strength of evidence.

Figure 98 Pooled odds ratios of mild/moderate hypoglycemia and strength of evidence for monotherapy and metformin-based combination comparisons

CI = confidence interval; DPP4 = dipeptidyl peptidase-4 inhibitors; Met = metformin; OR = odds ratio; PLE = profile likelihood estimate; RD = absolute risk difference; SGLT2 = sodium-glucose co-transporter-2 inhibitors; SU = sulfonylurea; TZD = thiazolidinediones; wks = weeks

The width of the horizontal lines represents the 95 percent confidence intervals for each pooled analysis. Drug 1 is the reference group.

Pooled odds ratios of mild/moderate hypoglycemia and strength of evidence for monotherapy and metformin-based combination comparisons.

For the newer medications (SGLT-2 inhibitors, GLP-1 receptor agonists, and DPP-4 inhibitors), we added to the evidence base by showing that SGLT-2 inhibitor monotherapy may be associated with 54 percent lower odds of mild or moderate hypoglycemia compared with metformin monotherapy, although absolute event rates were small across arms. This is consistent with a high-quality systematic review of the SGLT-2 inhibitors that also showed a non-significant lower risk of hypoglycemia in the SGLT-2 inhibitor arms compared with active comparators, although excluding sulfonylureas.282 We found that mild or moderate hypoglycemia was 1.7-fold higher for the combination of metformin plus an SGLT-2 inhibitor compared with metformin monotherapy. We also found an increased risk of hypoglycemia with the combination of metformin plus premixed or basal insulin compared with metformin plus GLP-1 receptor agonists (range in absolute risk differences of 3% to 13%; moderate strength of evidence). Prior systematic reviews of individual classes of newer agents had sparse data on hypoglycemia when compared with active comparators, although the newer classes were generally found to have low rates of hypoglycemia.277, 282, 298 While we found more studies comparing metformin combinations with metformin plus sulfonylurea, there were still few studies on the newer medication classes as monotherapy and in combination with metformin.

#### Gastrointestinal Side Effects

Metformin and GLP-1 receptor agonists as monotherapy and in combination had an increased risk of gastrointestinal (GI) adverse events (typically nausea, vomiting, or diarrhea) when compared with most other comparators, with moderate to high strength of evidence (Figure 99). Several medications had similar rates of GI adverse events with moderate or high strength of evidence: thiazolidinedione versus sulfonylurea, metformin plus a sulfonylurea versus metformin plus a DPP-4 inhibitor, metformin plus a thiazolidinedione versus metformin plus a sulfonylurea, metformin plus a sulfonylurea versus metformin plus a SGLT-2 inhibitor, metformin monotherapy versus metformin plus a SGLT-2 inhibitor, and metformin monotherapy versus metformin plus a DPP-4 inhibitor.

Figure 99 Pooled odds ratios of gastrointestinal adverse events and strength of evidence for monotherapy and metformin-based combination comparisons^*^ * All results presented in this graph are based on short-term (less than 52 weeks) studies unless otherwise specified.

AE = adverse event; CI = confidence interval; DPP4 = dipeptidyl peptidase-4 inhibitors; GI = gastrointestinal; Met = metformin; OR = odds ratio; PLE = profile likelihood estimate; RD = absolute risk difference; SGLT2 = sodium-glucose co-transporter-2 inhibitors; SU = sulfonylurea; TZD = thiazolidinediones

The width of the horizontal lines represents the 95 percent confidence intervals for each pooled analysis. Drug 1 is the reference group.

† Based on studies with 104 weeks of followup.

Pooled odds ratios of gastrointestinal adverse events and strength of evidence for monotherapy and metformin-based combination comparisons

We confirmed findings of the 2011 report16 showing that metformin had a greater risk of GI adverse events than thiazolidinediones, sulfonylureas, or DPP-4 inhibitors. We also report new findings showing GLP-1 receptor agonists have higher risk of GI adverse events when compared with thiazolidinediones and sulfonylureas, both as monotherapy or when used in combination with metformin. Our data confirm the GLP-1 comparative findings from a prior Cochrane systematic review277 and add information about specific combination comparisons and specific types of GI adverse events. GLP-1 receptor agonists also had higher risk of nausea and vomiting than metformin but no significant difference in diarrhea. The combinations of metformin plus DPP-4 inhibitors did not have worse GI adverse events than metformin monotherapy or metformin combinations. Lastly, we report new findings that SGLT-2 inhibitors showed no difference in GI adverse events when compared in combination with metformin against metformin plus sulfonylureas or compared with metformin monotherapy.

#### Cancer

The evidence about cancer was generally insufficient because of a lack of studies, and the existing evidence was of low strength. Of 25 RCTs reporting on cancer, only eight (32 percent) had at least 2 years of followup. Most published studies for the comparisons did not report on cancer events in all arms, which limited our ability to synthesize the evidence quantitatively and to draw conclusions.

Reviews and meta-analyses published since the 2011 report suggest that metformin decreases the risk of many types of cancer309, 310 and suggest that pioglitazone311 increases the risk of bladder cancer slightly, but we did not include many of the studies supporting those conclusions because of our stringent inclusion criteria for observational studies. We excluded the PROspective pioglitAzone Clinical Trial In macroVascular Events (PROactive) study,312 because it did not evaluate a comparison of interest. This trial found a higher rate of bladder cancer in the pioglitazone versus placebo arm, which did not persist in the 5.8-year followup study that included only 74 percent of the original study population, most of whom did not take pioglitazone after the randomized period.313

However, our review adds low strength of evidence for many comparisons of GLP-1 receptor agonists and DPP-4 inhibitors. Evidence on these therapies and cancer outcomes is of particular interest given the preclinical evidence linking incretins (the GLP-1 receptor agonists and DPP-4 inhibitors) to cancer.314 The three large, placebo-controlled RCTs described above, Saxagliptin Assessment of Vascular Outcomes Recorded in Patients with Diabetes Mellitus Thrombolysis in Myocardial Infarction (SAVOR TIMI 53), Examination of Cardiovascular Outcomes with Alogliptin versus Standard of Care (EXAMINE), and Trial Evaluating Cardiovascular Outcomes with Sitagliptin (TECOS), did not find an increased risk of cancer for DPP-4 inhibitors added to standard therapy.302-304 The FDA prescribing information for the GLP-1 receptor agonists, liraglutide,315 albiglutide,316 exenatide,317 and dulaglutide318 includes a warning regarding the potential for a link between these agents and medullary thyroid cancer, based on data in mice and rats.319 The evidence that we identified on the incretin-based therapies and cancer was of low strength and inconsistent. However, we found low strength of evidence that the combination of metformin plus a sulfonylurea was favored over the combination of metformin plus a DPP-4 inhibitor for longer-term cancer risk. An unpublished study's results, as well as longer-term followup of one of the included published studies,141 were consistent with this finding and may have increased this evidence to moderate strength.

#### Congestive Heart Failure

There was only one long-term 4-year RCT and only a few observational studies of medium quality with 6 to 8 years of followup that could provide a comparative assessment of the safety of diabetes medications on congestive heart failure. We found low strength of evidence of 1.2 to 1.6 increased odds of heart failure with the thiazolidinedione class of medications, when compared with sulfonylureas or metformin. Our strength of evidence on this outcome dropped to low in this update (from moderate in the prior review), because we excluded lower-quality observational studies and also excluded the RECORD trial for this outcome, owing to the active comparator being either sulfonylurea or metformin, instead of a single active comparator. RECORD showed that the combination of thiazolidinediones and another agent (sulfonylurea or metformin) was associated with a significant doubling in the risk of heart failure in comparison with the combination of sulfonylurea and metformin (61/2220 versus 29/2227, risk ratio (RR), 2.1; 95% CI, 1.35 to 3.27).49 These results showing a higher risk of congestive heart failure with thiazolidinediones were also confirmed in two recent meta-analyses.320, 321 Both thiazolidinediones, rosiglitazone and pioglitazone, are contraindicated in patients with serious or severe heart failure (Stage 3 or Stage 4), according to product labels.322, 323

We had low or insufficient strength of evidence for most other medication comparisons for heart failure, including the newer agents. Despite recent concerns about congestive heart failure with DPP-4 inhibitors, we found low or insufficient strength of evidence on the comparative safety of this drug class for this outcome in mainly short duration studies [five short duration RCTs reporting no events in the DPP-4 inhibitor arms, one short duration RCT with one event in the metformin plus DPP-4 arm and none in the comparator arm, and one RCT which reported few congestive heart failure events in the metformin plus DPP-4 inhibitor arm compared with the metformin plus sulfonylurea arm (three versus six respectively)]. Several large, double-blind, placebo-controlled RCTs evaluating DPP-4 inhibitors on cardiovascular outcomes in adults with moderate to high cardiovascular risk were excluded from our systematic review of head-to-head comparisons but deserve mention due to recent controversy.302, 303, 324 Two of these RCTs (comparing either saxagliptin or alogliptin with placebo) reported a small increased risk of hospitalization for congestive heart failure in adults at moderate to high cardiovascular risk (between-group absolute risk differences of 0.7% and 0.9%).302, 324 The EXAMINE trial with the alogliptin comparison reported these differences solely for the outcome of first hospitalization for heart failure in adults without pre-existing congestive heart failure as part of a posthoc subgroup analysis.324 The third placebo-controlled RCT303 compared sitagliptin with placebo on cardiovascular outcomes and reported no between-group differences in hospitalization for congestive heart failure. It is unclear if differences in these trials were due to differences in drug type, chance, or other causes. Due to these findings, however, the FDA has requested additional labeling for saxagliptin and alogliptin to reflect concerns of the potential increased risk of hospitalization for congestive heart failure.325 Further research directly comparing DPP-4 inhibitors with other active comparators on heart failure outcomes will be useful in determining the comparative safety of these medications on heart failure risk, including results of two RCTs [the Cardiovascular Outcome Study of Linagliptin Versus Glimepiride in Patients with Type 2 Diabetes (CAROLINA) and the Cardiovascular and Renal Microvascular Outcome Study with Linagliptin in Patients with Type 2 Diabetes Mellitus (CARMELINA) studies] of linagliptin, which are in progress.326, 327

#### Liver Injury

Similar to the 2011 report, we found little evidence on liver injury. Compared to the prior report showing no between-group differences in liver injury, we downgraded the available evidence for metformin versus thiazolidinedione monotherapy (from moderate to low) and downgraded the evidence for thiazolidinedione versus sulfonylurea monotherapy (from high to low). Notably, there are FDA warnings of post-marketing cases of hepatic failure for both alogliptin328 and pioglitazone,329 but we found low or insufficient strength of evidence for thiazolidinedione- and DPP-4 inhibitor-based comparisons and liver injury.

#### Lactic Acidosis

Prior evidence on the elevated risk of lactic acidosis with phenformin, an earlier biguanide, and case reports of lactic acidosis among metformin users have led to continued concern about an increased risk of lactic acidosis with metformin; however, for most of the ∼300 case reports on metformin and lactic acidosis, other factors contributing to lactic acidosis could not be excluded (e.g., acute myocardial infarction330, 331 or acute kidney failure). Consistent with the prior report16 and a Cochrane review on this topic,332 we did not find an increased risk of lactic acidosis with metformin based on the little evidence identified. A more recent systematic review by Inzucchi et al.333 evaluated the risk of lactic acidosis associated with metformin use in adults with mild to moderate chronic kidney disease (CKD; estimated glomerular filtration rates of 30-60 mL/min per 1.73 m^2^). Using data from 65 studies (mainly observational), they reported an overall incidence of 3-10 per 100,000 person-years of lactic acidosis in metformin users across studies,333 which is similar to the background prevalence in adults with diabetes not on metformin.332 The FDA is currently reviewing two citizen petitions to expand the use of metformin to adults with diabetes and mild to moderate CKD, with potential dose reductions in metformin to enhance safety in these populations.

#### Pancreatitis

Compared to the prior report, we identified many more studies on pancreatitis but found low strength of evidence for most comparisons. The DPP-4 inhibitors and GLP-1 receptor agonists were of most interest for this outcome, given the spontaneous reports to the FDA of pancreatitis associated with these agents. In the three large, placebo-controlled RCTs described above (SAVOR TIMI 53, EXAMINE, TECOS),302-304 more cases of pancreatitis have been observed in the DPP-4 inhibitor than placebo arms with a consistent absolute risk difference of 0.1 percent (number needed to harm of 1,000). In the SAVOR TIMI 53 trial, definite acute pancreatitis occurred in 17 participants (0.2 percent) in the saxagliptin arm and nine participants (0.1 percent) in the placebo arm (P =0.17).302 In EXAMINE, acute pancreatitis occurred in 12 participants (0.4 percent) in the alogliptin arm and in eight participants (0.3 percent) in the placebo arm. Finally, in TECOS, acute pancreatitis occurred in 23 participants (0.3 percent) and in 12 participants (0.2 percent) in the sitagliptin and placebo arms, respectively (HR, 1.93; 95% CI, 0.96 to 3.88; P =0.07). We excluded some of the Liraglutide Effect and Action in Diabetes (LEAD) RCTs from this report, because they did not evaluate comparisons of interest;334 seven participants exposed to liraglutide and one exposed to a sulfonylurea were diagnosed with pancreatitis across the six LEAD trials.335

Systematic reviews of RCTs336 and observational studies337 have reported small, non-statistically significant increases in the relative odds of pancreatitis for incretin-based therapies versus control treatments. However, these meta-analyses are underpowered for this rare outcome, grouped GLP-1 receptor agonists and DPP-4 inhibitors together, grouped comparators (placebo and different active treatments), and included studies of patients without diabetes.

#### Severe Allergic Reactions

In the prior report, we did not find evidence on severe allergic reactions. However, the issue of hypersensitivity reactions with diabetes medications has become more prominent with the uptake of DPP-4 inhibitors338 and GLP-1 receptor agonists.339-341 In March, 2012, the FDA added a warning about the risk of hypersensitivity reactions with DPP-4 inhibitors.342 Although still of low strength, we found the strongest evidence (based on four RCTs) that the addition of a DPP-4 inhibitor to metformin increases the risk of hypersensitivity reactions over metformin monotherapy alone. Prior data on the risk of hypersensitivity reactions with DPP-4 inhibitors have been mixed.338 The SAVOR-TIMI 53 trial found similar rates of hypersensitivity reactions for saxagliptin compared with placebo.302 In EXAMINE, angioedema was more frequent for the alogliptin arm (17/2701, 0.6%) than for the placebo arm (13/2679, 0.5%).304 TECOS did not report on this outcome.303

#### Macular Edema and Decreased Vision

We did not find conclusive evidence on outcomes of macular edema and decreased vision. A concern regarding the risks of macular edema with the thiazolidinediones persists and is based primarily on observational studies.343-345 Seven compared with three participants in the rosiglitazone and active comparator arms, respectively, developed macular edema in the RECORD trial (described above), although there were more than 2000 treated in each arm.49

#### Adverse Events Specific to SGLT-2 Inhibitors

Our findings of an increased risk of genital mycotic infections for SGLT-2 inhibitors compared to other agents are consistent with recent reviews of this topic.282, 346 The existing systematic reviews did not evaluate comparative effectiveness but, instead, grouped comparators together for synthesis.

In contrast to one of these recent systematic reviews of SGLT-2 monotherapy,282 but consistent with another,346 we did not find an increased risk of urinary tract infection (except for low strength of evidence in women for SGLT-2 inhibitor monotherapy relative to DPP-4 inhibitors) or volume depletion events; of note, all evidence in this report was of low strength (or insufficient) for urinary tract infection and volume depletion.

We also evaluated fracture risk and renal insufficiency associated with SGLT-2 inhibitors, given the issues raised about these adverse events in Vasilakou et al. 2013; in that review, the authors did not make conclusions about these outcomes, as their data were limited. We did not identify substantial evidence on these outcomes either. However, on September 10, 2015, the FDA strengthened its warning of an increased risk of fractures with canagliflozin based on pooled data from nine clinical trials.347 The risk of fracture was increased for canagliflozin (1.4/100 patient-years and 1.5/100 patient-years for canagliflozin 100 mg and canagliflozin 300 mg respectively) versus the comparator (1.1/100 patient-years for placebo and active comparators combined) with a mean follow up of 85 weeks across trials. The labeling for canagliflozin notes that clinicians should consider factors that increase fracture when starting canagliflozin.348

The FDA issued a warning regarding the risk of ketoacidosis with SGLT-2 inhibitors on May 15, 2015.^325^ We did not evaluate this outcome, as it was not a concern at the time that we selected outcomes for this report. The FDA warning stemmed from the observation of 20 cases of ketoacidosis in patients taking SGLT-2 inhibitors recorded in the FDA Adverse Event Reporting System (FAERS) database through June 6, 2014, followed by continued reports of ketoacidosis in patients taking SGLT-2 inhibitors since that time. A recent analysis of 17,596 participants from randomized trials of canagliflozin (mainly placebo-controlled), with 24,000 patient-years of exposure, demonstrated a higher number of patients experiencing ketoacidosis in the canagliflozin versus comparator arms: canagliflozin 100 mg: 4 (0.07 percent); canagliflozin 300 mg: 6 (0.11 percent); and comparator: 2 (0.03 percent).349 The authors noted that six of the 10 patients with ketoacidosis in the canagliflozin arms were found to have type 1 diabetes, latent autoimmune diabetes of adulthood (LADA) or antibodies to GAD65.^349^ The FDA has not changed labeling of the SGLT-2 inhibitors, at this time.325

### Subgroups

The limited evidence on outcomes in subgroups was for the outcome of HbA1c and did not show differential effects of the included comparisons on glycemic control by age, sex, race/ethnicity, or body mass index. Otherwise, the evidence on the comparative effectiveness of diabetes medications in subgroups defined by age, sex, race/ethnicity, and body mass index was generally inconclusive. This is especially unfortunate for the age and race/ethnicity sub-populations because of the known disparities in diabetes prevalence and diabetes outcomes for these groups. Older Americans suffer disproportionately from diabetes, with over 25 percent of persons 65 years of age and older having diabetes compared to 16 percent of persons 45 years of age to 64 years of age, and there is concern about the safety of medications (and polypharmacy) in older adults.1, 8 Also, compared to non-Hispanic white adults in the United States, diabetes is 20 percent more common in Asian Americans, 70 percent more common in Hispanics and non-Hispanic blacks, and twice as common in American Indians/Alaska Natives.1 Racial and ethnic minorities are also more likely to suffer from diabetes complications, including diabetic end-stage renal disease,350 retinopathy,351 amputations, hospitalization for cardiovascular outcomes,352 and diabetes-related mortality.353 Finally, racial and ethnic minorities are less likely to have controlled diabetes (HbA1c <7 percent), but are more likely to be on oral treatment only for diabetes.354

## Applicability

The applicability of these studies depends largely on the similarity of the study populations to the U.S. population with type 2 diabetes and the similarity of the interventions to usual clinical care (e.g., comparability of the drug interventions including dosing and duration of exposure to drugs). The included studies generally had populations, interventions, outcomes, and settings applicable to U.S. adults with type 2 diabetes, with a few notable exceptions, as described below.

Study population differences are the most pronounced threat to applicability. Study participants were mainly middle-aged (mean age in the mid 50s), overweight or obese adults who had diabetes for 3 to 7 years at the start of the studies. This is similar to the U.S. population with type 2 diabetes, which has a mean age of 60.5 years and a mean body mass index of 33 kg/m2 (23.5 percent overweight, 65.3 percent obese).355 However, most studies excluded people older than 75 or 80 years of age and excluded people with significant renal, hepatic, and cardiovascular disease, and other significant co-morbid conditions, making these studies less applicable, given that 52 percent of US adults with diabetes are older than 60 years of age, and just over 25 percent have a history of cardiovascular disease.355 When race was reported in the included studies, most subjects were Caucasian, although about 10 to 20 percent of study participants were of other races. These studies are, therefore, less applicable to people of different races and ethnicities, who make up about 40 percent of the US population with diabetes and, importantly, these groups have a greater diabetes burden than Caucasians (i.e., African Americans, Hispanics, Asian Americans, and American Indians).1, 355

Characteristics of the interventions also impact applicability, and most studies used dosing, frequency, and monitoring comparable to usual care. However, a threat to applicability relates to the duration of drug exposure, especially for glycemic control. The vast majority of RCTs lasted for 2 years or less. In usual care, patients with diabetes are on medications for over 10 years and are on multiple medications that impact adherence and side effects. Also, the glycemic response to medications may degrade over time; retained insulin sensitivity may allow insulin sensitizers (like metformin) to work longer as monotherapy than medications that are not insulin sensitizers. Also, in roughly one-third of the included trials, rescue therapy was used if participants did not meet specific glycemic goals, and participants were often censored from the study at that time. Thus, the results of these studies may not reflect what will occur with the clinical usage of the studied medications.

We generally had few concerns regarding applicability of the trial settings to usual care. While many trials did not take place exclusively in the United States, they did occur in similar settings. About half the trials occurred partly or exclusively in the United States, Italy, and/or were multinational; the rest of the trials occurred in developed or newly industrialized countries. However, few trials (about 25 percent) reported on the setting of recruitment, such as primary care or specialty care, so we cannot definitively comment on how like this is to usual care.

## Implications for Clinical and Policy Decisionmaking

This update provides additional evidence supporting metformin as the first-line medication therapy to treat type 2 diabetes, when tolerated; the evidence also supports the addition to metformin of a number of treatment options, based on patient preferences. Not only is metformin favored on the intermediate outcomes of HbA1c and weight, and not associated with serious adverse events, we found more conclusive evidence to support that cardiovascular mortality is lower with metformin compared with sulfonylureas. This evidence supports current guidelines, such as the American College of Physicians356 and American Diabetes Association26 guidelines, which recommend metformin as a first-line treatment choice. The American Association of Clinical Endocrinologists19 guideline also lists metformin as one of its first-line choices for treatment of type 2 diabetes, although it allows more flexibility in the choice of first-line therapy.

Metformin is currently contraindicated in patients with “renal disease or renal dysfunction,”357 because of concerns for an increased risk of lactic acidosis in this population. However, as described above, this risk is small and may not be higher than the background risk of lactic acidosis for patients with type 2 diabetes.332, 333 Twenty-two percent of patients with type 2 diabetes in the United States are estimated to have at least mild chronic kidney disease, indicating a large group of patients with type 2 diabetes who are not currently candidates for metformin therapy.358 Furthermore, some patients with type 2 diabetes are unable tolerate the side effects of metformin. The selection of initial diabetes therapy is an important clinical question for this relatively large population in which metformin is contraindicated or not tolerated. We evaluated non-metformin-based monotherapy comparisons in this report and demonstrated that, with the exception of DPP-4 inhibitors, which are not as effective in reducing HbA1c as metformin, the other monotherapies generally decrease HbA1c similarly (and comparably) to metformin. As described in detail, the other monotherapies' effects on weight vary as do their adverse effects, such as congestive heart failure (increased risk for thiazolidinediones), hypoglycemia (highest risk with sulfonylureas, including for severe hypoglycemia for many comparisons), gastrointestinal side effects (nausea and vomiting with GLP-1 receptor agonists), and genital mycotic infections (increased risk for SGLT-2 inhibitors). Most importantly, we do not have conclusive evidence on the relative long-term effects of non-metformin-based monotherapy on all-cause mortality or cardiovascular outcomes and rare, serious adverse events (e.g., pancreatitis risk with GLP-1 receptor agonists). Therefore, the alternative to metformin initial therapy is unclear and, seemingly, must be based on individual patient factors (e.g., HbA1c goal, risk of hypoglycemia) and preferences (e.g., avoidance of weight gain, cost).

Similarly, our evaluation of metformin-based combination therapies provides some insight into the selection of add-on therapy to metformin but is not definitive, because of the uncertainty of long-term outcomes and differential effects on weight and side effects. Comparisons of the metformin-based combinations suggested similar HbA1c-lowering for the metformin-based combination therapies (except for DPP-4 inhibitors added to metformin having a smaller HbA1c-lowering effect), differential weight effects, highest hypoglycemia risk with metformin plus a sulfonylurea, highest risk of gastrointestinal side effects with metformin plus GLP-1 receptor agonists, and increased risk of genital mycotic infections with metformin plus an SGLT-2 inhibitor.

As the newer medications (DPP-4 inhibitors, SGLT-2 inhibitors, and GLP-1 receptor agonists) remain on the market, become available as generics, and have additional data on comparative efficacy (for long-term outcomes) and safety, these newer medications may be preferred by patients. Therefore, the continued emphasis in guidelines about accounting for patient preferences when choosing therapy will be critical.26 In terms of cost, pioglitazone is the newest agent that has a generic. The first patent for Byetta expires in December 2016 and Januvia will have a patent expiry in 2017. If generics are available soon after, this will give patients and clinicians more affordable options for therapy.

In summary, we did not find large differences in HbA1c-lowering effects of the diabetes medications studied, except for DPP-4 inhibitors, which are not as effective as metformin. Weight effects of the medications are differential, and there is only evidence on cardiovascular mortality to support metformin over sulfonylureas as monotherapy. Each class of drug has different side effects (e.g., hypoglycemia, GI side effects, congestive heart failure), and the evidence on rare, serious side effects is less strong. Therefore, factors such as patient preferences and costs are likely to continue to drive selection of and adherence to the diabetes medications.

## Limitations of the Comparative Effectiveness Review Process

Several important limitations to our updated systematic review deserve mention. Although this was an update of a comprehensive review published in 2007 and an update in 2011, we focused this update a priori on studies with active control comparators, which are most relevant for clinical practice. Placebo-controlled trials had been included in the original 2007 review but excluded in the 2011 update. In general, the majority of placebo-controlled trials are short. However, the exclusion of placebo-controlled trials has implications for the review, including the inability to evaluate rare outcomes using indirect comparisons. To conclude from an active-control study that one medication is more effective than another requires prior knowledge that the active-control drug has been studied previously and is known to be more effective than placebo. Because the 2007 review had included placebo-controlled trials, we know that many drugs were more effective than placebo for the intermediate outcomes for many drug comparisons. However, this assumption may be less valid for the newer medications, where evidence on comparisons with placebo from other systematic reviews, such as the Cochrane Reviews,277, 283 will also be helpful in making conclusions.

In addition, our inclusion criteria required that all studies fit into one or more of the pre-specified comparisons of interest (Table 2), which identified specific drug-drug or two-drug comparisons. For example, studies that included any number of “background medications” were excluded. Our rationale was to avoid attributing outcomes to the medication of interest when it was truly due to the background medication. This was especially important because of our goal of evaluating two-drug combinations. Applying the inclusion criteria, which required pre-specified comparisons of interest, had several implications. This criteria required the exclusion of several large trials,9-12, 312, 359-363 some of which evaluated HbA1c-lowering strategies rather than individual medications, as well as some smaller trials and observational studies.

Of note, the RECORD study49 was included for the intermediate outcomes but excluded for the long-term and safety outcomes, because it did not stratify these outcomes by comparisons of interest. While excluding this study for these outcomes lowered our evidence grade for congestive heart failure, it did not change the overall conclusion. Another consequence of requiring direct comparisons of interest was that some of the recent studies of exenatide174, 364-366 and liraglutide261, 367-369 as add-on therapy to metformin did not have a specific comparison of interest and were therefore excluded. However, these studies would not have changed our findings as HbA1c were similar to those observed in the included studies, and these studies did not report on mortality, cardiovascular outcomes, pancreatitis, or cancer – outcomes of particular interest for these agents.

We also had strict criteria for including only medium- to high-quality observational studies. For instance, we required observational studies to have accounted for confounding by age, gender, race/socioeconomic status, and co-morbid conditions. The article could have used propensity score methodologies or other appropriate methods to account for differences between groups, or could have restricted to one race or socioeconomic status, for examples. By excluding observational studies with a higher risk of bias, we included only observational studies that could provide the most valid results. This resulted in the exclusion of many observational studies of harms, which could have strengthened the evidence base, but this was necessary to reduce confounding by indication in these studies.

We selected Key Questions focused on intermediate and long-term clinical outcomes through a topic refinement at the beginning of this process, which involved input from stakeholders on the Technical Expert Panel. Diabetes care is an extensive field, and we note the omission of key outcomes. For example, we did not collect information about patient-reported outcomes, such as medication adherence and barriers to adherence, health-related quality of life, or treatment satisfaction. These outcomes are important, because they may mediate the efficacy of treatment, and also are valuable to patients and clinicians. Future reviews with methodologies designed to capture many different study designs, including qualitative studies, and use of a wide range of measures, are needed to address these outcomes. For microvascular outcomes, we included studies evaluating proximal measures such as change in retinal exam or changes in microalbuminuria which may be less clinically relevant than other microvascular outcomes of blindness and changes in estimated glomerular filtration rate. However, we were unable to conclude anything about the comparative effects on the microvascular outcomes due to lack of sufficient evidence. These distinctions may become more important as more evidence accrues on these different microvascular outcomes. Although we assessed the mean difference in HbA1c between intervention groups in Key Question 1, we did not include the durability of HbA1c changes over time as an outcome, which may best be addressed using long-term well-designed observational studies.

In terms of pooling results, we chose to combine similar studies for pooled estimates. For study duration, we chose to combine similar duration studies which were often less than or equal to 52 weeks. While between-group differences might vary between 12, 24 and 52 week studies, we did not find substantial clinical or statistical heterogeneity related to these study duration differences in our pooled analyses. We also chose to combine results by drug class for most comparisons, except where clinically indicated (e.g., separated rosiglitazone and pioglitazone in cardiovascular comparisons). This may have led us to miss small differences within a drug class. However, if there was clinical or statistical heterogeneity noted among the studies, we evaluated for differences by drug type. For instance, we did not combine GLP-1 receptor agonists together in the hemoglobin A1c section (unless all studies used a single drug within the class, such as exenatide) owing to potential differences by drug type in glycemic control. This potential clinical heterogeneity was noted prior to combining the individual medications and was also identified when examining statistical heterogeneity among those studies. Also, in the 2007 report,15 we found that glyburide/glibenclamide had a higher absolute risk difference of mild, moderate, or total hypoglycemia compared with other sulfonylureas (pooled RD 3%; 95% CI, 0.5% to 5%). In this update, which focused on interclass comparisons, the studies that included glyburide/glibenclamide as the sulfonylurea did not consistently have larger between-group differences in hypoglycemia risk compared to the other sulfonylurea studies. Therefore, these studies were combined with the other sulfonylurea comparisons for hypoglycemia.

## Limitations of the Evidence Base

The major limitation of the evidence base was a lack of evidence supporting conclusions on the comparative long-term (followup at least 2 years) clinical (mortality, cardiovascular outcomes, and microvascular outcomes) and safety outcomes of the medications of interest. Given the low event rates for these outcomes and the timeframe in which they develop, RCTs, while extremely helpful, do not feasibly provide all of the evidence on long-term outcomes. Once we applied selection criteria to account for confounding by key factors, including confounding by indication, an important threat to validity in this setting, we did not identify many observational studies on the long-term and rare outcomes. Given the resources needed, not surprisingly, we did not identify any RCTs designed to evaluate long-term outcomes as the primary outcome. The included RCT evidence was underpowered for these outcomes based on the combination of small sample sizes, low event rates, and short study durations (generally 12 months or less). Substantial losses to followup, often differential across study arms, were another major limitation to the evidence on long-term clinical and safety outcomes. Additional limitations of the evidence base on long-term and safety outcomes included lack of reporting on these outcomes (including lack of reporting across all study arms), lack of active ascertainment of safety outcomes, and lack of an intention-to-treat approach.

As expected, the vast majority of included RCTs were industry-sponsored, raising the possibility of publication bias and other forms of bias, such as selective reporting of outcomes. While publication bias and reporting bias generally were not found, publication bias analyses have limited power, owing to the small numbers of studies for any given comparison. Although we cannot conclude that bias was present, we have to be especially concerned about the following issues identified across the included RCTs (which are important regardless of sponsorship):

- For the long-term clinical and safety outcomes, many studies reported an event in one arm but not in the comparator arm, making it challenging to compare medications.
- Several studies failed to report the significance of between-group differences and the measures of dispersion, thereby hindering efforts to estimate effect size across trials for intermediate outcomes.
- Some trials compared medications using dissimilar doses, limiting our ability to draw conclusions about efficacy.

Also, many studies had high rates of withdrawals; even if the studies described the rates of withdrawals, they often did not use a valid method for accounting for missing data.370 Finally, authors of the included randomized trials often did not describe their method of randomization and often did not describe double-blinding, making it difficult to appropriately assess risk of bias of individual studies.

## Research Gaps and Future Research Needs

Based on the limitations of the evidence base, using the PICOT framework, we highlight several major gaps in the evidence in Table 127. We report these for all of the Key Questions (Key Questions 1-4; comparative effectiveness and safety) together, to avoid duplicating research gaps that apply to more than one Key Question. We also added a specific “methodologic” category to complement the content-oriented research gaps. We provide recommendations on future research needs corresponding to these research gaps (Table 127).

Table 127 Evidence gaps and future research needs for the comparative effectiveness and safety of diabetes medications for adults with type 2 diabetes

PICOT Category | Evidence Gap | Future Research Needs
Population
| - Lack of study of older adults, racial/ethnic minorities, and persons with co-morbid conditions such as significant renal, cardiovascular and hepatic impairment.; - Limited evidence on a priori subgroups of interest such as older adults, racial/ethnic minorities, sex, and BMI | - Studies which include diverse populations; - Studies with an a priori plan to investigate differences by important subgroups of interest
Interventions & Comparators
HbA1c, weight, hypoglycemia and GI adverse events | - Limited information on GLP-1 receptor agonist comparisons as monotherapy and in combination with metformin versus specific diabetes medication comparators.; - Limited information on metformin plus insulin versus other metformin-based combinations. | - RCTs evaluating the GLP-1 receptor agonists as monotherapy and in combination with metformin. If adding GLP-1 receptor agonists to different background medications, then RCTs should conduct stratified randomization by background medication and evaluate effects by background medication.; - RCTs evaluating intermediate outcomes for metformin plus the addition of insulin with other metformin-based combinations, and in particular metformin plus a GLP-1 receptor agonist would be useful for patients and clinicians contemplating an add-on injectable to metformin.
Outcomes
All-cause mortality and macrovascular and microvascular outcomes | - Limited information on macrovascular outcomes and death; - Existing evidence underpowered; - Limited number of high-quality observational studies; - No conclusive evidence on microvascular outcomes; - No RCTs evaluated these outcomes as a primary outcome; - Inconsistent outcome definitions, ascertainment, and reporting in each study arm | - High-quality observational studies for all comparisons; - Longer duration RCTs for all comparisons evaluating macrovascular and microvascular events as primary outcomes; - Standardized definitions for macrovascular and especially microvascular outcomes (e.g., incident nephropathy based on eGFR and urine albumin:creatinine ratios); - Reporting on outcomes in all arms of RCTs
Rare safety outcomes | - Existing evidence underpowered; - Lack of high-quality observational studies; - Inconsistent outcome definitions, ascertainment, and reporting in each study arm, especially for pancreatitis and cancer; - No conclusive evidence on any of the following adverse events: CHF, pancreatitis, cancer, liver injury, lactic acidosis, severe allergic reactions, macular edema; - No conclusive evidence on volume depletion for SGLT-2 inhibitor comparisons | - High-quality observational studies for rare outcomes^*^; - Specific safety outcomes and drugs require further study including the following:; ○ CHF – DPP-4 inhibitors; ○ Macular edema – TZDs; ○ Pancreatitis – DPP-4 inhibitors and GLP-1 receptor agonists; ○ Thyroid cancer – GLP-1 receptor agonists; ○ Volume depletion – SGLT-2 inhibitors; ○ Ketoacidosis – SGLT-2 inhibitors; - RCTs; ○ Active ascertainment of all safety outcomes; ○ Standardized definitions for all safety outcomes; ○ Reporting on safety outcomes in all arms
Timing | - Most evidence is for short-term outcomes as few studies lasted more than 2 years | - Longer duration studies (>2 years); ○ To determine durability of short-term comparative effects on HbA1c and weight; ○ To determine long-term clinical effectiveness (e.g., all-cause mortality and cardiovascular outcomes) and safety
Methodological | - High, and often differential, losses to followup in RCTs; - Lack of reporting on randomization methods (for RCTs); - Lack of reporting on allocation concealment, blinding, and withdrawals for all studies; - Lack of appropriate accounting for confounding in observational studies; - Lack of reporting on treatments in observational studies | - Complete or near-complete followup in RCTs (focus on retention); - Appropriate methods to account for losses to followup if needed (e.g., multiple imputation); - Reporting on methods for randomization, allocation concealment, and blinding in RCTs; - High-quality observational studies for long-term comparative effectiveness and safety of diabetes medications^*^

BMI = body mass index; CHF = congestive heart failure; DPP-4 = dipeptidyl peptidase-4; eGFR = estimated glomerular filtration rate; GI = gastrointestinal; GLP-1 = glucagon-like peptide-1; HbA1c = hemoglobin A1c; RCT = randomized controlled trial; SGLT-2 sodium-glucose co-transporter-2; TZD = thiazolidinediones

* See text above for more detail.

In particular, we want to highlight the importance of future research using high-quality observational studies to determine the comparative effects of diabetes medications on long-term clinical and safety outcomes. Multi-year (or decade) trials are often infeasible. Supplementing the rare RCT that can be conducted for these outcomes with truly high-quality observational studies is paramount.

We propose that, at a minimum, such observational studies will need to follow patients over time, analyze similar comparison groups, and account for confounding by indication (including duration of diabetes and co-morbid conditions). Databases with sufficient sample size, followup over time, data on treatments (including doses and duration), and confounders, such as demographics, duration of diabetes, and co-morbid conditions, will be necessary. A recent review by Patorno et al. provided a thorough evaluation of threats to the validity of observational studies of diabetes medications and cardiovascular outcomes and outlined approaches to avoiding these biases.371 Briefly, the following are major methodological pitfalls and strategies to avoiding biases in the conduct of future observational studies of the comparative effectiveness and safety of diabetes medications371:

- Confounding by indication: Basic variables which must be considered to reduce confounding by indication include demographics, duration of diabetes, and co-morbid conditions. Many statistical methods may be sufficient (e.g., multivariate regression, restriction, instrumental variables), but propensity score methods may be the strongest to handle confounding by indication. In particular, high-dimensional propensity score algorithms may be the most rigorous, as they can help deal with unmeasured confounders.
- Immortal time bias: Prospective studies that define cohort entry based on exposure to a drug (versus calendar time or diagnosis of diabetes during a specified window), that have covariate information prior to exposure, and that do not condition cohort entry on events that occur during followup (e.g., initiation of insulin) are most likely to avoid immortal time bias.
- Time- and cumulative exposure-varying incidence of outcomes: The effects of medications on the outcomes of interest may vary over time and with cumulative drug exposure; study designs evaluating new users of drugs and accounting for exposure time will minimize biases due to time- and cumulative exposure-dependent effects of medications.
- Reverse causation: Analyses allowing for lag time after exposure can reduce the chance of reverse causality.
- Informative censoring: Censoring of observations when a drug exposure stops may lead to informative censoring, because reasons related to drug continuation may also be related to the outcome of interest. Analyses accounting for latency of drug effects can address this issue.
- Time-varying drug exposure: Although time-to-event analyses are often preferred to evaluate risk factors for outcomes such as cardiovascular disease, in the case of diabetes, drug changes may be related to the outcome. Sensitivity analyses can be used to support analyses based on time-to-event analyses.
- Time-dependent confounders: Inclusion of important confounding factors, such as co-morbid conditions that change over time, and the use of statistical methods, such as marginal structural models, may be helpful in handling such confounders.

## Conclusions

Although the comparative long-term benefits and harms of most diabetes medications remain unclear, the evidence supports use of metformin as a first-line agent, because of its beneficial effects on HbA1c, weight, and long-term outcomes (cardiovascular mortality benefit for metformin versus sulfonylureas, in particular), and its relative safety. With the exception of DPP-4 inhibitors, which have smaller effects on HbA1c reduction compared to metformin, the HbA1c-lowering of the other diabetes medications are similar, for monotherapy and metformin-based combination comparisons. The alternative to metformin monotherapy is unclear because of a lack of evidence on long-term effectiveness and safety outcomes on the other monotherapy comparisons. Likewise, the comparative effectiveness of metformin-based combinations for long-term macrovascular, microvascular, and rare safety outcomes is unclear. Monotherapy and metformin-based combination comparisons have differential effects on weight and side effects (e.g., hypoglycemia, GI side effects). In this report, we provide comprehensive information on the relative benefits and harms of diabetes medications to inform personalized treatment choices by patients and their clinicians, as well as to support decisionmaking by payers and regulators.