# Appendix G References

1 Aaboe K, Knop FK, Vilsboll T, et al. (2010). Twelve weeks treatment with the DPP-4 inhibitor, sitagliptin, prevents degradation of peptide YY and improves glucose and non-glucose induced insulin secretion in patients with type 2 diabetes mellitus. Diabetes Obes Metab.
2 Ahren B, Johnson SL, Stewart M, et al. (2014). HARMONY 3: 104-Week Randomized, Double-Blind, Placebo- and Active-Controlled Trial Assessing the Efficacy and Safety of Albiglutide Compared With Placebo, Sitagliptin, and Glimepiride in Patients With Type 2 Diabetes Taking Metformin. Diabetes Care.
3 Alba M, Ahren B, Inzucchi SE, et al. (2013). Sitagliptin and pioglitazone provide complementary effects on postprandial glucose and pancreatic islet cell function. Diabetes Obes Metab.
4 Apovian CM, Bergenstal RM, Cuddihy RM, et al. (2010). Effects of exenatide combined with lifestyle modification in patients with type 2 diabetes. Am J Med.
5 Arechavaleta R, Seck T, Chen Y, et al. (2011). Efficacy and safety of treatment with sitagliptin or glimepiride in patients with type 2 diabetes inadequately controlled on metformin monotherapy: a randomized, double-blind, non-inferiority trial. Diabetes Obes Metab.
6 Arjona Ferreira JC, Marre M, Barzilai N, et al. (2013). Efficacy and safety of sitagliptin versus glipizide in patients with type 2 diabetes and moderate-to-severe chronic renal insufficiency. Diabetes Care.
7 Aschner P, Katzeff HL, Guo H, et al. (2010). Efficacy and safety of monotherapy of sitagliptin compared with metformin in patients with type 2 diabetes. Diabetes Obes Metab.
8 Aschner P, Chan J, Owens DR, et al. (2012). Insulin glargine versus sitagliptin in insulin-naive patients with type 2 diabetes mellitus uncontrolled on metformin (EASIE): a multicentre, randomised open-label trial. Lancet.
9 Bailey CJ, Bagdonas A, Rubes J, et al. (2005). Rosiglitazone/metformin fixed-dose combination compared with uptitrated metformin alone in type 2 diabetes mellitus: a 24-week, multicenter, randomized, double-blind, parallel-group study. Clin Ther.
10 Bailey CJ, Gross JL, Hennicken D, et al. (2013). Dapagliflozin add-on to metformin in type 2 diabetes inadequately controlled with metformin: a randomized, double-blind, placebo-controlled 102-week trial. BMC Med.
11 Bakris G, Viberti G, Weston WM, et al. (2003). Rosiglitazone reduces urinary albumin excretion in type II diabetes. J Hum Hypertens.
12 Bakris GL, Ruilope LM, McMorn SO, et al. (2006). Rosiglitazone reduces microalbuminuria and blood pressure independently of glycemia in type 2 diabetes patients with microalbuminuria. J Hypertens.
13 Barnett AH, Patel S, Harper R, et al. (2012). Linagliptin monotherapy in type 2 diabetes patients for whom metformin is inappropriate: an 18-week randomized, double-blind, placebo-controlled phase III trial with a 34-week active-controlled extension. Diabetes Obes Metab.
14 Bergenstal RM, Wysham C, Macconell L, et al. (2010). Efficacy and safety of exenatide once weekly versus sitagliptin or pioglitazone as an adjunct to metformin for treatment of type 2 diabetes (DURATION-2): a randomised trial. Lancet.
15 Bergenstal RM, Forti A, Chiasson JL, et al. (2012). Efficacy and safety of taspoglutide versus sitagliptin for type 2 diabetes mellitus (T-emerge 4 trial). Diabetes Ther.
16 Blonde L, Rosenstock J, Mooradian AD, et al. (2002). Glyburide/metformin combination product is safe and efficacious in patients with type 2 diabetes failing sulphonylurea therapy. Diabetes Obes Metab.
17 Bolinder J, Ljunggren O, Kullberg J, et al. (2012). Effects of dapagliflozin on body weight, total fat mass, and regional adipose tissue distribution in patients with type 2 diabetes mellitus with inadequate glycemic control on metformin. J Clin Endocrinol Metab.
18 Borges JL, Bilezikian JP, Jones-Leone AR, et al. (2011). A randomized, parallel group, double-blind, multicentre study comparing the efficacy and safety of Avandamet (rosiglitazone/metformin) and metformin on long-term glycaemic control and bone mineral density after 80 weeks of treatment in drug-naive type 2 diabetes mellitus patients. Diabetes Obes Metab.
19 Campbell IW, Menzies DG, Chalmers J, et al. (1994). One year comparative trial of metformin and glipizide in type 2 diabetes mellitus. Diabete Metab.
20 Cefalu WT, Leiter LA, Yoon KH, et al. (2013). Efficacy and safety of canagliflozin versus glimepiride in patients with type 2 diabetes inadequately controlled with metformin (CANTATA-SU): 52 week results from a randomised, double-blind, phase 3 non-inferiority trial. Lancet.
21 Charbonnel B, Karasik A, Liu J, et al. (2006). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes inadequately controlled with metformin alone. Diabetes Care.
22 Charpentier G, Fleury F, Kabir M, et al. (2001). Improved glycaemic control by addition of glimepiride to metformin monotherapy in type 2 diabetic patients. Diabet Med.
23 Chawla S, Kaushik N, Singh NP, et al. (2013). Effect of addition of either sitagliptin or pioglitazone in patients with uncontrolled type 2 diabetes mellitus on metformin: A randomized controlled trial. J Pharmacol Pharmacother.
24 Chien HH, Chang CT, Chu NF, et al. (2007). Effect of glyburide-metformin combination tablet in patients with type 2 diabetes. J Chin Med Assoc.
25 Comaschi M, Demicheli A, Di Pietro C, et al. (2007). Effects of pioglitazone in combination with metformin or a sulfonylurea compared to a fixed-dose combination of metformin and glibenclamide in patients with type 2 diabetes. Diabetes Technol Ther.
26 Davies MJ, Thaware PK, Tringham JR, et al. (2007). A randomized controlled trial examining combinations of repaglinide, metformin and NPH insulin. Diabet Med.
27 DeFronzo RA, Goodman AM. (1995). Efficacy of metformin in patients with non-insulin-dependent diabetes mellitus. The Multicenter Metformin Study Group. N Engl J Med.
28 DeFronzo RA, Ratner RE, Han J, et al. (2005). Effects of exenatide (exendin-4) on glycemic control and weight over 30 weeks in metformin-treated patients with type 2 diabetes. Diabetes Care.
29 DeFronzo RA, Hissa MN, Garber AJ, et al. (2009). The efficacy and safety of saxagliptin when added to metformin therapy in patients with inadequately controlled type 2 diabetes with metformin alone. Diabetes Care.
30 DeFronzo RA, Triplitt C, Qu Y, et al. (2010). Effects of exenatide plus rosiglitazone on beta-cell function and insulin sensitivity in subjects with type 2 diabetes on metformin. Diabetes Care.
31 DeFronzo RA, Burant CF, Fleck P, et al. (2012). Efficacy and tolerability of the DPP-4 inhibitor alogliptin combined with pioglitazone, in metformin-treated patients with type 2 diabetes. J Clin Endocrinol Metab.
32 Del Prato S, Nauck M, Duran-Garcia S, et al. (2015). Long-term glycaemic response and tolerability of dapagliflozin versus a sulphonylurea as add-on therapy to metformin in type 2 diabetes patients: 4-year data. Diabetes Obes Metab.
33 Del Prato S, Camisasca R, Wilson C, et al. (2014). Durability of the efficacy and safety of alogliptin compared with glipizide in type 2 diabetes mellitus: a 2-year study. Diabetes Obes Metab.
34 Derosa G, Franzetti I, Gadaleta G, et al. (2004). Metabolic variations with oral antidiabetic drugs in patients with Type 2 diabetes: comparison between glimepiride and metformin. Diabetes Nutr Metab.
35 Derosa G, Cicero AF, Gaddi AV, et al. (2005). Long-term effects of glimepiride or rosiglitazone in combination with metformin on blood pressure control in type 2 diabetic patients affected by the metabolic syndrome: a 12-month, double-blind, randomized clinical trial. Clin Ther.
36 Derosa G, Gaddi AV, Piccinni MN, et al. (2005). Antithrombotic effects of rosiglitazone-metformin versus glimepiride-metformin combination therapy in patients with type 2 diabetes mellitus and metabolic syndrome. Pharmacotherapy.
37 Derosa G, Gaddi AV, Ciccarelli L, et al. (2005). Long-term effect of glimepiride and rosiglitazone on non-conventional cardiovascular risk factors in metformin-treated patients affected by metabolic syndrome: a randomized, double-blind clinical trial. J Int Med Res.
38 Derosa G, Maffioli P, Salvadeo SA, et al. (2009). Direct comparison among oral hypoglycemic agents and their association with insulin resistance evaluated by euglycemic hyperinsulinemic clamp: the 60's study. Metabolism.
39 Derosa G, Maffioli P, Salvadeo SA, et al. (2010). Exenatide versus glibenclamide in patients with diabetes. Diabetes Technol Ther.
40 Derosa G, Putignano P, Bossi AC, et al. (2011). Exenatide or glimepiride added to metformin on metabolic control and on insulin resistance in type 2 diabetic patients. Eur J Pharmacol.
41 Derosa G, Carbone A, D'Angelo A, et al. (2012). A randomized, double-blind, placebo-controlled trial evaluating sitagliptin action on insulin resistance parameters and beta-cell function. Expert Opin Pharmacother.
42 Derosa G, Carbone A, D'Angelo A, et al. (2013). Variations in inflammatory biomarkers following the addition of sitagliptin in patients with type 2 diabetes not controlled with metformin. Intern Med.
43 Derosa G, Cicero AF, Franzetti IG, et al. (2013). Effects of exenatide and metformin in combination on some adipocytokine levels: a comparison with metformin monotherapy. Can J Physiol Pharmacol.
44 Diamant M, Van Gaal L, Stranks S, et al. (2010). Once weekly exenatide compared with insulin glargine titrated to target in patients with type 2 diabetes (DURATION-3): an open-label randomised trial. Lancet.
45 Einhorn D, Rendell M, Rosenzweig J, et al. (2000). Pioglitazone hydrochloride in combination with metformin in the treatment of type 2 diabetes mellitus: a randomized, placebo-controlled study. The Pioglitazone 027 Study Group. Clin Ther.
46 Erdem G, Dogru T, Tasci I, et al. (2008). The effects of pioglitazone and metformin on plasma visfatin levels in patients with treatment naive type 2 diabetes mellitus. Diabetes Res Clin Pract.
47 Erem C, Ozbas HM, Nuhoglu I, et al. (2014). Comparison of effects of gliclazide, metformin and pioglitazone monotherapies on glycemic control and cardiovascular risk factors in patients with newly diagnosed uncontrolled type 2 diabetes mellitus. Exp Clin Endocrinol Diabetes.
48 Esposito K, Maiorino MI, Di Palo C, et al. (2011). Effects of pioglitazone versus metformin on circulating endothelial microparticles and progenitor cells in patients with newly diagnosed type 2 diabetes--a randomized controlled trial. Diabetes Obes Metab.
49 Esteghamati A, Ghasemiesfe M, Mousavizadeh M, et al. (2014). Pioglitazone and metformin are equally effective in reduction of chemerin in patients with type 2 diabetes. J Diabetes Investig.
50 Esteghamati A, Azizi R, Ebadi M, et al. (2015). The Comparative Effect of Pioglitazone and Metformin on Serum Osteoprotegerin, Adiponectin and Intercellular Adhesion Molecule Concentrations in Patients with Newly Diagnosed Type 2 Diabetes: a Randomized Clinical Trial. Exp Clin Endocrinol Diabetes.
51 Farcasiu E, Ivanyi T, Mozejko-Pastewka B, et al. (2011). Efficacy and safety of prandial premixed therapy using insulin lispro mix 50/50 3 times daily compared with progressive titration of insulin lispro mix 75/25 or biphasic insulin aspart 70/30 twice daily in patients with type 2 diabetes mellitus: a randomized, 16-week, open-label study. Clin Ther.
52 Feinglos M, Dailey G, Cefalu W, et al. (2005). Effect on glycemic control of the addition of 2.5 mg glipizide GITS to metformin in patients with T2DM. Diabetes Res Clin Pract.
53 Ferrannini E, Berk A, Hantel S, et al. (2013). Long-term safety and efficacy of empagliflozin, sitagliptin, and metformin: An active-controlled, parallel-group, randomized, 78-week open-label extension study in patients with type 2 diabetes. Diabetes Care.
54 Fidan E, Onder Ersoz H, Yilmaz M, et al. (2011). The effects of rosiglitazone and metformin on inflammation and endothelial dysfunction in patients with type 2 diabetes mellitus. Acta Diabetol.
55 Fonseca V, Rosenstock J, Patwardhan R, et al. (2000). Effect of metformin and rosiglitazone combination therapy in patients with type 2 diabetes mellitus: a randomized controlled trial. JAMA.
56 Fonseca V, Zhu T, Karyekar C, et al. (2012). Adding saxagliptin to extended-release metformin vs. uptitrating metformin dosage. Diabetes Obes Metab.
57 Forst T, Uhlig-Laske B, Ring A, et al. (2010). Linagliptin (BI 1356), a potent and selective DPP-4 inhibitor, is safe and efficacious in combination with metformin in patients with inadequately controlled Type 2 diabetes. Diabet Med.
58 Forst T, Michelson G, Ratter F, et al. (2012). Addition of liraglutide in patients with Type 2 diabetes well controlled on metformin monotherapy improves several markers of vascular function. Diabet Med.
59 Forst T, Anastassiadis E, Diessel S, et al. (2014). Effect of linagliptin compared to glimepiride on postprandial glucose metabolism, islet cell function, and vascular function parameters in patients with type 2 diabetes mellitus on ongoing metformin treatment. Diabetes Metab Res Rev.
60 Gallwitz B, Bohmer M, Segiet T, et al. (2011). Exenatide twice daily versus premixed insulin aspart 70/30 in metformin-treated patients with type 2 diabetes: a randomized 26-week study on glycemic control and hypoglycemia. Diabetes Care.
61 Gallwitz B, Rosenstock J, Rauch T, et al. (2012). 2-year efficacy and safety of linagliptin compared with glimepiride in patients with type 2 diabetes inadequately controlled on metformin: a randomised, double-blind, non-inferiority trial. Lancet.
62 Gallwitz B, Guzman J, Dotta F, et al. (2012). Exenatide twice daily versus glimepiride for prevention of glycaemic deterioration in patients with type 2 diabetes with metformin failure (EUREXA): an open-label, randomised controlled trial. Lancet.
63 Garber AJ, Larsen J, Schneider SH, et al. (2002). Simultaneous glyburide/metformin therapy is superior to component monotherapy as an initial pharmacological treatment for type 2 diabetes. Diabetes Obes Metab.
64 Garber AJ, Donovan DSJ, Dandona P, et al. (2003). Efficacy of glyburide/metformin tablets compared with initial monotherapy in type 2 diabetes. J Clin Endocrinol Metab.
65 Garber A, Klein E, Bruce S, et al. (2006). Metformin-glibenclamide versus metformin plus rosiglitazone in patients with type 2 diabetes inadequately controlled on metformin monotherapy. Diabetes Obes Metab.
66 Garber A, Henry R, Ratner R, et al. (2009). Liraglutide versus glimepiride monotherapy for type 2 diabetes (LEAD-3 Mono): a randomised, 52-week, phase III, double-blind, parallel-treatment trial. Lancet.
67 Garber A, Henry RR, Ratner R, et al. (2011). Liraglutide, a once-daily human glucagon-like peptide 1 analogue, provides sustained improvements in glycaemic control and weight for 2 years as monotherapy compared with glimepiride in patients with type 2 diabetes. Diabetes Obes Metab.
68 Genovese S, Passaro A, Brunetti P, et al. (2013). Pioglitazone Randomised Italian Study on Metabolic Syndrome (PRISMA): effect of pioglitazone with metformin on HDL-C levels in Type 2 diabetic patients. J Endocrinol Invest.
69 Genovese S, De Berardis G, Nicolucci A, et al. (2013). Effect of pioglitazone versus metformin on cardiovascular risk markers in type 2 diabetes. Adv Ther.
70 Goke B, Gallwitz B, Eriksson J, et al. (2010). Saxagliptin is non-inferior to glipizide in patients with type 2 diabetes mellitus inadequately controlled on metformin alone: a 52-week randomised controlled trial. Int J Clin Pract.
71 Goldstein BJ, Pans M, Rubin CJ. (2003). Multicenter, randomized, double-masked, parallel-group assessment of simultaneous glipizide/metformin as second-line pharmacologic treatment for patients with type 2 diabetes mellitus that is inadequately controlled by a sulfonylurea. Clin Ther.
72 Goldstein BJ, Feinglos MN, Lunceford JK, et al. (2007). Effect of initial combination therapy with sitagliptin, a dipeptidyl peptidase-4 inhibitor, and metformin on glycemic control in patients with type 2 diabetes. Diabetes Care.
73 Gomez-Perez FJ, Fanghanel-Salmon G, Antonio Barbosa J, et al. (2002). Efficacy and safety of rosiglitazone plus metformin in Mexicans with type 2 diabetes. Diabetes Metab Res Rev.
74 Gupta AK, Smith SR, Greenway FL, et al. (2009). Pioglitazone treatment in type 2 diabetes mellitus when combined with portion control diet modifies the metabolic syndrome. Diabetes Obes Metab.
75 Gupta RK, Rehan HS, Rohatagi A, et al. (2010). The effect of glipizide, metformin and rosiglitazone on nontraditional cardiovascular risk factors in newly diagnosed patients with type 2 diabetes mellitus. International journal of diabetes in developing countries.
76 Gupta A, Ahmad Ansari N, Yadav N. (2013). Comparative efficacy and safety of sitagliptin and Glimepiride in patients of newly diagnosed type 2 diabetes mellitus. International Journal of Pharmaceutical Sciences Review and Research.
77 Haak T, Meinicke T, Jones R, et al. (2012). Initial combination of linagliptin and metformin improves glycaemic control in type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab.
78 Haak T, Meinicke T, Jones R, et al. (2013). Initial combination of linagliptin and metformin in patients with type 2 diabetes: efficacy and safety in a randomised, double-blind 1-year extension study. Int J Clin Pract.
79 Hallsten K, Virtanen KA, Lonnqvist F, et al. (2002). Rosiglitazone but not metformin enhances insulin- and exercise-stimulated skeletal muscle glucose uptake in patients with newly diagnosed type 2 diabetes. Diabetes.
80 Hamann A, Garcia-Puig J, Paul G, et al. (2008). Comparison of fixed-dose rosiglitazone/metformin combination therapy with sulphonylurea plus metformin in overweight individuals with Type 2 diabetes inadequately controlled on metformin alone. Exp Clin Endocrinol Diabetes.
81 Hanefeld M, Brunetti P, Schernthaner GH, et al. (2004). One-year glycemic control with a sulfonylurea plus pioglitazone versus a sulfonylurea plus metformin in patients with type 2 diabetes. Diabetes Care.
82 Hanefeld M, Patwardhan R, Jones NP. (2007). A one-year study comparing the efficacy and safety of rosiglitazone and glibenclamide in the treatment of type 2 diabetes. Nutr Metab Cardiovasc Dis.
83 Haring HU, Merker L, Seewaldt-Becker E, et al. (2014). Empaglif lozin as add-on to metformin in patients with type 2 diabetes: A 24-week, randomized, double-blind, placebo-controlled trial. Diabetes Care.
84 Henry RR, Murray AV, Marmolejo MH, et al. (2012). Dapagliflozin, metformin XR, or both: initial pharmacotherapy for type 2 diabetes, a randomised controlled trial. Int J Clin Pract.
85 Hermann LS, Bitzen PO, Kjellstrom T, et al. (1991). Comparative efficacy of metformin and glibenclamide in patients with non-insulin-dependent diabetes mellitus. Diabete Metab.
86 Hermann LS, Schersten B, Bitzen PO, et al. (1994). Therapeutic comparison of metformin and sulfonylurea, alone and in various combinations. A double-blind controlled study. Diabetes Care.
87 Hermans MP, Delibasi T, Farmer I, et al. (2012). Effects of saxagliptin added to sub-maximal doses of metformin compared with uptitration of metformin in type 2 diabetes: the PROMPT study. Curr Med Res Opin.
88 Home PD, Jones NP, Pocock SJ, et al. (2007). Rosiglitazone RECORD study: glucose control outcomes at 18 months. Diabet Med.
89 Home PD, Pocock SJ, Beck-Nielsen H, et al. (2009). Rosiglitazone evaluated for cardiovascular outcomes in oral agent combination therapy for type 2 diabetes (RECORD): a multicentre, randomised, open-label trial. Lancet.
90 Iliadis F, Kadoglou NP, Hatzitolios A, et al. (2007). Metabolic effects of rosiglitazone and metformin in Greek patients with recently diagnosed type 2 diabetes. In Vivo.
91 Jadzinsky M, Pfutzner A, Paz-Pacheco E, et al. (2009). Saxagliptin given in combination with metformin as initial therapy improves glycaemic control in patients with type 2 diabetes compared with either monotherapy: a randomized controlled trial. Diabetes Obes Metab.
92 Jain R, Osei K, Kupfer S, et al. (2006). Long-term safety of pioglitazone versus glyburide in patients with recently diagnosed type 2 diabetes mellitus. Pharmacotherapy.
93 Ji L, Zinman B, Patel S, et al. (2015). Efficacy and safety of linagliptin co-administered with low-dose metformin once daily versus high-dose metformin twice daily in treatment-naive patients with type 2 diabetes: a double-blind randomized trial. Adv Ther.
94 Jonker JT, Meer RWVD, Rijzewijk LJ, et al. (2009). A differential effect of pioglitazone versus metformin on fat depots in patients with type 2 diabetes mellitus. Diabetes.
95 Kadoglou NP, Kapelouzou A, Tsanikidis H, et al. (2011). Effects of rosiglitazone/metformin fixed-dose combination therapy and metformin monotherapy on serum vaspin, adiponectin and IL-6 levels in drug-naive patients with type 2 diabetes. Exp Clin Endocrinol Diabetes.
96 Kadowaki T, Tajima N, Odawara M, et al. (2013). Addition of sitagliptin to ongoing metformin monotherapy improves glycemic control in Japanese patients with type 2 diabetes over 52 weeks. J Diabetes Investig.
97 Kahn SE, Haffner SM, Heise MA, et al. (2006). Glycemic durability of rosiglitazone, metformin, or glyburide monotherapy. N Engl J Med.
98 Kaku K. (2009). Efficacy and safety of therapy with metformin plus pioglitazone in the treatment of patients with type 2 diabetes: a double-blind, placebo-controlled, clinical trial. Curr Med Res Opin.
99 Kaku K, Rasmussen MF, Nishida T, et al. (2011). Fifty-two-week, randomized, multicenter trial to compare the safety and efficacy of the novel glucagon-like peptide-1 analog liraglutide vs glibenclamide in patients with type 2 diabetes. J Diabetes Investig.
100 Kato T, Sawai Y, Kanayama H, et al. (2009). Comparative study of low-dose pioglitazone or metformin treatment in Japanese diabetic patients with metabolic syndrome. Exp Clin Endocrinol Diabetes.
101 Kikuchi M, Kaku K, Odawara M, et al. (2012). Efficacy and tolerability of rosiglitazone and pioglitazone in drug-naive Japanese patients with type 2 diabetes mellitus: a double-blind, 28 weeks' treatment, comparative study. Curr Med Res Opin.
102 Kim HJ, Kang ES, Kim DJ, et al. (2007). Effects of rosiglitazone and metformin on inflammatory markers and adipokines: decrease in interleukin-18 is an independent factor for the improvement of homeostasis model assessment-beta in type 2 diabetes mellitus. Clin Endocrinol (Oxf).
103 Kim HS, Kim DM, Cha BS, et al. (2014). Efficacy of glimepiride/metformin fixed-dose combination vs metformin uptitration in type 2 diabetic patients inadequately controlled on low-dose metformin monotherapy: A randomized, open label, parallel group, multicenter study in Korea. Journal of Diabetes Investigation.
104 Kiyici S, Ersoy C, Kaderli A, et al. (2009). Effect of rosiglitazone, metformin and medical nutrition treatment on arterial stiffness, serum MMP-9 and MCP-1 levels in drug naive type 2 diabetic patients. Diabetes Research and Clinical Practice.
105 Kvapil M, Swatko A, Hilberg C, et al. (2006). Biphasic insulin aspart 30 plus metformin: an effective combination in type 2 diabetes. Diabetes Obes Metab.
106 Lavalle-Gonzalez FJ, Januszewicz A, Davidson J, et al. (2013). Efficacy and safety of canagliflozin compared with placebo and sitagliptin in patients with type 2 diabetes on background metformin monotherapy: a randomised trial. Diabetologia.
107 Lawrence JM, Reid J, Taylor GJ, et al. (2004). Favorable effects of pioglitazone and metformin compared with gliclazide on lipoprotein subfractions in overweight patients with early type 2 diabetes. Diabetes Care.
108 Leiter LA, Harris SB, Chiasson J-L, et al. (2005). Efficacy and safety of Rosiglitazone as monotherapy or in combination with metformin in primary care settings. Can J Diabetes.
109 List JF, Woo V, Morales E, et al. (2009). Sodium-glucose cotransport inhibition with dapagliflozin in type 2 diabetes. Diabetes Care.
110 Madsbad S, Schmitz O, Ranstam J, et al. (2004). Improved glycemic control with no weight increase in patients with type 2 diabetes after once-daily treatment with the long-acting glucagon-like peptide 1 analog liraglutide (NN2211): a 12-week, double-blind, randomized, controlled trial. Diabetes Care.
111 Maffioli P, Fogari E, D'Angelo A, et al. (2013). Ultrasonography modifications of visceral and subcutaneous adipose tissue after pioglitazone or glibenclamide therapy combined with rosuvastatin in type 2 diabetic patients not well controlled by metformin. Eur J Gastroenterol Hepatol.
112 Malone JK, Beattie SD, Campaigne BN, et al. (2003). Therapy after single oral agent failure: adding a second oral agent or an insulin mixture?. Diabetes Res Clin Pract.
113 Marre M, Howlett H, Lehert P, et al. (2002). Improved glycaemic control with metformin-glibenclamide combined tablet therapy (Glucovance) in Type 2 diabetic patients inadequately controlled on metformin. Diabet Med.
114 Moon JS, Ha KS, Yoon JS, et al. (2014). The effect of glargine versus glimepiride on pancreatic beta-cell function in patients with type 2 diabetes uncontrolled on metformin monotherapy: open-label, randomized, controlled study. Acta Diabetol.
115 Nakamura T, Ushiyama C, Shimada N, et al. (2000). Comparative effects of pioglitazone, glibenclamide, and voglibose on urinary endothelin-1 and albumin excretion in diabetes patients. J Diabetes Complications.
116 Nakamura T, Matsuda T, Kawagoe Y, et al. (2004). Effect of pioglitazone on carotid intima-media thickness and arterial stiffness in type 2 diabetic nephropathy patients. Metabolism.
117 Natali A, Baldeweg S, Toschi E, et al. (2004). Vascular effects of improving metabolic control with metformin or rosiglitazone in type 2 diabetes. Diabetes Care.
118 Nauck MA, Meininger G, Sheng D, et al. (2007). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor, sitagliptin, compared with the sulfonylurea, glipizide, in patients with type 2 diabetes inadequately controlled on metformin alone: a randomized, double-blind, non-inferiority trial. Diabetes Obes Metab.
119 Nauck MA, Ellis GC, Fleck PR, et al. (2009). Efficacy and safety of adding the dipeptidyl peptidase-4 inhibitor alogliptin to metformin therapy in patients with type 2 diabetes inadequately controlled with metformin monotherapy: a multicentre, randomised, double-blind, placebo-controlled study. Int J Clin Pract.
120 Nauck MA, Del Prato S, Meier JJ, et al. (2011). Dapagliflozin versus glipizide as add-on therapy in patients with type 2 diabetes who have inadequate glycemic control with metformin: a randomized, 52-week, double-blind, active-controlled noninferiority trial. Diabetes Care.
121 Nauck M, Weinstock RS, Umpierrez GE, et al. (2014). Efficacy and Safety of Dulaglutide Versus Sitagliptin After 52 Weeks in Type 2 Diabetes in a Randomized Controlled Trial (AWARD-5). Diabetes Care.
122 Oz Gul O, Tuncel E, Yilmaz Y, et al. (2010). Comparative effects of pioglitazone and rosiglitazone on plasma levels of soluble receptor for advanced glycation end products in type 2 diabetes mellitus patients. Metabolism.
123 Pavo I, Jermendy G, Varkonyi TT, et al. (2003). Effect of pioglitazone compared with metformin on glycemic control and indicators of insulin sensitivity in recently diagnosed patients with type 2 diabetes. J Clin Endocrinol Metab.
124 Perez-Monteverde A, Seck T, Xu L, et al. (2011). Efficacy and safety of sitagliptin and the fixed-dose combination of sitagliptin and metformin vs. pioglitazone in drug-naive patients with type 2 diabetes. Int J Clin Pract.
125 Perez A, Zhao Z, Jacks R, et al. (2009). Efficacy and safety of pioglitazone/metformin fixed-dose combination therapy compared with pioglitazone and metformin monotherapy in treating patients with T2DM. Curr Med Res Opin.
126 Petrica L, Petrica M, Vlad A, et al. (2009). Nephro- and neuroprotective effects of rosiglitazone versus glimepiride in normoalbuminuric patients with type 2 diabetes mellitus: a randomized controlled trial. Wien Klin Wochenschr.
127 Pfutzner A, Marx N, Lubben G, et al. (2005). Improvement of cardiovascular risk markers by pioglitazone is independent from glycemic control: results from the pioneer study. J Am Coll Cardiol.
128 Pfutzner A, Schondorf T, Tschope D, et al. (2011). PIOfix-study: effects of pioglitazone/metformin fixed combination in comparison with a combination of metformin with glimepiride on diabetic dyslipidemia. Diabetes Technol Ther.
129 Pfutzner A, Paz-Pacheco E, Allen E, et al. (2011). Initial combination therapy with saxagliptin and metformin provides sustained glycaemic control and is well tolerated for up to 76 weeks. Diabetes Obes Metab.
130 Pratley RE, Nauck M, Bailey T, et al. (2010). Liraglutide versus sitagliptin for patients with type 2 diabetes who did not have adequate glycaemic control with metformin: a 26-week, randomised, parallel-group, open-label trial. Lancet.
131 Pratley RE, Fleck P, Wilson C. (2014). Efficacy and safety of initial combination therapy with alogliptin plus metformin versus either as monotherapy in drug-naive patients with type 2 diabetes: a randomized, double-blind, 6-month study. Diabetes Obes Metab.
132 Qiu R, Capuano G, Meininger G. (2014). Efficacy and safety of twice-daily treatment with canagliflozin, a sodium glucose co-transporter 2 inhibitor, added on to metformin monotherapy in patients with type 2 diabetes mellitus. Journal of Clinical and Translational Endocrinology.
133 Ramachandran A, Snehalatha C, Salini J, et al. (2004). Use of glimepiride and insulin sensitizers in the treatment of type 2 diabetes--a study in Indians. J Assoc Physicians India.
134 Raskin PR, Hollander PA, Lewin A, et al. (2007). Basal insulin or premix analogue therapy in type 2 diabetes patients. Eur J Intern Med.
135 Reasner C, Olansky L, Seck TL, et al. (2011). The effect of initial therapy with the fixed-dose combination of sitagliptin and metformin compared with metformin monotherapy in patients with type 2 diabetes mellitus. Diabetes Obes Metab.
136 Ridderstrale M, Andersen KR, Zeller C, et al. (2014). Comparison of empagliflozin and glimepiride as add-on to metformin in patients with type 2 diabetes: a 104-week randomised, active-controlled, double-blind, phase 3 trial. The Lancet Diabetes and Endocrinology.
137 Rigby SP, Handelsman Y, Lai YL, et al. (2010). Effects of colesevelam, rosiglitazone, or sitagliptin on glycemic control and lipid profile in patients with type 2 diabetes mellitus inadequately controlled by metformin monotherapy. Endocr Pract.
138 Robbins DC, Beisswenger PJ, Ceriello A, et al. (2007). Mealtime 50/50 basal + prandial insulin analogue mixture with a basal insulin analogue, both plus metformin, in the achievement of target HbA1c and pre- and postprandial blood glucose levels in patients with type 2 diabetes: a multinational, 24-week, randomized, open-label, parallel-group comparison. Clin Ther.
139 Roden M, Weng J, Eilbracht J, et al. (2013). Empagliflozin monotherapy with sitagliptin as an active comparator in patients with type 2 diabetes: A randomised, double-blind, placebo-controlled, phase 3 trial. The Lancet Diabetes and Endocrinology.
140 Rosenstock J, Rood J, Cobitz A, et al. (2006). Initial treatment with rosiglitazone/metformin fixed-dose combination therapy compared with monotherapy with either rosiglitazone or metformin in patients with uncontrolled type 2 diabetes. Diabetes Obes Metab.
141 Rosenstock J, Inzucchi SE, Seufert J, et al. (2010). Initial combination therapy with alogliptin and pioglitazone in drug-naive patients with type 2 diabetes. Diabetes Care.
142 Rosenstock J, Aggarwal N, Polidori D, et al. (2012). Dose-ranging effects of canagliflozin, a sodium-glucose cotransporter 2 inhibitor, as add-on to metformin in subjects with type 2 diabetes. Diabetes Care.
143 Rosenstock J, Wilson C, Fleck P. (2013). Alogliptin versus glipizide monotherapy in elderly type 2 diabetes mellitus patients with mild hyperglycaemia: a prospective, double-blind, randomized, 1-year study. Diabetes Obes Metab.
144 Rosenstock J, Seman LJ, Jelaska A, et al. (2013). Efficacy and safety of empagliflozin, a sodium glucose cotransporter 2 (SGLT2) inhibitor, as add-on to metformin in type 2 diabetes with mild hyperglycaemia. Diabetes Obes Metab.
145 Rosenstock J, Hansen L, Zee P, et al. (2015). Dual Add-on Therapy in Type 2 Diabetes Poorly Controlled With Metformin Monotherapy: A Randomized Double-Blind Trial of Saxagliptin Plus Dapagliflozin Addition Versus Single Addition of Saxagliptin or Dapagliflozin to Metformin. Diabetes Care.
146 Ross SA, Rafeiro E, Meinicke T, et al. (2012). Efficacy and safety of linagliptin 25?mg twice daily versus 5?mg once daily in patients with type 2 diabetes inadequately controlled on metformin: a randomised, double-blind, placebo-controlled trial. Curr Med Res Opin.
147 Russell-Jones D, Cuddihy RM, Hanefeld M, et al. (2012). Efficacy and safety of exenatide once weekly versus metformin, pioglitazone, and sitagliptin used as monotherapy in drug-naive patients with type 2 diabetes (DURATION-4): a 26-week double-blind study. Diabetes Care.
148 Schernthaner G, Duran-Garcia S, Hanefeld M, et al. (2015). Efficacy and tolerability of saxagliptin compared with glimepiride in elderly patients with type 2 diabetes: a randomized, controlled study (GENERATION). Diabetes Obes Metab.
149 Schernthaner G, Matthews DR, Charbonnel B, et al. (2004). Efficacy and safety of pioglitazone versus metformin in patients with type 2 diabetes mellitus: a double-blind, randomized trial. J Clin Endocrinol Metab.
150 Schondorf T, Musholt PB, Hohberg C, et al. (2011). The fixed combination of pioglitazone and metformin improves biomarkers of platelet function and chronic inflammation in type 2 diabetes patients: results from the PIOfix study. J Diabetes Sci Technol.
151 Schumm-Draeger PM, Burgess L, Koranyi L, et al. (2015). Twice-daily dapagliflozin co-administered with metformin in type 2 diabetes: a 16-week randomized, placebo-controlled clinical trial. Diabetes Obes Metab.
152 Scott R, Wu M, Sanchez M, et al. (2007). Efficacy and tolerability of the dipeptidyl peptidase-4 inhibitor sitagliptin as monotherapy over 12 weeks in patients with type 2 diabetes. Int J Clin Pract.
153 Scott R, Loeys T, Davies MJ, et al. (2008). Efficacy and safety of sitagliptin when added to ongoing metformin therapy in patients with type 2 diabetes. Diabetes Obes Metab.
154 Seck T, Nauck M, Sheng D, et al. (2010). Safety and efficacy of treatment with sitagliptin or glipizide in patients with type 2 diabetes inadequately controlled on metformin: a 2-year study. Int J Clin Pract.
155 Seino Y, Rasmussen MF, Nishida T, et al. (2010). Efficacy and safety of the once-daily human GLP-1 analogue, liraglutide, vs glibenclamide monotherapy in Japanese patients with type 2 diabetes. Curr Med Res Opin.
156 Seino Y, Miyata Y, Hiroi S, et al. (2012). Efficacy and safety of alogliptin added to metformin in Japanese patients with type 2 diabetes: a randomized, double-blind, placebo-controlled trial with an open-label, long-term extension study. Diabetes Obes Metab.
157 Shihara N, Kitaoka M, Inagaki N, et al. (2011). Randomized controlled trial of single-agent glimepiride and pioglitazone in Japanese patients with type 2 diabetes: A comparative study. J Diabetes Investig.
158 Srivastava S, Saxena GN, Keshwani P, et al. (2012). Comparing the efficacy and safety profile of sitagliptin versus glimepiride in patients of type 2 diabetes mellitus inadequately controlled with metformin alone. J Assoc Physicians India.
159 St John Sutton M, Rendell M, Dandona P, et al. (2002). A comparison of the effects of rosiglitazone and glyburide on cardiovascular function and glycemic control in patients with type 2 diabetes. Diabetes Care.
160 Stewart MW, Cirkel DT, Furuseth K, et al. (2006). Effect of metformin plus roziglitazone compared with metformin alone on glycaemic control in well-controlled Type 2 diabetes. Diabet Med.
161 Suzuki K, Tanaka S, Aoki C, et al. (2014). Greater efficacy and improved endothelial dysfunction in untreated type 2 diabetes with liraglutide versus sitagliptin. Dokkyo Journal of Medical Sciences.
162 Tan MH, Johns D, Strand J, et al. (2004). Sustained effects of pioglitazone vs. glibenclamide on insulin sensitivity, glycaemic control, and lipid profiles in patients with Type 2 diabetes. Diabet Med.
163 Tan M, Johns D, Gonzalez Galvez G, et al. (2004). Effects of pioglitazone and glimepiride on glycemic control and insulin sensitivity in Mexican patients with type 2 diabetes mellitus: A multicenter, randomized, double-blind, parallel-group trial. Clin Ther.
164 Taskinen MR, Rosenstock J, Tamminen I, et al. (2011). Safety and efficacy of linagliptin as add-on therapy to metformin in patients with type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab.
165 Taslimi S, Esteghamati A, Rashidi A, et al. (2013). Treatment with pioglitazone is associated with decreased preprandial ghrelin levels: a randomized clinical trial. Peptides.
166 Teramoto T, Yamada N, Shirai K, et al. (2007). Effects of pioglitazone hydrochloride on Japanese patients with type 2 diabetes mellitus. J Atheroscler Thromb.
167 Tosi F, Muggeo M, Brun E, et al. (2003). Combination treatment with metformin and glibenclamide versus single-drug therapies in type 2 diabetes mellitus: a randomized, double-blind, comparative study. Metabolism.
168 Turkmen Kemal Y, Guvener Demirag N, Yildirir A, et al. (2007). Effects of rosiglitazone on plasma brain natriuretic peptide levels and myocardial performance index in patients with type 2 diabetes mellitus. Acta Diabetol.
169 Turner RC, Cull CA, Frighi V, et al. (1999). Glycemic control with diet, sulfonylurea, metformin, or insulin in patients with type 2 diabetes mellitus: progressive requirement for multiple therapies (UKPDS 49). UK Prospective Diabetes Study (UKPDS) Group. JAMA.
170 Umpierrez G, Issa M, Vlajnic A. (2006). Glimepiride versus pioglitazone combination therapy in subjects with type 2 diabetes inadequately controlled on metformin monotherapy: results of a randomized clinical trial. Curr Med Res Opin.
171 Umpierrez G, Povedano ST, Manghi FP, et al. (2014). Efficacy and Safety of Dulaglutide Monotherapy Versus Metformin in Type 2 Diabetes in a Randomized Controlled Trial (AWARD-3). Diabetes Care.
172 van der Meer RW, Rijzewijk LJ, de Jong HW, et al. (2009). Pioglitazone improves cardiac function and alters myocardial substrate metabolism without affecting cardiac triglyceride accumulation and high-energy phosphate metabolism in patients with well-controlled type 2 diabetes mellitus. Circulation.
173 Wang W, Yang J, Yang G, et al. (2015). Efficacy and safety of linagliptin in Asian patients with type 2 diabetes mellitus inadequately controlled by metformin: A multinational 24-week, randomized clinical trial. J Diabetes.
174 Weissman P, Goldstein BJ, Rosenstock J, et al. (2005). Effects of rosiglitazone added to submaximal doses of metformin compared with dose escalation of metformin in type 2 diabetes: the EMPIRE Study. Curr Med Res Opin.
175 White JL, Buchanan P, Li J, et al. (2014). A randomized controlled trial of the efficacy and safety of twice-daily saxagliptin plus metformin combination therapy in patients with type 2 diabetes and inadequate glycemic control on metformin monotherapy. BMC Endocr Disord.
176 Williams-Herman D, Johnson J, Teng R, et al. (2009). Efficacy and safety of initial combination therapy with sitagliptin and metformin in patients with type 2 diabetes: a 54-week study. Curr Med Res Opin.
177 Williams-Herman D, Johnson J, Teng R, et al. (2010). Efficacy and safety of sitagliptin and metformin as initial combination therapy and as monotherapy over 2 years in patients with type 2 diabetes. Diabetes Obes Metab.
178 Xu W, Bi Y, Sun Z, et al. (2015). Comparison of the effects on glycaemic control and beta-cell function in newly diagnosed type 2 diabetes patients of treatment with exenatide, insulin or pioglitazone: a multicentre randomized parallel-group trial (the CONFIDENCE study). J Intern Med.
179 Yamanouchi T, Sakai T, Igarashi K, et al. (2005). Comparison of metabolic effects of pioglitazone, metformin, and glimepiride over 1 year in Japanese patients with newly diagnosed Type 2 diabetes. Diabet Med.
180 Yang W, Pan CY, Tou C, et al. (2011). Efficacy and safety of saxagliptin added to metformin in Asian people with type 2 diabetes mellitus: a randomized controlled trial. Diabetes Res Clin Pract.
181 Yang W, Chen L, Ji Q, et al. (2011). Liraglutide provides similar glycaemic control as glimepiride (both in combination with metformin) and reduces body weight and systolic blood pressure in Asian population with type 2 diabetes from China, South Korea and India: a 16-week, randomized, double-blind, active control trial(*). Diabetes Obes Metab.
182 Yang W, Guan Y, Shentu Y, et al. (2012). The addition of sitagliptin to ongoing metformin therapy significantly improves glycemic control in Chinese patients with type 2 diabetes. J Diabetes.
183 Yoon KH, Shin JA, Kwon HS, et al. (2011). Comparison of the efficacy of glimepiride, metformin, and rosiglitazone monotherapy in korean drug-naive type 2 diabetic patients: the practical evidence of antidiabetic monotherapy study. Diabetes Metab J.
184 Yuan GH, Song WL, Huang YY, et al. (2012). Efficacy and tolerability of exenatide monotherapy in obese patients with newly diagnosed type 2 diabetes: a randomized, 26 weeks metformin-controlled, parallel-group study. Chin Med J (Engl).
185 Nakamura T, Sugaya T, Kawagoe Y, et al. (2006). Effect of pioglitazone on urinary liver-type fatty acid-binding protein concentrations in diabetes patients with microalbuminuria. Diabetes Metab Res Rev.
186 Amador-Licona N, Guizar-Mendoza J, Vargas E, et al. (2000). The short-term effect of a switch from glibenclamide to metformin on blood pressure and microalbuminuria in patients with type 2 diabetes mellitus. Arch Med Res.
187 Zhang H, Zhang X, Hu C, et al. (2012). Exenatide reduces urinary transforming growth factor-beta1 and type IV collagen excretion in patients with type 2 diabetes and microalbuminuria. Kidney Blood Press Res.
188 Raz I, Chen Y, Wu M, et al. (2008). Efficacy and safety of sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes. Curr Med Res Opin.
189 Agarwal R, Saha C, Battiwala M, et al. (2005). A pilot randomized controlled trial of renal protection with pioglitazone in diabetic nephropathy. Kidney Int.
190 Andersson C, Olesen JB, Hansen PR, et al. (2010). Metformin treatment is associated with a low risk of mortality in diabetic patients with heart failure: a retrospective nationwide cohort study. Diabetologia.
191 Brownstein JS, Murphy SN, Goldfine AB, et al. (2010). Rapid identification of myocardial infarction risk associated with diabetes medications using electronic medical records. Diabetes Care.
192 Corrao G, Romio SA, Zambon A, et al. (2011). Multiple outcomes associated with the use of metformin and sulphonylureas in type 2 diabetes: a population-based cohort study in Italy. Eur J Clin Pharmacol.
193 Ekstrom N, Schioler L, Svensson AM, et al. (2012). Effectiveness and safety of metformin in 51 675 patients with type 2 diabetes and different levels of renal function: a cohort study from the Swedish National Diabetes Register. BMJ Open.
194 Ferrannini E, Seman L, Seewaldt-Becker E, et al. (2013). A Phase IIb, randomized, placebo-controlled study of the SGLT2 inhibitor empagliflozin in patients with type 2 diabetes. Diabetes, Obesity and Metabolism.
195 Hong J, Zhang Y, Lai S, et al. (2013). Effects of metformin versus glipizide on cardiovascular outcomes in patients with type 2 diabetes and coronary artery disease. Diabetes Care.
196 Horsdal HT, Sondergaard F, Johnsen SP, et al. (2011). Antidiabetic treatments and risk of hospitalisation with myocardial infarction: a nationwide case-control study. Pharmacoepidemiol Drug Saf.
197 Hsiao FY. (2009). Does cardiovascular risk decrease after discontinuing rosiglitazone use? Early and late effects of rosiglitazone on the risk of myocardial infarction in type 2 diabetic patients. Drug Information Journal.
198 Hung AM, Roumie CL, Greevy RA, et al. (2012). Comparative effectiveness of incident oral antidiabetic drugs on kidney function. Kidney Int.
199 Hung YC, Lin CC, Wang TY, et al. (2013). Oral hypoglycaemic agents and the development of non-fatal cardiovascular events in patients with type 2 diabetes mellitus. Diabetes Metab Res Rev.
200 Hung AM, Roumie CL, Greevy RA, et al. (2013). Kidney function decline in metformin versus sulfonylurea initiators: assessment of time-dependent contribution of weight, blood pressure, and glycemic control. Pharmacoepidemiol Drug Saf.
201 Johnson JA, Simpson SH, Toth EL, et al. (2005). Reduced cardiovascular morbidity and mortality associated with metformin use in subjects with Type 2 diabetes. Diabet Med.
202 Jones TA, Sautter M, Van Gaal LF, et al. (2003). Addition of rosiglitazone to metformin is most effective in obese, insulin-resistant patients with type 2 diabetes. Diabetes Obes Metab.
203 Kahler KH, Rajan M, Rhoads GG, et al. (2007). Impact of oral antihyperglycemic therapy on all-cause mortality among patients with diabetes in the Veterans Health Administration. Diabetes Care.
204 Malone JK, Kerr LF, Campaigne BN, et al. (2004). Combined therapy with insulin lispro Mix 75/25 plus metformin or insulin glargine plus metformin: a 16-week, randomized, open-label, crossover study in patients with type 2 diabetes beginning insulin therapy. Clin Ther.
205 Malone JK, Bai S, Campaigne BN, et al. (2005). Twice-daily pre-mixed insulin rather than basal insulin therapy alone results in better overall glycaemic control in patients with Type 2 diabetes. Diabet Med.
206 Masica AL, Ewen E, Daoud YA, et al. (2013). Comparative effectiveness research using electronic health records: impacts of oral antidiabetic drugs on the development of chronic kidney disease. Pharmacoepidemiol Drug Saf.
207 Mogensen UM, Andersson C, Fosbol EL, et al. (2014). Cardiovascular safety of combination therapies with incretin-based drugs and metformin compared with a combination of metformin and sulphonylurea in type 2 diabetes mellitus - a retrospective nationwide study. Diabetes Obes Metab.
208 Pantalone KM, Kattan MW, Yu C, et al. (2009). The risk of developing coronary artery disease or congestive heart failure, and overall mortality, in type 2 diabetic patients receiving rosiglitazone, pioglitazone, metformin, or sulfonylureas: a retrospective analysis. Acta Diabetol.
209 Pantalone KM, Kattan MW, Yu C, et al. (2012). Increase in overall mortality risk in patients with type 2 diabetes receiving glipizide, glyburide or glimepiride monotherapy versus metformin: a retrospective analysis. Diabetes Obes Metab.
210 Roumie CL, Hung AM, Greevy RA, et al. (2012). Comparative effectiveness of sulfonylurea and metformin monotherapy on cardiovascular events in type 2 diabetes mellitus: a cohort study. Ann Intern Med.
211 Scheller NM, Mogensen UM, Andersson C, et al. (2014). All-cause mortality and cardiovascular effects associated with the DPP-IV inhibitor sitagliptin compared with metformin, a retrospective cohort study on the Danish population. Diabetes, Obesity and Metabolism.
212 Schramm TK, Gislason GH, Vaag A, et al. (2011). Mortality and cardiovascular risk associated with different insulin secretagogues compared with metformin in type 2 diabetes, with or without a previous myocardial infarction: a nationwide study. Eur Heart J.
213 Stenlof K, Cefalu WT, Kim KA, et al. (2014). Long-term efficacy and safety of canagliflozin monotherapy in patients with type 2 diabetes inadequately controlled with diet and exercise: findings from the 52-week CANTATA-M study. Curr Med Res Opin.
214 Wheeler S, Moore K, Forsberg CW, et al. (2013). Mortality among veterans with type 2 diabetes initiating metformin, sulfonylurea or rosiglitazone monotherapy. Diabetologia.
215 Hsiao FY, Huang WF, Wen YW, et al. (2009). Thiazolidinediones and cardiovascular events in patients with type 2 diabetes mellitus: a retrospective cohort study of over 473,000 patients using the National Health Insurance database in Taiwan. Drug Saf.
216 Curkendall SM, Zhang B, Lenhart G, et al. (2014). Rate of hypoglycemia in patients with type 2 diabetes receiving metformin plus saxagliptin versus metformin plus sulfonylurea: A retrospective observational cohort study using administrative claims data. Expert Review of Endocrinology and Metabolism.
217 Currie CJ, Poole CD, Gale EA. (2009). The influence of glucose-lowering therapies on cancer risk in type 2 diabetes. Diabetologia.
218 Davies M, Heller S, Sreenan S, et al. (2013). Once-weekly exenatide versus once- or twice-daily insulin detemir: randomized, open-label, clinical trial of efficacy and safety in patients with type 2 diabetes treated with metformin alone or in combination with sulfonylureas. Diabetes Care.
219 Dormuth CR, Carney G, Carleton B, et al. (2009). Thiazolidinediones and fractures in men and women. Arch Intern Med.
220 Kahn SE, Zinman B, Lachin JM, et al. (2008). Rosiglitazone-associated fractures in type 2 diabetes: an Analysis from A Diabetes Outcome Progression Trial (ADOPT). Diabetes Care.
221 Karter AJ, Ahmed AT, Liu J, et al. (2005). Pioglitazone initiation and subsequent hospitalization for congestive heart failure. Diabet Med.
222 Komajda M, McMurray JJ, Beck-Nielsen H, et al. (2010). Heart failure events with rosiglitazone in type 2 diabetes: data from the RECORD clinical trial. Eur Heart J.
223 Lee YK, Song SO, Kim KJ, et al. (2013). Glycemic Effectiveness of Metformin-Based Dual-Combination Therapies with Sulphonylurea, Pioglitazone, or DPP4-Inhibitor in Drug-Naive Korean Type 2 Diabetic Patients. Diabetes Metab J.
224 Lehman DM, Lorenzo C, Hernandez J, et al. (2012). Statin use as a moderator of metformin effect on risk for prostate cancer among type 2 diabetic patients. Diabetes Care.
225 Rajagopalan R, Iyer S, Perez A. (2005). Comparison of pioglitazone with other antidiabetic drugs for associated incidence of liver failure: no evidence of increased risk of liver failure with pioglitazone. Diabetes Obes Metab.
226 Skrivanek Z, Gaydos BL, Chien JY, et al. (2014). Dose-finding results in an adaptive, seamless, randomized trial of once-weekly dulaglutide combined with metformin in type 2 diabetes patients (AWARD-5). Diabetes Obes Metab.
227 Weir MA, Gomes T, Mamdani M, et al. (2011). Impaired renal function modifies the risk of severe hypoglycaemia among users of insulin but not glyburide: a population-based nested case-control study. Nephrol Dial Transplant.
228 Wright AD, Cull CA, Macleod KM, et al. (2006). Hypoglycemia in Type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications.
229 Bunck MC, Diamant M, Corner A, et al. (2009). One-year treatment with exenatide improves beta-cell function, compared with insulin glargine, in metformin-treated type 2 diabetic patients: a randomized, controlled trial. Diabetes Care.
230 van Staa TP, Patel D, Gallagher AM, et al. (2012). Glucose-lowering agents and the patterns of risk for cancer: a study with the General Practice Research Database and secondary care data. Diabetologia.
231 Kawai T, Funae O, Shimada A, et al. (2008). Effects of pretreatment with low-dose metformin on metabolic parameters and weight gain by pioglitazone in Japanese patients with type 2 diabetes. Intern Med.
232 Gallwitz B, Rosenstock J, Patel S, et al. (2015). Regardless of the degree of glycaemic control, linagliptin has lower hypoglycaemia risk than all doses of glimepiride, at all time points, over the course of a 2-year trial. Diabetes Obes Metab.
233 (1998). United Kingdom Prospective Diabetes Study 24: a 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. United Kingdom Prospective Diabetes Study Group. Ann Intern Med.
234 Leiter LA, Carr MC, Stewart M, et al. (2014). Efficacy and safety of the once-weekly GLP-1 receptor agonist albiglutide versus sitagliptin in patients with type 2 diabetes and renal impairment: a randomized phase III study. Diabetes Care.
235 Merker L, Haering HU, Christiansen AV. (2014). LBSU-1082: Empagliflozin (EMPA) for >= 76 weeks as add-on to metformin un patients with type 2 diabetes (T2DM).
236 Belcher G, Lambert C, Goh KL, et al. (2004). Cardiovascular effects of treatment of type 2 diabetes with pioglitazone, metformin and gliclazide. Int J Clin Pract.
237 Lester JW, Fernandes AW. (2005). Pioglitazone in a subgroup of patients with type 2 diabetes meeting the criteria for metabolic syndrome. Int J Clin Pract.
238 Belcher G, Schernthaner G. (2005). Changes in liver tests during 1-year treatment of patients with Type 2 diabetes with pioglitazone, metformin or gliclazide. Diabet Med.
239 Belcher G, Lambert C, Edwards G, et al. (2005). Safety and tolerability of pioglitazone, metformin, and gliclazide in the treatment of type 2 diabetes. Diabetes Res Clin Pract.
240 Charbonnel B, Schernthaner G, Brunetti P, et al. (2005). Long-term efficacy and tolerability of add-on pioglitazone therapy to failing monotherapy compared with addition of gliclazide or metformin in patients with type 2 diabetes. Diabetologia.
241 Ceriello A, Johns D, Widel M, et al. (2005). Comparison of effect of pioglitazone with metformin or sulfonylurea (monotherapy and combination therapy) on postload glycemia and composite insulin sensitivity index during an oral glucose tolerance test in patients with type 2 diabetes. Diabetes Care.
242 Rendell MS, Glazer NB, Ye Z. (2003). Combination therapy with pioglitazone plus metformin or sulfonylurea in patients with Type 2 diabetes: influence of prior antidiabetic drug regimen. J Diabetes Complications.
243 Del Prato S, Taskinen MR, Owens DR, et al. (2013). Efficacy and safety of linagliptin in subjects with type 2 diabetes mellitus and poor glycemic control: pooled analysis of data from three placebo-controlled phase III trials. J Diabetes Complications.
244 Sjostrand M, Iqbal N, Lu J, et al. (2014). Saxagliptin improves glycemic control by modulating postprandial glucagon and C-peptide levels in Chinese patients with type 2 diabetes. Diabetes Res Clin Pract.
245 Davidson JA. (2014). Tolerability of saxagliptin in patients with inadequately controlled type 2 diabetes: results from 6 phase III studies. J Manag Care Pharm.
246 Grimm M, Li Y, Brunell SC, et al. (2013). Exenatide once weekly versus daily basal insulin as add-on treatment to metformin with or without a sulfonylurea: a retrospective pooled analysis in patients with poor glycemic control. Postgrad Med.
247 Rosenstock J, Gross JL, Aguilar-Salinas C, et al. (2013). Long-term 4-year safety of saxagliptin in drug-naive and metformin-treated patients with Type 2 diabetes. Diabet Med.
248 Karyekar C, Donovan M, Allen E, et al. (2011). Efficacy and safety of saxagliptin combination therapy in US patients with type 2 diabetes. Postgrad Med.
249 Home PD, Kahn SE, Jones NP, et al. (2010). Experience of malignancies with oral glucose-lowering drugs in the randomised controlled ADOPT (A Diabetes Outcome Progression Trial) and RECORD (Rosiglitazone Evaluated for Cardiovascular Outcomes and Regulation of Glycaemia in Diabetes) clinical trials. Diabetologia.
250 Jendle J, Nauck MA, Matthews DR, et al. (2009). Weight loss with liraglutide, a once-daily human glucagon-like peptide-1 analogue for type 2 diabetes treatment as monotherapy or added to metformin, is primarily as a result of a reduction in fat tissue. Diabetes Obes Metab.
251 Bailey RA, Vijapurkar U, Meininger G, et al. (2015). Diabetes-Related Composite Quality End Point Attainment: Canagliflozin Versus Sitagliptin Based on a Pooled Analysis of 2 Clinical Trials. Clin Ther.