# Appendix F Key Points and Evidence Grades

## Key Points and Evidence Grades for Intermediate Outcomes

- Conclusions for all the intermediate outcomes are short term (≤ 1 year) due to the few studies of longer duration evaluating these outcomes.
- Of the few studies that did evaluate longer time frames (≥2 years), almost all had at least 20 percent losses to followup, making it challenging to draw firm conclusions about long term outcomes.

### Hemoglobin A1c

#### Monotherapy Comparisons

- Most oral diabetes medications had similar efficacy in achieving reductions in hemoglobin A1c (HbA1c).
  ○ In the prior report, the strength of evidence was graded as high that metformin was similar to sulfonylurea (pooled between-group difference of 0.1%; 95% confidence interval [CI], -0.1% to 0.3%).Therefore, we did not update this comparison for HbA1c in this review.
  ○ The strength of evidence (SOE) was graded as high that metformin was similar to thiazolidinedione (pooled between-group difference of -0.04%; 95% CI, -0.11% to 0.03%).
  ○ Thiazolidinediones performed similarly to sulfonylureas (pooled between-group difference of -0.04%; 95% CI, -0.13% to 0.06%). (SOE: High)
  ○ The SOE was graded as low or insufficient for the monotherapy comparisons with the newer classes of sodium-glucose cotransporter (SGLT-2) inhibitors and glucagon-like peptide-1 (GLP-1) agonists, and will warrant further study.
- The one exception was that metformin had a greater reduction in HbA1c compared with dipeptidyl peptidase-4 (DPP-4) inhibitors (pooled between-group difference of -0.4%; 95% CI, -0.5% to -0.3%). (SOE: High)

#### Metformin-Based Combination Comparisons

- The combination of metformin plus GLP-1 agonists reduced HbA1c more than metformin plus DPP-4 inhibitors, with a pooled between-group difference of -0.65% (95% CI, -0.75% to -0.54%) in the short-term. (SOE: Moderate)
- Most other combination therapy comparisons had either no significant or no clinically meaningful (<0.3%) between-group differences in HbA1c between arms.
- The evidence was graded as moderate for the following comparisons: metformin plus a thiazolidinedione versus metformin plus a sulfonylurea, metformin plus a thiazolidinedione versus metformin plus a DPP-4 inhibitor, metformin plus a sulfonylurea versus metformin plus an SGLT-2 inhibitor, metformin plus a DPP-4 inhibitor versus metformin plus an SGLT-2 inhibitor, and metformin plus a DPP-4 inhibitor versus metformin plus a GLP-1 agonist.
- Despite the clinical interest in comparing metformin plus injectables, there was insufficient or low strength of evidence on glycemic control for the following comparisons: metformin plus the GLP-1 agonists versus metformin plus basal or premixed insulin, and metformin plus premixed insulin versus metformin plus basal insulin.

### Weight

#### Monotherapy Comparisons

- In the 2011 report, metformin had greater weight reduction than thiazolidinediones (pooled mean between-group difference of -2.6 kg; 95% CI, -4.1 kg to -1.2 kg) or sulfonylureas (pooled mean between-group difference of -2.7 kg; 95% CI, -3.5 kg to -1.9 kg) with high strength of evidence. Therefore, we did not update these two comparisons in this report.
- Metformin had greater weight reduction than DPP-4 inhibitors (pooled mean between-group difference, -1.3 kg; 95% CI, -1.6 kg to -1.0 kg). (SOE: High)
- SGLT-2 inhibitors had greater weight reduction when compared with metformin or DPP-4 inhibitors (between-group differences ranging from -1.3 kg to -2.7 kg). (SOE: Moderate for both comparisons)
- DPP-4 inhibitors and GLP-1 agonists both decreased weight more than thiazolidinediones (between-group differences ranging from -2.3 kg to -3.5 kg). (SOE: Moderate for both comparisons)
- GLP-1 agonists decreased weight more than sulfonylureas (pooled mean between-group difference, -2.3 kg; 95% CI, -3.3 kg to -1.2 kg). (SOE: Moderate)
- Sulfonylureas caused slightly less weight gain when compared with thiazolidinediones (between-group difference of -1.2 kg; 95% CI, -1.8 kg to -0.6 kg). (SOE: Moderate)

#### Metformin Versus Metformin-Based Combination Comparisons

- Metformin monotherapy reduced weight more than the combination of metformin plus a thiazolidinedione (pooled mean between-group difference, -2.2 kg; 95% CI, -2.6 kg to -1.9 kg) or metformin plus a sulfonylurea (pooled mean between-group difference, -2.2 kg, 95% CI, -3.4 kg to -1.0 kg). (SOE: High for both comparisons)
- When compared with metformin monotherapy, the combination of metformin plus
  ○ SGLT-2 inhibitor had greater weight reduction (pooled mean between-group difference, -2.0 kg; 95% CI, -2.5 kg to -1.5 kg). (SOE: High)
  ○ GLP-1 agonist had greater weight reduction (pooled mean between-group difference, -2.0 kg; 95% CI, -2.7 kg to -1.3 kg). (SOE: Moderate)
- Metformin monotherapy had no significant differences in weight when compared with the combination of metformin plus DPP-4 inhibitors (pooled mean between-group difference, -0.1 kg; 95% CI, -0.2 kg to 0.03 kg). (SOE: Moderate)

#### Metformin-Based Combination Comparisons

- The combinations of metformin plus a sulfonylurea, metformin plus a GLP-1 agonist, and metformin plus a DPP-4 inhibitor all had a more favorable effect on weight compared with metformin plus a thiazolidinedione (range in between-group differences, -0.9 kg to -5.1 kg). (SOE: Moderate for all comparisons)
- When compared with the combination of metformin plus a sulfonylurea, the combination of metformin plus
  ○ DPP-4 inhibitors had more favorable effects on weight (pooled mean between-group difference, -2.2 kg; 95% CI, -1.8 kg to -2.5 kg). (SOE: High)
  ○ SGLT-2 inhibitors had more favorable effects on weight (pooled mean between-group difference, -4.7 kg; 95% CI, -4.4 kg to -5.0 kg). (SOE: High)
  ○ GLP-1 agonist had more favorable effects on weight (range in mean between-group differences, -2.4 kg to -12.3 kg). (SOE: Moderate)
  ○ Premixed insulin or basal insulin had less favorable effects on weight (range in mean between-group differences, 0.5 kg to 1.7 kg). The strength of evidence was low for both comparisons, due to the small number of studies. However, taken together, the strength of evidence would be moderate favoring metformin plus sulfonylurea over metformin plus a premixed or long-acting insulin.
- When compared with metformin plus a DPP-4 inhibitor, the combination of metformin plus
  ○ GLP-1 agonist had greater reductions in weight (pooled mean between-group difference, -1.8 kg; 95% CI, -1.1 kg to -2.5 kg). (SOE: Moderate)
  ○ SGLT-2 inhibitors had greater reductions in weight (between-group differences of around -2.5 kg). (SOE: Moderate)
- Despite the clinical interest in comparing metformin plus injectables, there was low strength of evidence on weight for the following comparisons: metformin plus the GLP-1 agonists versus metformin plus basal or premixed insulin, and metformin plus premixed insulin versus metformin plus basal insulin.

### Systolic Blood Pressure (for Comparisons That Include SGLT-2 Inhibitors or GLP-1 Agonists)

#### Monotherapy Comparisons

- SGLT-2 inhibitors had a greater reduction in systolic blood pressure compared with metformin, (pooled between-group difference of -2.8 mmHg; 95% CI, -2.6 mmHg to -3.0 mmHg). (SOE: Moderate)
- The strength of evidence was graded low or insufficient for the following comparisons:
  ○ SGLT-2 inhibitors versus DPP-4 inhibitors, and
  ○ GLP-1 agonists versus metformin, thiazolidinediones, sulfonylureas, and DPP-4 inhibitors.

#### Metformin Versus Metformin-Based Combination Comparisons

- Metformin plus a SGLT-2 inhibitor reduced systolic blood pressure more than metformin alone (pooled between-group difference of -4.4 mmHg; 95% CI, -2.9 to -6.0 mmHg) for shorter studies. (SOE: High)
- Metformin plus a GLP-1 agonist reduced systolic blood pressure more than metformin alone (pooled between-group difference of -3.1 mmHg; 95% CI, -1.4 to -4.9 mmHg). (SOE: Moderate)

#### Metformin-Based Combination Comparisons

- Metformin plus a SGLT-2 inhibitor reduced systolic blood pressure more than metformin plus a sulfonylurea (pooled between-group difference, -5.0 mmHg; 95% CI, -4.2 mmHg to -6.0 mmHg) or metformin plus a DPP-4 inhibitor (pooled between-group difference, -4.1 mmHg; 95% CI, -3.6 mmHg to -4.6 mmHg). (SOE: High and Moderate, respectively)

### Heart Rate (for Comparisons That Include SGLT-2 Inhibitors or GLP-1 Agonists)

#### Monotherapy Comparisons

- Metformin compared with a GLP-1 agonist yielded no differences in heart rate between arms. (SOE: Moderate)

#### Metformin Versus Metformin-Based Combination Comparisons

- There was low or insufficient evidence for all metformin combination therapies compared with metformin alone.

#### Metformin-Based Combination Comparisons

Combination therapy with metformin plus a SGLT-2 inhibitor resulted in less increase in heart rate compared with metformin plus a sulfonylurea (pooled between group difference in heart rate, -1.5 bpm; 95% CI, -0.6 bpm to -2.3 bpm). (SOE: Moderate)

## Key Points and Evidence Grades for Long-Term Outcomes

### All-Cause Mortality

- All evidence on all-cause mortality was of low strength or insufficient

### Cardiovascular Mortality

- Sulfonylurea monotherapy was associated with increased cardiovascular mortality compared with metformin monotherapy (relative risk range 1.5 to 1.7 from individual RCTs; range in risk differences, 0.1 to 2.9%; range in duration of follow up, 2.8 to 4.0 years). (SOE: Moderate)
- To date, there has been uncertainty about the cardiovascular benefits of diabetes medications as evidenced by the FDA labeling stating a lack of known lower macrovascular risk for any diabetes medications; still, all evidence on the comparative effectiveness of the included diabetes medications on cardiovascular mortality was of low strength or insufficient.

### Cardiovascular and Cerebrovascular Disease Morbidity

- To date, there has been uncertainty about the cardiovascular benefits of diabetes medications as evidenced by the FDA labeling stating a lack of known lower macrovascular risk for any diabetes medications; still, all evidence on the comparative effectiveness of the included diabetes medications on cardiovascular mobidity was of low strength or insufficient.

### Retinopathy, Nephropathy, and Neuropathy

- The evidence was low or insufficient for all comparisons, and almost all RCTs were short-term.

## Key Points and Evidence Grades for Safety

### Hypoglycemia

#### Mild, Moderate, or Total Hypoglycemia

Unless otherwise noted, results on hypoglycemia refer to the number of participants experiencing hypoglycemia and not to the number of events.

- Metformin monotherapy was favored over the following:
  ○ Sulfonylurea monotherapy for mild-moderate hypoglycemia (pooled OR for sulfonylurea versus metformin, 4.00; 95% CI, 1.75 to 9.83) (SOE: High);
  ○ The combination of metformin plus a thiazolidinedione (pooled OR for metformin plus a thiazolidinedione versus metformin monotherapy for total hypoglycemia, 1.56; 95% CI, 0.99 to 2.44) (SOE: Moderate);
  ○ The combination of metformin plus a sulfonylurea for mild, moderate, or total hypoglycemia (range in ORs, 2.15 to 28.6) (SOE: Moderate).
  ○ The combination of metformin plus an SGLT-2 inhibitor for mild or moderate hypoglycemia (pooled OR, 1.74; 95% CI, 0.83 to 3.66) (SOE: Moderate).
- The risks of mild-moderate and total hypoglycemia were similar for metformin monotherapy and the combination of metformin plus a DPP-4 inhibitor. (SOE: High)
  ○ Pooled OR for metformin plus a DPP-4 inhibitor versus metformin monotherapy:
    ▪ Mild-moderate hypoglycemia: 0.97; 95% CI, 0.63 to 1.51
    ▪ Total hypoglycemia: 0.92; 95% CI, 0.43 to 1.97
- Sulfonylurea monotherapy increased the risk of total hypoglycemia compared with thiazolidinedione monotherapy (pooled OR 6.31; 95% CI, 4.08 to 9.76). (SOE: High)
- SGLT-2 inhibitor monotherapy was associated with a lower risk of hypoglycemia compared with metformin monotherapy (pooled OR, 0.46; 95% CI, 0.16 to 1.30). (SOE: Moderate)
- DPP-4 inhibitor monotherapy was favored over sulfonylurea monotherapy (range of OR, 0.08 to 0.26 from individual studies for sulfonylurea versus DPP-4 inhibitor monotherapy). (SOE: Moderate)
- Mild-moderate hypoglycemia was more common with sulfonylurea monotherapy than with GLP-1 agonist monotherapy (range in OR, 3.2 to 5.3). (SOE: Moderate)
- When compared with metformin plus a sulfonylurea, metformin plus an SGLT-2 inhibitor had less risk of mild or moderate hypoglycemia (range in OR, 0.03 to 0.13). (SOE: High)
- When compared with metformin plus sulfonylurea, several combinations had less risk of mild, moderate, or total hypoglycemia: metformin plus a thiazolidinedione, metformin plus a DPP-4 inhibitor, and metformin plus a GLP-1 agonist (range in OR, 0.07 to 0.27). (SOE: High or Moderate for all comparisons)
- When compared with metformin plus basal insulin or premixed insulin, metformin plus a GLP-1 agonist had less risk of mild or moderate hypoglycemia (range in OR, 0.18 to 0.35). (SOE: Moderate)
- Moderate grade evidence showed a lower risk of hypoglycemia when metformin is combined with a basal insulin rather than a premixed insulin (range in OR, 0.23 to 0.89).

#### Severe Hypoglycemia

- Only the sulfonylurea comparisons convincingly demonstrated an increased risk of severe hypoglycemia in the sulfonylurea arms compared with nonsulfonylurea medications:
  ○ Sulfonylurea versus metformin (range in OR, 1.41 to 2.04) (SOE: Moderate)
  ○ Sulfonylurea versus thiazolidinediones (OR, 8.1) (SOE: Moderate)
  ○ Metformin plus sulfonylurea versus metformin plus SGLT-2 inhibitors, and metformin plus sulfonylurea versus metformin plus DPP-4 inhibitors. (SOE: Moderate or High)
- Only two comparisons had sufficient evidence to show no between-group differences in severe hypoglycemia: the combination of metformin plus thiazolidinediones versus metformin plus DPP-4 inhibitors and metformin monotherapy versus metformin plus a DPP-4 inhibitor. (SOE: Moderate)

### Gastrointestinal (GI) Side Effects

- GI adverse events are more common with:
  ○ metformin than with DPP-4 inhibitors (pooled OR 2.6 and 2.7 for diarrhea and nausea, favoring DPP-4 inhibitors), (SOE: High);
  ○ metformin than thiazolidinediones (between 1.7 to 4.2 fold higher risk), (SOE: Moderate);
  ○ metformin than sulfonylureas (between 2.2 to 2.4 fold higher risk), (SOE: Moderate);
  ○ GLP-1 agonists than metformin for nausea and vomiting (between 1.3 to 1.7 fold increased risk with GLP-1 agonists). (SOE: Moderate)
  ○ GLP-1 agonists than sulfonylureas (between 1.5 to 2.4 fold higher risk of diarrhea), (SOE: Moderate)
  ○ metformin plus a GLP-1 agonist than metformin plus a DPP-4 inhibitor (between 1.0 to 7.8 fold higher risk with metformin plus GLP-1 agonists), (SOE: Moderate);
  ○ metformin plus a GLP-1 agonist than metformin plus a thiazolidinedione (between 2.9 to 6.3 fold higher risk with metformin plus a GLP-1 agonist). (SOE: Moderate)
- GI adverse events are equally common with:
  ○ thiazolidinediones and sulfonylureas, (SOE: High);
  ○ metformin monotherapy and metformin plus a DPP-4 inhibitor, (SOE: Moderate for any GI adverse event, nausea, and vomiting for shorter duration studies);
  ○ metformin plus a sulfonylurea and metformin plus a DPP-4 inhibitor in longer studies, (SOE: High);
  ○ metformin monotherapy and combination therapy with metformin plus a SGLT-2 inhibitor (for diarrhea), (SOE: Moderate);
  ○ metformin plus a thiazolidinedione and metformin plus a sulfonylurea. (SOE: Moderate)

### Cancer

- Type of cancer was not designated a priori in most of the studies reporting on cancer; thus, the following conclusions apply to any cancer, unless specified.
- Even though the FDA has issued warnings regarding increased risk of bladder cancer risk with pioglitazone, we found low or insufficient strength of evidence on TZD-based comparisons and cancer outcomes.
- Despite FDA warnings of a possible increased risk of thyroid cancer with GLP-1 agonists, we found low-strength or insufficient evidence on GLP-1 agonist-based comparisons and cancer outcomes.

### Congestive Heart Failure

- Thiazolidinediones alone increase the risk of heart failure when compared with sulfonylureas (pooled OR in four RCTs of 1.6; 95% CI, 0.96 to 2.8) or metformin (two short RCTs with no events, one 4-year RCT with an absolute risk difference of 3% and range in HR of 1.2 to 1.5 in two observational studies). (SOE: Low)
- Despite recent concerns of congestive heart failure with DPP-4 inhibitors, we found low or insufficient strength of evidence on the comparative safety of this drug class for this outcome.

### Pancreatitis

- Despite FDA warnings regarding an increased risk of pancreatitis with GLP-1 agonists and DPP-4 inhibitors, we found low or insufficient evidence on the comparative safety of these drug classes for this outcome.

### Genital Mycotic Infections (for Comparisons That Include SGLT-2 Inhibitors)

- Compared to metformin monotherapy, genital infection rates were higher for SGLT-2 inhibitor monotherapy and for the combination of metformin plus an SGLT-2 inhibitor Rates of genital infections for combination therapy with metformin plus an SGLT-2 inhibitor were higher compared to the following:
  ○ Metformin monotherapy: pooled OR for women, 3.0; 95% CI, 1.2 to 7.2 and pooled OR for men, 2.7; 95% CI, 0.8 to 9.0 (SOE: High)
  ○ Metformin plus a sulfonylurea: pooled OR for women, 5.2; 95% CI, 3.4 to 7.8; pooled OR for men, 7.6; 95% CI, 4.0 to 14.4 (SOE: High)
  ○ Metformin plus a DPP-4 inhibitor

### Other Serious Adverse Events

- There was no moderate or high strength of evidence for the following adverse events: liver injury, lactic acidosis, severe allergic reactions, macular edema/decreased vision, urinary tract infections (for SGLT-2 inhibitors) impaired renal function (for SGLT-2 inhibitors), fractures (for SGLT-2 inhibitors), and volume depletion (for SGLT-2 inhibitors). Therefore, we were unable to draw any firm conclusions regarding the diabetes medication comparisons and these safety outcomes.

## Key Question 4 Subgroups

Although thirty-two studies reported on the comparative effectiveness and safety for sub-populations relevant to Key Question 4 (Appendix D, Table D14), few studies had sufficient power to assess comparative effectiveness or safety by subgroup. The evidence favoring one medication over another across subgroups is unclear.