# Appendix E Gray Literature

We searched the Food and Drug Administration (FDA) Web site for unpublished trials of the following drugs: albiglutide, alogliptin, canagliflozin, dapagliflozin, dulaglutide, empagliflozin, linagliptin, liraglutide, saxagliptin, pioglitazone and rosiglitazone. After reviewing the data from the FDA medical reviews and statistical reviews, we found 40 studies with drug comparisons of interest. Thirty-seven of these 40 trials were published in the peer-reviewed literature and were included in this report. The published data were consistent with the data described in the FDA reviews on select outcomes (HbA1c, hypoglycemia, and all-cause mortality). One trial was not published in the peer-reviewed literature until October 2014 and was therefore not included in this report.234 Two trials were published only as meeting abstracts in 2014; therefore, they were not included in this report.235

Additionally, we found 38 unpublished studies from our search of the ClinicalTrials.gov registry. Fourteen of these studies were either ongoing or not yet open therefore no data was available. Twenty-four of these studies were completed and 10 of them had study results available on the website. We identified a clinical study registry that has been published and included in this report, but several of the long term outcomes were not included in its related publication.2

## KQ1 Intermediate Outcomes

We found 10 unpublished reports from ClinicalTrials.gov that reported on HbA1c outcomes for our comparison of interest. These results were not entirely consistent with the results from the published studies included in the review.

### Monotherapy Comparisons

#### Metformin Versus DPP-4 Inhibitors

Two short RCTs compared metformin with DPP-4 inhibitors. One RCT (NCT01289119) was an international multicenter phase-3 trial. The study had 98 participants in the metformin monotherapy arm (mean daily dose of 1484.2 mg) group, and 92 participants in the alogliptin monotherapy (25 mg daily) arm. The mean change from baseline in HbA1c at week 16 was -0.22 ± 0.065% (mean ± standard error) for metformin monotherapy group and was -0.99 ± 0.074% for alogliptin monotherapy group.

Another RCT (NCT01076088) was a multicenter phase 3 trial conducted in China. The study had 124 participants in the metformin monotherapy (1700 mg daily) group, and 120 participants in the sitagliptin monotherapy (100 mg daily) group. The mean change in HbA1c from baseline to week 24 was -1.6% (95% CI, -1.8% to -1.3%) for the metformin group and -0.99 (95% CI, -1.2% to -0.75%) for the sitagliptin monotherapy group.

#### Thiazolidinediones Versus DPP-4 Inhibitors

One unpublished 30-week RCT (NCT01183013) had 134 participants receiving 45mg of pioglitazone daily and 130 participants receiving 5mg of linagliptin. The mean change from baseline in HbA1c was -0.87 ± 0.09% (mean ± standard error) in the pioglitazone group, which exceeded than that in the linagliptin group (-0.39 ± 0.09%).

#### Thiazolidinediones Versus GLP-1 Agonists

One unpublished trial (NCT01147627) had 136 subjects in the pioglitazone 30 mg arm and 142 in the exenatide arm (10 μg twice daily titrated up to 20 μg twice daily). The mean change from baseline in HbA1c at week 48 was greater in the exenatide group (mean ± standard deviation, -1.8 ± 1.3%) than in the pioglitazone group (-1.5 ± 1.3%). This was inconsistent with the one published study included in this report.147

#### Sulfonylureas Versus DPP-4 Inhibitors

Two unpublished RCTs compared glimepiride (1 to 6 mg) with DPP-4 inhibitors in older patients, and both studies favored glimepiride over DPP-4 inhibitors. One trial (NCT01006603) evaluated glimepiride against 5 mg of saxagliptin daily. The study had 360 subjects in both arms and the mean change from baseline in HbA1c at week 52 was greater in the glimepiride arm than in the saxagliptin arm (-0.64% versus -0.44%). Another 30-week trial (NCT01189890) had 239 subjects in the glimepiride arm and 241 in the sitagliptin group. The between-group difference in change in HbA1c of 0.19% (95% CI, 0.03% to 0.34%) favored glimepiride over sitagliptin.

### Metformin Versus Metformin-Based Combination Comparisons

#### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Three RCTs lasting 4 to 6 months compared metformin with the combination of metformin plus a DPP-4 inhibitor. The results were consistent with the results from the published study, as all favored the combination arm. One unpublished 16-week trial (NCT01289119) reported statistically significant between-group difference in mean HbA1c change of -0.69% (95% CI, -0.87% to -0.51%; P < 0.001), favoring metformin plus 25mg of daily alogliptin (-0.91 ± 0.065%, n=99) over metformin monotherapy (-0.22 ± 0.065%, n=98). Another trial in China (NCT01076088) reported a greater decrease in mean HbA1c at week 24 in patients treated with 100 mg of sitagliptin daily as add-on therapy to metformin (-1.8%; 95% CI, -2.1% to -1.6%) compared with those treated with metformin monotherapy (-1.6%, 95% CI, -1.8% to -1.3%), after adjustment for differences between groups. Another trial (NCT00960076) randomized 144 participants to the metformin (2000 mg daily) group and 138 to the metformin (1500 mg daily) plus saxagliptin (5 mg daily) group, and favored the combination arm with a mean between-group difference in HbA1c from baseline to week 18 of -0.52% (95% CI, -0.73% to -0.31%).

### Metformin-Based Combination Comparisons

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One large, unpublished trial (NCT00856284) compared metformin plus 5 mg of glipizide to metformin plus 25 mg of alogliptin. The metformin plus alogliptin combination was not inferior to the metformin plus glipizide combination, with a mean between-group difference of -0.13%.

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a SGLT-2 Inhibitor

One unpublished trial in Japan (NCT01368081) had 63 subjects treated with 500 mg of metformin as add-on therapy to background sulfonylurea, and 65 treated with empagliflozin at 25mg daily as add-on therapy to background metformin. Unlike the published study favoring the metformin plus SGLT-2 inhibitor combination group, the mean change from baseline in HbA1c was very similar for both the metformin plus sulfonylurea combination group (-0.97 ± 0.08%) and the metformin plus empagliflozin combination group (-0.98 ± 0.06%) after 52 weeks of treatment.

#### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

The combination of metformin and insulin detemir was evaluated against the combination of metformin and biphasic insulin aspart 30 in a 50-week RCT (NCT01068652). The study had 200 subjects in the metformin plus insulin detemir group and 203 in the metformin plus biphasic insulin aspart 30 group, and similar to previously published studies, reported no statistically-significant between-group difference in HbA1c at week 50 (0.11%; 95% CI, -0.12% to 0.34). The change in HbA1c from baseline was -1.2% in the metformin plus glipizide group, and -1.3% in the metformin plus alogliptin group.

## KQ2 Long-Term Outcomes

We found nine unpublished reports from the ClinicalTrials.gov site and one clinical registry study that reported on long-term clinical outcomes for our comparisons of interest. These results were generally consistent with the results from the published studies included in the review.

### Monotherapy Comparisons

#### Metformin Versus DPP-4 Inhibitors

One 24-week RCT (NCT01076088) evaluated sitagliptin against metformin, both as monotherapy. The study reported one case of cerebral infarction out of 120 participants in sitagliptin arm and no cases in the metformin group. One subarachnoid hemorrhage was reported among 124 patients treated with metformin while none was reported in sitagliptin arm.

#### Thiazolidinediones Versus DPP-4 Inhibitors

One 54-week study (NCT01183013) reported the occurrence of a cardiac outcome in one subject treated with pioglitazone (atrial fibrillation) and three subjects treated with linagliptin (one coronary artery disease, one myocardial infarction, and one tachycardia). One nervous system disorder was reported in the pioglitazone arm (peripheral nerve palsy) and one in the linagliptin arm (radiculopathy). No other cardiac disorders (acute myocardial infarction, cardiopulmonary failure, supraventricular tachycardia, congestive cardiomyopathy) were reported.

#### Thiazolidinediones Versus GLP-1 Agonists

One study (NCT01147627) reported one case of a nervous system disorder (facial neuritis) in the pioglitazone group (1/136). Both arms had one case of cerebral infarction. Blurred vision was reported in three participants treated with pioglitazone monotherapy and in participants treated with exenatide monotherapy.

#### Sulfonylureas Versus DPP-4 Inhibitors

Two short, unpublished trials tested glimepiride against DPP-4 inhibitors. One (NCT01006603) was a 52-week trial comparing glimepiride with saxagliptin, and the other (NCT01189890) was a 30-week trial comparing glimepiride to sitagliptin. Both trials had one death in the glimepiride arm while no patient died in the DPP-4 inhibitors arms. The incidences of cardiac disorders were low in both arms for both studies. The 52-week study reported three patients in glimepiride arm versus one in saxagliptin arm having heart failure, and three patients in each arm with myocardial infarction. The 30-week trial reported that 2 of 236 participants in the glimepiride arm had cardiac events (one angina unstable and one chronic cardiac failure) and 1 of 241 in the sitagliptin arm (atrial fibrillation).

### Metformin Versus Metformin-Based Combination Comparisons

#### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

The clinical registry study (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus glimepiride (n=307) with metformin monotherapy (n=101) at 156 weeks. It reported the occurrence of cardiac disorders in six subjects in the metformin monotherapy group (four graded as serious events), and six for the metformin plus glimepiride combination group; five graded as serious events. It also reported three serious nervous system adverse event in the metformin monotherapy arm; one subarachnoid hemorrhage, one cerebrovascular accident and one VIIth nerve paralysis, while in the combination therapy arm it reported one episode of carotid artery stenosis and one case of complicated migraine. One death was reported for the metformin monotherapy arm and six cases of fatal severe adverse events for the metformin plus glimepiride combination therapy arm. No fatal myocardial infarctions were reported in the metformin or metformin plus glimepiride arms.

#### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Two short-term RCTs compared the combination of metformin plus saxagliptin with metformin monotherapy. One (NCT00960076) reported the occurrence of cardiac disorders in two subjects in the metformin monotherapy group (one atherosclerotic disease and one myocardial infarction) (n=144), while none was reported for the metformin plus saxagliptin combination group (n=138). The other trial (NCT01076088) reported one subarachnoid hemorrhage in the metformin monotherapy arm (n=124) and none in the combination therapy arm (n=125). No cerebral infarction was reported for either the metformin monotherapy arm or the metformin plus saxagliptin combination therapy arm. The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus sitagliptin with metformin monotherapy at 156 weeks. It reported the occurrence of cardiac disorders in six subjects in the metformin monotherapy group (four graded as serious) (n=101), and five for the metformin plus sitagliptin combination group; all graded as serious (n=302). It also reported three serious nervous system adverse event in the metformin monotherapy arm; one subarachnoid hemorrhage, one cerebrovascular accident and one VIIth nerve paralysis, while in the combination therapy arm it reported one episode of syncope. One death was reported for the metformin monotherapy arm and two cases of fatal severe adverse events for the metformin plus sitagliptin combination therapy arm.

#### Metformin Versus a Combination of Metformin Plus a GLP-1 Agonist

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus albiglutide (n=302) with metformin monotherapy (n=101) at 156 weeks. It reported the occurrence of cardiac disorders in six subjects in the metformin monotherapy group (four graded as serious), and 14 for the metformin plus albiglutide combination group; 12 graded as serious. It also reported three serious nervous system adverse event in the metformin monotherapy arm; one subarachnoid hemorrhage, one cerebrovascular accident and one VIIth nerve paralysis, while in the combination therapy arm it reported two cases of cerebrovascular accidents, one transient ischemic attack, one case of convulsion, one of polyneuropathy and of presyncope. One death was reported for the metformin monotherapy arm and four cases of fatal severe adverse events for the metformin plus albiglutide combination therapy arm.

### Metformin-Based Combination Comparisons

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One study (NCT00856284) had 869 subjects treated with the combination of metformin plus 5 mg of glipizide, and 378 treated with the combination of metformin plus 25 mg of alogliptin. Events were reported for up to 108 weeks after initiation of study treatment. One sudden death was reported in the glipizide combination arm, but none was reported in alogliptin combination arm. Cardiac disorders were rare. The study reported coronary artery disease in three subjects in the metformin with alogliptin arm versus two subjects in the metformin with glipizide arm; one versus five for acute myocardial infarction (a statistically significant difference), three versus two with atrial fibrillation, three versus one with heart failure, none versus one with myocardial ischemia, and one in each arm with a cardiomyopathy. Cerebrovascular accident was reported in one patient in the alogliptin combination arm, and in three patients in the glipizide combination arm. Ischemic stroke (including transient ischemic attack) was reported in three patients in the alogliptin combination arm, and none in the glipizide combination arm.

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus sitagliptin with the combination of metformin plus glimepiride at 156 weeks. It reported the occurrence of cardiac disorders in six subjects in the metformin plus glimepiride group (five graded as serious) (n=307), and five for the metformin plus sitagliptin combination group; all graded as serious (n=302). It also reported two serious nervous system adverse event in the metformin plus glimepiride arm (one carotid artery stenosis and one complicated migraine), while in the metformin plus sitagliptin combination therapy arm it reported one episode of syncope. Six deaths were reported for the metformin plus glimepiride arm and two cases of fatal severe adverse events for the metformin plus sitagliptin combination therapy arm.

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Agonist

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus albiglutide with the combination of metformin plus glimepiride at 156 weeks. It reported the occurrence of cardiac disorders in six subjects in the metformin plus glimepiride group (five graded as serious) (n=307), and 14 for the metformin plus albiglutide combination group (12 graded as serious) (n=302). It also reported two serious nervous system adverse event in the metformin plus glimepiride arm (one carotid artery stenosis and one complicated migraine), while in the metformin plus albiglutide combination therapy arm it reported two cases of cerebrovascular accidents, one transient ischemic attack, one case of convulsion, one of polyneuropathy and of presyncope. Six deaths were reported for the metformin plus glimepiride arm and four deaths for the metformin plus albiglutide combination therapy arm.

#### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Agonist

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus albiglutide with the combination of metformin plus sitagliptin at 156 weeks. It reported the occurrence of cardiac disorders in five subjects in the metformin plus sitagliptin group (all graded as serious) (n=302), and 14 for the metformin plus albiglutide combination group (12 graded as serious) (n=302). It also reported one serious nervous system adverse event in the metformin plus sitagliptin arm (one episode of syncope), while in the metformin plus albiglutide combination therapy arm it reported two cases of cerebrovascular accidents, one transient ischemic attack, one case of convulsion, one of polyneuropathy and of presyncope. Two deaths were reported for the metformin plus sitagliptin arm and four deaths for the metformin plus albiglutide combination therapy arm.

#### Combination of Metformin Plus a Basal-Bolus Insulin Versus a Combination of Metformin Plus a Premixed Insulin

One study (NCT01068652) compared the effect of the combination of metformin plus basal-bolus insulin analogs (insulin detemir and aspart) with the combination of metformin plus 70/30 insulin aspart. Incidence of cardiac disorders were 2 among 200 in the metformin plus insulin detemir arm and 4 among 203 in the metformin plus biphasic insulin aspart 30 arm.

## KQ3 Safety Outcomes

We found 10 unpublished reports from the ClinicalTrials.gov site that reported on safety outcomes for our comparisons of interest.

### Monotherapy Comparisons

#### Metformin Versus DPP-4 Inhibitors

One 24-week trial (NCT01076088) compared metformin monotherapy with 100 mg of sitagliptin monotherapy. The study reported a greater incidence of GI adverse events in the metformin arm (9/124 subjects reported diarrhea and 4/124 reported nausea) than in the sitagliptin arm (2/120 for diarrhea and 0/120 for nausea). Hypoglycemia was reported in four subjects in the sitagliptin arm, and two subjects in the metformin arm.

#### Thiazolidinediones Versus DPP-4 Inhibitors

One trial (NCT01183013) reported no cases of diarrhea, vomiting, hypoglycemia, or acute pancreatitis in any of the 134 patients receiving pioglitazone at 45 mg daily or the 130 patients receiving linagliptin at 5 mg daily. Cancer was reported in two patients in the pioglitazone arm and no patients in the linagliptin arm.

#### Thiazolidinediones Versus GLP-1 Agonists

One RCT (NCT01147627) described one patient on exenatide who developed acute pancreatitis (n=142) compared with none in the pioglitazone group (0/136). The incidence of GI disorders in the exenatide group was much higher than in the pioglitazone group (37/142 versus 1/136 for nausea, 15/142 versus 1/136 for vomiting, 6/142 versus 4/136 for diarrhea).

#### Sulfonylureas Versus DPP-4 Inhibitors

Two unpublished trials evaluated glimepiride against DPP-4 inhibitors. A 52-week RCT (NCT01006603) reported a much higher proportion of patients having experienced at least one hypoglycemic event (confirmed or severe) in the glimepiride group (15.3%) compared with the saxagliptin group (1.1%). Incidence of cancer was higher in the saxagliptin group (10/359) than in the glimepiride group (3/359). The incidence of GI disorders did not differ significantly among patients receiving glimepiride monotherapy and those receiving saxagliptin monotherapy (19/359 verses 15/359 for diarrhea, and 8/359 versus 4/359 for nausea).

The other trial (NCT01189890) reported symptomatic hypoglycemia up to week 30 in 11 subjects in the glimepiride monotherapy group and two subjects in the sitagliptin monotherapy group. The between-group difference in hypoglycemia incidence was -3.9% (95% CI, -7.5% to -1.2%), favoring glimepiride over sitagliptin. Three cases of cancer were reported in patients treated with sitagliptin (colon cancer, malignant melanoma, and prostate cancer), and none in those treated with glimepiride.

### Metformin Versus Metformin-Based Combination Comparisons

#### Metformin Versus a Combination of Metformin Plus a Sulfonylurea

The clinical registry study (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus glimepiride (n=307) with metformin monotherapy (n=101) at 156 weeks. Hypoglycemia occurred in nine patients in the metformin arm and in 90 patients in the metformin plus glimepiride combination arm. None of the patients in the metformin arm had a severe hypoglycemic event, but one patient in the metformin plus glimepiride arm did. Two patients in the metformin arm (both serious) and five patients in the metformin plus glimepiride arm (four serious) had a gastrointestinal disorder. One of the gastrointestinal events in the metformin plus glimepiride arm was an acute pancreatitis. While the related publication only reported on thyroid cancer, the registry reported other types of cancer after 156 weeks; two cases of cancer in the metformin arm (breast and prostate) and seven on the combination arm (lymphoma, lung, uterus, and liver).

#### Metformin Versus a Combination of Metformin Plus a DPP-4 Inhibitor

Two short-term RCTs compared the combination of metformin plus saxagliptin with metformin monotherapy. One trial (NCT00960076) reported diarrhea in five out of 144 patients in the metformin monotherapy group (3.5%), which was comparable to the incidence among patients treated with saxagliptin as add-on therapy to metformin (8/138, 5.8%). The other trial (NCT01076088) reported a similar incidence of GI adverse events in both the metformin monotherapy group (nine people reported diarrhea and four reported nausea) and the metformin plus sitagliptin combination group (four for diarrhea and eight for nausea). Hypoglycemia events did not differ significantly among patients treated with combination therapy (7/125) and patients treated with metformin monotherapy (2/124).

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus sitagliptin (n=302) with metformin monotherapy (n=101) at 156 weeks. Hypoglycemia occurred in nine patients in the metformin arm and in 16 patients in the metformin plus sitagliptin combination arm. None of the hypoglycemic events were severe. Two patients in the metformin arm and one patient in the metformin plus sitagliptin arm had a serious gastrointestinal disorder. The registry did not record any cases of acute pancreatitis among the patients in the metformin and in the metformin plus sitagliptin arms. The registry reported two cases of cancer in the metformin arm (breast and prostate) and ten on the combination arm (two cases of thyroid cancer and eight other cases; breast, prostate, lung, renal, and gastrointestinal).

#### Metformin Versus a Combination of Metformin Plus a GLP-1 Agonist

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus albiglutide (n=302) with metformin monotherapy (n=101) at 156 weeks. Hypoglycemia occurred in nine patients in the metformin arm and in 28 patients in the metformin plus albiglutide combination arm. None of the hypoglycemic events were severe. Two patients in the metformin arm and six patients in the metformin plus albiglutide arm had a serious gastrointestinal disorder. One of the serious gastrointestinal events in the metformin plus albiglutide arms was an acute pancreatitis. The registry reported two cases of cancer in the metformin arm (breast and prostate) and three in the combination arm (thyroid, uterus, and bladder).

### Metformin-Based Combination Comparisons

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a DPP-4 Inhibitor

One study (NCT00856284) with up to 104 weeks of followup had 869 subjects treated with the combination of metformin plus glipizide 5 mg, and 378 treated with the combination of metformin plus alogliptin at 25 mg daily. Hypoglycemia was rare and did not differ between arms. The metformin plus glipizide combination therapy arm reported had the only participant developing pancreatitis. The occurrence of GI adverse events was more frequently among patients receiving metformin plus alogliptin combination therapy (32 nausea, 1 severe vomiting, 60 diarrhea) than metformin plus glipizide combination therapy (20 nausea and 63 diarrhea), but this was not statistically significant. No severe diarrhea was reported in either group. Two cases of cancer were reported in the glipizide combination group (breast cancer and endometrial cancer), while three were reported in the alogliptin combination group (colon cancer and ovarian cancer).

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus sitagliptin (n=302) with the combination of metformin plus glimepiride (n=307) at 156 weeks. Hypoglycemia occurred in 90 patients in the metformin plus glimepiride combination arm and in 16 patients in the metformin plus sitagliptin combination arm. None of the patients in the metformin plus sitagliptin arm had a severe hypoglycemic event, but one patient in the metformin plus glimepiride arm did. Two patients in the metformin arm (both serious) and five patients in the metformin plus glimepiride arm (four serious) had a gastrointestinal disorder. One of the gastrointestinal events in the metformin plus glimepiride arm was an acute pancreatitis, and no pancreatitis was reported in the metformin plus DPP-4 inhibitor arm. While the related publication only reported on thyroid cancer, the registry reported other types of cancer after 156 weeks; seven cases in the metformin plus glimepiride combination arm (lymphoma, lung, uterus, and liver) and ten in the metformin plus sitagliptin combination arm (two cases of thyroid cancer and eight other cases; breast, prostate, lung, renal, and gastrointestinal).

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a SGLT-2 Inhibitor

One 52-week trial in Japan (NCT01368081) evaluated several safety outcomes for the combination of metformin plus sulfonylurea relative to the combination of metformin plus empagliflozin. Five out of 63 participants in the metformin plus sulfonylurea combination group experienced confirmed hypoglycemic events, which did not differ from the incidence in the metformin plus empagliflozin combination group (1 out of 65 participants). Five diarrhea cases were reported in metformin plus sulfonylurea arm, compared with four in the metformin plus empagliflozin arm. No drug-induced liver injury, no urinary tract infection, and no fractures were seen in either arm.

#### Combination of Metformin Plus a Sulfonylurea Versus a Combination of Metformin Plus a GLP-1 Agonist

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus albiglutide (n=302) with the combination of metformin plus glimepiride (n=307) at 156 weeks. Hypoglycemia occurred in 90 patients in the metformin plus glimepiride combination arm and in 28 patients in the metformin plus albiglutide combination arm. None of the patients in the metformin plus albiglutide arm had a severe hypoglycemic event, but one patient in the metformin plus glimepiride arm did. Five patients in the metformin plus glimepiride arm (four serious) and seven patients (six serious) in the metformin plus albiglutide arm had a gastrointestinal disorder. One of the gastrointestinal events in each arm was an acute pancreatitis. While the related publication only reported on thyroid cancer, the registry reported other types of cancer after 156 weeks; seven cases in the metformin plus glimepiride combination arm (lymphoma, lung, uterus, and liver) and three in the metformin plus albiglutide combination arm (thyroid, uterus, and bladder).

#### Combination of Metformin Plus a DPP-4 Inhibitor Versus a Combination of Metformin Plus a GLP-1 Agonist

The clinical study registry (NCT00838903-Glaxo study GLP112753) compared the combination of metformin plus albiglutide (n=302) with the combination of metformin plus sitagliptin (n=302) at 156 weeks. Hypoglycemia occurred in 16 patients in the metformin plus sitagliptin combination arm and in 28 patients in the metformin plus albiglutide combination arm. None of the events were considered serious. Two patients in the metformin plus sitagliptin arm (two serious) and seven patients (six serious) in the metformin plus albiglutide arm had a gastrointestinal disorder. One of the gastrointestinal events in the metformin plus albiglutide arm was an acute pancreatitis, and no cases of acute pancreatitis were reported in the metformin plus DPP-4 inhibitor arm. While the related publication only reported on thyroid cancer, the registry reported other types of cancer after 156 weeks; ten in the metformin plus sitagliptin combination arm (two cases of thyroid cancer and eight other cases; breast, prostate, lung, renal, and gastrointestinal) and three in the metformin plus albiglutide combination arm (thyroid, uterus, and bladder).

#### Combination of Metformin Plus a Basal Insulin Versus a Combination of Metformin Plus a Premixed Insulin

One study (NCT01068652) had 200 subjects in the metformin plus insulin detemir combination therapy group and 203 in the metformin plus biphasic insulin aspart 30 combination therapy group. One cancer case was reported in subjects treated with combination of metformin plus insulin detemir (breast cancer) but none in the comparison group. Diarrhea was reported in 13 subjects in the metformin plus insulin detemir combination group, and 15 in the metformin plus biphasic insulin aspart 30 combination group.

## Articles Reporting More Than One Study

Sixteen studies reported on more than one study (see Table E1).236-251 Since many of these studies pooled data from studies already included in our review, we did not abstract that data. For articles that pooled data from studies not included in our review, we abstracted and reported the results. The results from these studies are consistent with the findings from our review.

Table E1 Summary of studies reporting on more than one study

Author, year | Results of pooled studies if not duplicated or already in our report
Del Prato, 2013^243^ | Individual studies were included in the report
Sjostrand, 2014^244^ | Individual studies were included in the report
Davidson, 2014^245^ | Individual studies were included in the report
Grimm, 2013^246^ | Individual studies were included in the report
Rosenstock, 2013^247^ | Individual studies were included in the report
Karyekar, 2011^248^ | Individual studies were included in the report
Home, 2010^249^ | Individual studies were included in the report
Jendle, 2009^250^ | Individual studies were included in the report
Belcher, 2004^236^ | Mean blood pressure was slightly reduced by all treatments, with pioglitazone treatment resulting in the largest falls (approximately 1.5 mmHg). Hospitalizations for cardiac or cerebrovascular events were similar with the different treatments. Overall mortality was 7 of 1857 for pioglitazone and 10 of 1856 for non-pioglitazone treatments, of which 3 and 6 were cardiac deaths, respectively. The incidence of congestive cardiac failure was similar with pioglitazone (12/1857) and non-pioglitazone (10/1856) treatments.
Lester, 2005^237^ | Individual studies were included in the report
Belcher, 2005^238^ | Individual studies were included in the report
Belcher, 2005^239^ | Individual studies were included in the report
Charbonnel, 2005^240^ | Individual studies were included in the report
Ceriello, 2005^241^ | Individual studies were included in the report
Rendell, 2003^242^ | Individual studies were included in the report
Bailey, 2015^251^ | Individual studies were included in the report

mmHg = millimeters of mercury; HR =hazard ratio; CI =confidence interval; mmol/L = millimoles per liter