# Appendix D Evidence Tables

Table D1 Characteristics of studies evaluating diabetes medications in terms of intermediate outcomes

Table D2 Population characteristics of studies evaluating diabetes medications for intermediate outcomes

Table D3 Results of studies evaluating effects of diabetes medications on intermediate outcomes

Table D4 Quality of studies evaluating effects of diabetes medications on intermediate outcomes

Table D5 Characteristics of studies evaluating effects of diabetes medications on long-term outcomes

Table D6 Population characteristics of studies evaluating effects of diabetes medications on long-term outcomes

Table D7 Results of studies evaluating effects of diabetes medications on long-term clinical outcomes

Table D8 Results of studies evaluating effects of diabetes medications on nephropathy and neuropathy

Table D9 Quality of studies evaluating long-term clinical outcomes

Table D10 Characteristics of studies evaluating safety of diabetes medications

Table D11 Population characteristics of studies evaluating safety of diabetes medications

Table D12 Results of studies evaluating safety of diabetes medications

Table D13 Quality of studies evaluating safety of diabetes medications

Table D14 Results from randomized controlled trials and observational studies reporting outcomes in a subpopulation