# Appendix C List of Excluded Studies

(2014). Insulin vs. Sulfonylureas as add-on to metformin. Drug and Therapeutics Bulletin.
(2012). Risk of acute pancreatitis with ‘gliptins’. Drug Ther Bull.
(2013). A therapeutic option for the management of type 2 diabetes.
(2014). Correction To Comparison Of Empaglifl Ozin And Glimepiride As Add-On To Metformin In Patients With Type 2 Diabetes: A 104-Week Randomised, Active-Controlled, Double-Blind, Phase 3 Trial. Lancet Diabetes Endocrinol.
Valentine V, Hinnen D. (2014). Clinical Implications of Canagliflozin Treatment in Patients With Type 2 Diabetes. Clinical Diabetes.
Aaboe K, Knop FK, Vilsboll T, et al. (2009). Twelve weeks treatment with the DPP-4 inhibitor sitagliptin improves glycaemic control, but does not improve GLP-1 secretion, in patients with type 2 diabetes - A randomised trial. Diabetologia.
Aaboe K, Knop FK, Vilsboll T, et al. (2009). Twelve weeks treatment with the DPP-4 inhibitor, Sitagliptin, Reduces total PYY and PYY3-36 and increases PYY1-36 but has no effect on intact GLP-2 in subjects with type 2 diabetes Mellitus-A randomized trial. Diabetes.
Aaboe K, Vilsboll T, Knop FK, et al. (2009). Twelve weeks treatment with the DPP-4 Inhibitor, Sitagliptin, Improves the Insulin-Secreting capacity of the P-Cells in subjects with type 2 diabetes Mellitus-A randomized trial. Diabetes.
Abbatecola AM, Lattanzio F, Molinari AM, et al. (2010). Rosiglitazone and cognitive stability in older individuals with type 2 diabetes and mild cognitive impairment. Diabetes Care.
Abbatecola AM, Paolisso G. (2009). Rosiglitazone and cognitive stability in older persons with type 2 diabetes and mild cognitive impairment. Diabetologia.
Abdulkadir AA, Thanoon IA. (2012). Comparative Effects of Glibenclamide and Metformin on C-Reactive Protein and Oxidant/Antioxidant Status in Patients with Type II Diabetes Mellitus. Sultan Qaboos Univ Med J.
Abe M, Okada K, Maruyama T, et al. (2010). Clinical effectiveness and safety evaluation of long-term pioglitazone treatment for erythropoietin responsiveness and insulin resistance in type 2 diabetic patients on hemodialysis. Expert Opin Pharmacother.
Adetunji O, Skrivanek Z, Tahbaz A, et al. (2014). A post-hoc pooled analysis of two placebo controlled phase 3 trials, Assessment of Weekly AdministRation of LY2189265 in Diabetes-1 and-5 (AWARD-1 and AWARD-5): Dulaglutide compared with exenatide, sitagliptin, and placebo. Diabetologie und Stoffwechsel.
Adetunji O, Skrivanek Z, Tahbaz A, et al. (2014). A posthoc pooled analysis of two placebo-controlled phase 3 trials, Assessment of Weekly Administration of LY2189265 in Diabetes 1 and 5 (AWARD-1 and AWARD-5): Dulaglutide compared with exenatide, sitagliptin and placebo. Diabetic Medicine.
Agarwala A, Givens E, McGuire DK, et al. (2014). Rosiglitazone increases cholesterol efflux capacity in patients with type 2 diabetes. Journal of Investigative Medicine.
Agrawal A, Pradeep. (2012). To study the pattern of use and efficacy of anti-diabetic drugs in controlling adequate glycemic levels in diabetic patients in Navi Mumbai. Australasian Medical Journal.
Ajdi F, Khabbal Y, Safi S. (2009). ADR of oral antidiabetic. Drug Safety.
Al Sifri S, Basiounny A, Echtay A, et al. (2011). The incidence of hypoglycaemia in Muslim patients with type 2 diabetes treated with sitagliptin or a sulphonylurea during Ramadan: a randomised trial. Int J Clin Pract.
Alba M, Ahren B, Inzucchi SE, et al. (2009). Initial combination therapy with sitagliptin and pioglitazone: Complementary effects on postprandial glucose and islet cell function. Canadian Journal of Diabetes.
Alexanderson-Rosas E, de Jesus Martinez A, Ochoa-Lopez JM, et al. (2009). Arch Cardiol Mex.
Alkharfy KM, Al-Daghri NM, Sabico SB, et al. (2013). Vitamin D supplementation in patients with diabetes mellitus type 2 on different therapeutic regimens: a one-year prospective study. Cardiovasc Diabetol.
Allen E, Berglind N. (2011). Saxagliptin vs glipizide as add-on therapy to metformin in patients with type 2 diabetes: A 2-year assessment of HbA1c, hypoglycaemia, and weight gain in a randomised, double-blind study. Diabetologia.
Allen E, Donovan M, Berglind N, et al. (2010). Efficacy of saxagliptin according to patient baseline characteristics: A pooled analysis of three add-on pivotal randomised phase 3 clinical trials. Diabetologia.
Allen E, Karyekar C, Ohman P. (2011). Safety profile of saxagliptin (SAXA) in combination with 2 other agents: Data from dual-therapy trials in patients receiving rescue treatment. Diabetes.
Allen E, Slater J, Bryzinski B, et al. (2012). Efficacy and safety of saxagliptin (SAXA) in patients with type 2 diabetes stratified by cardiovascular risk factors. Diabetologia.
Alvarez-Guisasola F, Yin DD, Nocea G, et al. (2010). Association of hypoglycemic symptoms with patients' rating of their health-related quality of life state: a cross sectional study. Health Qual Life Outcomes.
Ambrosius WT, Danis RP, Goff DC, et al. (2010). Lack of association between thiazolidinediones and macular edema in type 2 diabetes: the ACCORD eye substudy. Arch Ophthalmol.
Ametov AS, Gusenbekova DG. (2014). Ter Arkh.
Araki A, Iimuro S, Sakurai T, et al. (2012). Long-term multiple risk factor interventions in Japanese elderly diabetic patients: The Japanese Elderly Diabetes Intervention Trial - study design, baseline characteristics and effects of intervention. Geriatrics and Gerontology International.
Aravind SR, Ismail SB, Balamurugan R, et al. (2012). Hypoglycemia in patients with type 2 diabetes from India and Malaysia treated with sitagliptin or a sulfonylurea during Ramadan: a randomized, pragmatic study. Curr Med Res Opin.
Arcidiacono B, Capula C, Chiefari E, et al. (2014). Glycemic efficacy of liraglutide is linked to gender in italian type 2 diabetic patients. Diabetes.
Ardawi MS, Akbar D, Al-Shaik A, et al. (2013). Circulating sclerostin, bone turnover markers and BMD in type-2 diabetic women treated with metformin or pioglitazone. Journal of Bone and Mineral Research.
Ardawi MS, Akbar D, Alshaikh A, et al. (2013). Circulating sclerostin, bone turnover markers and BMD in type 2 diabetic women treated with metformin or pioglitazone. Osteoporosis International.
Arjona Ferreira JC, Corry D, Mogensen CE, et al. (2013). Efficacy and safety of sitagliptin in patients with type 2 diabetes and ESRD receiving dialysis: a 54-week randomized trial. Am J Kidney Dis.
Arjona Ferreira JC, Corry D, Mogensen CE, et al. (2011). Efficacy and safety of sitagliptin vs. glipizide in patients with type 2 diabetes mellitus and end-stage renal disease on dialysis: A 54-week randomised trial. Diabetes, Stoffwechsel und Herz.
Arjona Ferreira JC, Marre M, Rabelink TJ, et al. (2011). Efficacy and safety of sitagliptin versus glipizide in patients with type 2 diabetes and moderate to severe chronic renal insufficiency. Diabetes, Stoffwechsel und Herz.
Armstrong M, Falahati A, Houlihan DD, et al. (2010). Effects of two years of liraglutide treatment on fatty liver disease in patients with type 2 diabetes: Analysis of the liraglutide effect and action in diabetes-2 extension trial. Gut.
Armstrong M, Houlihan D, Schmidt W, et al. (2011). Effects of once-daily liraglutide on fatty liver disease in patients with type 2 diabetes (T2D) after 2 years' treatment: Retrospective-analysis of the lead-2 extension trial. Journal of Diabetes.
Armstrong MJ, Falahati A, Houlihan D, et al. (2010). Effects of two years of liraglutide treatment on fatty liver disease in patients with type 2 diabetes: Analysis of the lead-2 extension trial. Hepatology.
Armstrong MJ, Houlihan DD, Rowe IA, et al. (2013). Safety and efficacy of liraglutide in patients with type 2 diabetes and elevated liver enzymes: individual patient data meta-analysis of the LEAD program. Aliment Pharmacol Ther.
Armstrong MJ, Houlihan DD, Rowe IA, et al. (2013). Safety and efficacy of liraglutide in patients with type 2 diabetes with elevated liver enzymes: Individual patient data meta-analysis of the LEAD programme. The Lancet.
Arnolds S, Sawicki PT. (2014). Liraglutide and the preservation of pancreatic (beta)-cell function in early type 2 diabetes: The libra trial. Diabetes care.
Arulanandham A, Raju A, Pradeep Rajkumar LA, et al. (2012). Prevalence of clinically significant macular edema [CSME] among glitazone users and non- users of type-2 DM patients with diabetic retinopathy. International Journal of Drug Development and Research.
Asanuma H, Kitakaze M. (2012). Nihon Rinsho.
Aschner P, Sethi B, Gomez-Peralta F, et al. (2013). Glargine vs. premixed insulin for management of type 2 diabetes patients failing oral antidiabetic drugs: The GALAPAGOS study. Diabetes.
Aschner P, Sethi B, Gomez-Peralta F, et al. (2015). Insulin glargine compared with premixed insulin for management of insulin-naive type 2 diabetes patients uncontrolled on oral antidiabetic drugs: the open-label, randomized GALAPAGOS study. J Diabetes Complications.
Aso Y, Takebayashi K, Inukai T, et al. (2011). Pioglitazone and cardiovascular events in type 2 diabetes: Effects of pioglitazone on cardiovascular outcomes in Japanese patients with type 2 diabetes in higashi-saitama (EPOCH Trial). Diabetes.
Atchison L, Steinke EL. (2011). Relationship between social and economic factors in diabetes medication-prescribing patterns. Journal of the American Pharmacists Association.
Aubert RE, Herrera V, Chen W, et al. (2010). Rosiglitazone and pioglitazone increase fracture risk in women and men with type 2 diabetes. Diabetes Obes Metab. Aydin Y, Erden M, Ermis F, et al. (2013). Oral antidiabetics and insulins do not increase cancer risk. Acta Medica Mediterranea.
Azar S, El-Mollayess GM, Al Shaar L, et al. (2013). Impact of thiazolidinediones on macular thickness and volume in diabetic eyes. Can J Ophthalmol.
Azar ST, Malha LP, Zantout MS, et al. (2013). Management and control of patients with type 2 diabetes mellitus in Lebanon: results from the International Diabetes Management Practices Study (IDMPS). J Med Liban.
Azoulay L, Dell'Aniello S, Gagnon B, et al. (2011). Metformin and the incidence of prostate cancer in patients with type 2 diabetes. Cancer Epidemiol Biomarkers Prev.
Azoulay L, Schneider-Lindner V, Dell'aniello S, et al. (2010). Combination therapy with sulfonylureas and metformin and the prevention of death in type 2 diabetes: a nested case-control study. Pharmacoepidemiol Drug Saf.
Azoulay L, Schneider-Lindner V, Dell'aniello S, et al. (2010). Thiazolidinediones and the risk of incident strokes in patients with type 2 diabetes: a nested case-control study. Pharmacoepidemiol Drug Saf.
Azoulay L, Yin H, Filion KB, et al. (2012). The use of pioglitazone and the risk of bladder cancer in patients with type 2 diabetes. Pharmacoepidemiology and Drug Safety.
Azoulay L, Yin H, Filion KB, et al. (2012). The use of pioglitazone and the risk of bladder cancer in people with type 2 diabetes: nested case-control study. BMJ.
Bach RG, Brooks MM, Lombardero M, et al. (2013). Rosiglitazone and outcomes for patients with diabetes mellitus and coronary artery disease in the Bypass Angioplasty Revascularization Investigation 2 Diabetes (BARI 2D) trial. Circulation.
Bailey CJ, Day C, Campbell IW, et al. (2012). Glycaemic control and cardiovascular outcome trials in type 2 diabetes. British Journal of Diabetes and Vascular Disease.
Bailey CJ, Gross JL, Bastone L, et al. (2009). Dapagliflozin as an add-on to metformin lowers hyperglycaemia in type 2 diabetes patients inadequately controlled with metformin alone. Diabetologia.
Bailey CJ, Gross JL, Hennicken D, et al. (2013). Correction to Dapagliflozin add-on to metformin in type 2 diabetes inadequately controlled with metformin: A randomized, double-blind, placebo-controlled 102-week trial. BMC Medicine.
Bailey CJ, Gross JL, Yadav M, et al. (2011). Sustained efficacy of dapagliflozin when added to metformin in type 2 diabetes inadequately controlled by metformin monotherapy. Diabetologia.
Bailey CJ, Iqbal N, T'Joen C, et al. (2012). Dapagliflozin monotherapy in drug-naive patients with diabetes: a randomized-controlled trial of low-dose range. Diabetes Obes Metab.
Bailey CJ, Morales Villegas EC, Woo V, et al. (2014). Efficacy and safety of dapagliflozin monotherapy in people with Type 2 diabetes: a randomized double-blind placebo-controlled 102-week trial. Diabet Med.
Bailey CJ, Wilding J, Nauck MA, et al. (2012). Sustained reductions in weight and HbA1c with dapagliflozin: Long-term results from phase III clinical studies in type 2 diabetes. Diabetologia.
Bailey RA, Damaraju CV, Martin SC, et al. (2014). Attainment of diabetes-related quality measures with canagliflozin versus sitagliptin. Am J Manag Care.
Bailey RA, Vijapurkar U, Martin S, et al. (2014). Composite quality measure (CQM) attainment in overweight/obese patients with type 2 diabetes mellitus treated with canagliflozin 300 mg (CANA) or sitagliptin 100 mg (SITA). Value in Health.
Bailey RA, Vijapurkar U, Meininger GE, et al. (2014). Diabetes-related quality measure attainment: canagliflozin versus sitagliptin based on a pooled analysis of 2 clinical trials. Am J Manag Care.
Bailey T, Pratley R, Buse J, et al. (2011). Liraglutide produces greater reductions in HbA1c levels compared with sitagliptin or exenatide across five baseline HbA1c categories. Diabetologia.
Bain SC, Skrivanek Z, Tahbaz A, et al. (2014). Efficacy of long-acting once weekly dulaglutide compared with short-acting twice daily (bid) exenatide in patients with Type 2 diabetes: A posthoc analysis to determine the influence of baseline HbA1c in the Assessment of Weekly Administration of LY2189265 in Diabetes-1 (AWARD-1) trial. Diabetic Medicine.
Bain SC, Stella P, Cao A. (2010). Significantly reduced body mass index with liraglutide 1.2 mg treatment versus glimepiride may have an impact on cardiovascular risk in patients with type 2 diabetes. Diabetic Medicine.
Balena R, Wintle M, Meloni A, et al. (2011). Exenatide once weekly, glycaemic goals, and selected cardiovascular risk factors in patients with T2DM: A retrospective analysis of pooled clinical trial data. Diabetes, Stoffwechsel und Herz.
Bannister CA, Holden SE, Jenkins-Jones S, et al. (2014). Can people with type 2 diabetes live longer than those without? A comparison of mortality in people initiated with metformin or sulphonylurea monotherapy and matched, non-diabetic controls. Diabetes Obes Metab.
Barnett A, Huisman H, Jones R, et al. (2012). Efficacy and safety of linagliptin in elderly patients ((greater-than or equal to) 70 years) with type 2 diabetes. Diabetes.
Barnett AH, Charbonnel B, Donovan M, et al. (2012). Effect of saxagliptin as add-on therapy in patients with poorly controlled type 2 diabetes on insulin alone or insulin combined with metformin. Curr Med Res Opin.
Barnett AH, Harper R, Toorawa R, et al. (2010). Linagliptin monotherapy improves glycaemic control in type 2 diabetes patients for whom metformin therapy is inappropriate. Diabetologia.
Barnett AH, Mithal A, Manassie J, et al. (2014). A phase III trial of empagliflozin in patients with Type 2 diabetes with stage 2 or 3 chronic kidney disease (EMPA-REG RENAL(trademark)). Diabetic Medicine.
Barnett AH, Mithal A, Manassie J, et al. (2014). Efficacy and safety of empagliflozin added to existing antidiabetes treatment in patients with type 2 diabetes and chronic kidney disease: A randomised, double-blind, placebo-controlled trial. The Lancet Diabetes and Endocrinology.
Barnett AH, Mithal A, Manassie J, et al. (2013). Empagliflozin in patients with type 2 diabetes mellitus (T2DM) and renal impairment (RI). Diabetes.
Barnett AH, Tahrani AA, Von Eynatten M, et al. (2011). The novel DPP-4 inhibitor linagliptin is associated with a very low risk of hypoglycemia: Results from a large phase III program. Diabetes.
Barrington P, Chien JY, Showalter HDH, et al. (2011). A 5-week study of the pharmacokinetics and pharmacodynamics of LY2189265, a novel, long-acting glucagon-like peptide-1 analogue, in patients with type 2 diabetes. Diabetes, Obesity and Metabolism.
Barthelemy M, Boullu Sanchis S, Moreau F, et al. (2014). Substitution of insulin by exenatide in bad controlled type 2 diabetic patients: efficacy and predictive factors. Minerva Endocrinol.
Barzilai N, Guo H, Mahoney EM, et al. (2011). Efficacy and tolerability of sitagliptin monotherapy in elderly patients with type 2 diabetes: a randomized, double-blind, placebo-controlled trial. Curr Med Res Opin.
Baser O, Tangirala K, Wei W, et al. (2013). Real-world outcomes of initiating insulin glargine-based treatment versus premixed analog insulins among US patients with type 2 diabetes failing oral antidiabetic drugs. ClinicoEconomics and Outcomes Research.
Baser O, Wei W, Baser E, et al. (2011). Clinical and economic outcomes in patients with type 2 diabetes initiating insulin glargine disposable pen versus exenatide BID. J Med Econ.
Baser O, Wei W, Baser E. (2011). Clinical and economic outcomes in patients with type 2 diabetes initiating insulin glargine using disposable pen versus exenatide. Journal of Managed Care Pharmacy.
Basile J, Ptaszynska A, Ying L, et al. (2012). The effects of dapagliflozin on cardiovascular risk factors in patients with type 2 diabetes mellitus. Circulation: Cardiovascular Quality and Outcomes.
Bayraktar S, Hernadez-Aya LF, Lei X, et al. (2012). Effect of metformin on survival outcomes in diabetic patients with triple receptor-negative breast cancer. Cancer.
Bazelier M, Gallagher A, Vestergaard P, et al. (2012). Use of thiazolidinediones and risk of osteoporotic fracture: Disease or drugs?. Osteoporosis International.
Bazelier MT, Gallagher AM, van Staa TP, et al. (2012). Use of thiazolidinediones and risk of osteoporotic fracture: disease or drugs?. Pharmacoepidemiol Drug Saf.
Belhadj M, Dahaoui A, Jamoussi H, et al. (2013). Exploring insulin analogue safety and effectiveness in a Maghrebian cohort with type 2 diabetes: Results from the A1chieve study. Diabetes Research and Clinical Practice.
Bell K, Hardy E, De Bruin T, et al. (2012). The effect of dapagliflozin on hedis performance measures of hba1c in patients with type 2 diabetes mellitus. Value in Health.
Bellary S. (2011). For type 2 diabetes poorly controlled by metformin monotherapy, the addition of any non-insulin antidiabetic drug reduces HbA1c to a similar extent, but with differing effects on weight and hypoglycaemic risk. Evidence-Based Medicine.
Bellows B, McAdam-Marx C, Unni S, et al. (2012). 12-month A1c and weight outcomes by drug class in treatment naive patients with type 2 diabetes. Journal of Managed Care Pharmacy.
Bellows BK, Ye X, Unni S, et al. (2012). Impact of anti-diabetic drug selection on weight change and hba1c outcomes in treatment naive patients with type 2 diabetes. Diabetes.
Bensimon L, Yin H, Suissa S, et al. (2014). The use of metformin in patients with prostate cancer and the risk of death. Cancer Epidemiol Biomarkers Prev.
Berard E, Bongard V, Arveiler D, et al. (2011). 14-year risk of all-cause mortality according to hypoglycemic drug exposure in a general population. European Heart Journal.
Berberoglu Z, Yazici AC, Bayraktar N, et al. (2012). Rosiglitazone decreases fasting plasma peptide YY3-36 in type 2 diabetic women: a possible role in weight gain?. Acta Diabetol.
Berberoglu Z, Yazici AC, Demirag NG. (2010). Effects of rosiglitazone on bone mineral density and remodelling parameters in Postmenopausal diabetic women: a 2-year follow-up study. Clin Endocrinol (Oxf).
Bergenstal R, Wysham C, Yan P, et al. (2010). Duration-2: Exenatide once weekly demonstrated significant glycaemic control and weight reduction compared to sitagliptin or pioglitazone after 26 weeks of treatment. Diabetic Medicine.
Bergenstal R, Wysham C, Yan P, et al. (2009). DurAtion-2: Exenatide once weekly demonstrated superior glycemic control and weight reduction compared to sitagliptin or pioglitazone after 26 weeks of treatment. Diabetes.
Bergenstal RM, Li Y, Porter TK, et al. (2013). Exenatide once weekly improved glycaemic control, cardiometabolic risk factors and a composite index of an HbA1c < 7%, without weight gain or hypoglycaemia, over 52 weeks. Diabetes Obes Metab.
Bergenstal RM, Rosenstock J, Arakaki RF, et al. (2012). A randomized, controlled study of once-daily LY2605541, a novel long-acting basal insulin, versus insulin glargine in basal insulin-treated patients with type 2 diabetes. Diabetes Care.
Berria R, Rosenstock J, Silberman C, et al. (2009). Weight loss and associated changes in glycaemic control and cardiovascular biomarkers in patients with type 2 diabetes mellitus receiving incretin therapies in a large cohort database. Diabetologia.
Berstein LM, Boyarkina MP, Teslenko SY. (2012). Familial diabetes is associated with reduced risk of cancer in diabetic patients: a possible role for metformin. Med Oncol.
Berthet S, Olivier P, Montastruc JL, et al. (2011). Drug safety of rosiglitazone and pioglitazone in France: a study using the French PharmacoVigilance database. BMC Clin Pharmacol.
Bertrand OF, Poirier P, Rodes-Cabau J, et al. (2010). Cardiometabolic effects of rosiglitazone in patients with type 2 diabetes and coronary artery bypass grafts: A randomized placebo-controlled clinical trial. Atherosclerosis.
Best JD, Drury PL, Davis TM, et al. (2012). Glycemic control over 5 years in 4,900 people with type 2 diabetes: real-world diabetes therapy in a clinical trial cohort. Diabetes Care.
Best JH, Hoogwerf BJ, Herman WH, et al. (2011). Risk of cardiovascular disease events in patients with type 2 diabetes prescribed the glucagon-like peptide 1 (GLP-1) receptor agonist exenatide twice daily or other glucose-lowering therapies: a retrospective analysis of the LifeLink database. Diabetes Care.
Best JH, Hoogwerf BJ, Pelletier EM, et al. (2010). Risk of cardiovascular events in patients with type 2 diabetes treated with exenatide or other glucose-lowering therapies: A retrospective analysis of the LifeLinkTM database. Diabetologia.
Best JH, Little W, Chiquette E, et al. (2011). The risk of heart failure among patients receiving exenatide versus other glucose-lowering medications for type 2 diabetes: A matched retrospective cohort analysis of the GE healthcare electronic medical record database. Diabetes.
Best JH, Pelletier E, Hoogwerf BJ, et al. (2010). Risk of cardiovascular events in patients with diabetes treated with exenatide or thiazolidinediones: A retrospective analysis of the pharmetrics database. Value in Health.
Best JH, Rubin RR, Peyrot M, et al. (2011). Weight-related quality of life, health utility, psychological well-being, and satisfaction with exenatide once weekly compared with sitagliptin or pioglitazone after 26 weeks of treatment. Diabetes Care.
Best JH, Wintle M, Saunders WB, et al. (2011). Glycemic outcomes among patients receiving exenatide bid or liraglutide for type 2 diabetes in clinical practice: A retrospective analysis of the ge centricity emr data. Value in Health.
Best JH, Yan P, Malloy J. (2009). DURATION 2: Weight-related quality of life, psychological well-being, and satisfaction with exenatide once weekly compared to sitagliptin or piaglitazone after 26 weeks of treatment. Diabetologia.
Bethel MA, Green JB, Milton J, et al. (2015). Regional, age and sex differences in baseline characteristics of patients enrolled in the Trial Evaluating Cardiovascular Outcomes with Sitagliptin (TECOS). Diabetes Obes Metab.
Bhushan R, Elkind-Hirsch KE, Bhushan M, et al. (2009). Improved glycemic control and reduction of cardiometabolic risk factors in subjects with type 2 diabetes and metabolic syndrome treated with exenatide in a clinical practice setting. Diabetes Technol Ther.
Bi Y, Yang H, Zhu D, et al. (2014). Effects of exenatide, insulin, and pioglitazone on liver fat content and body fat distributions in newly diagnosed subjects with type 2 diabetes. Diabetes.
Bilezikian J, Kravitz B, Lewiecki EM, et al. (2010). Effects of rosiglitazone on bone: Assessing qct parameters in a mechanistic study in postmenopausal women with type 2 diabetes mellitus. Journal of Bone and Mineral Research.
Blak BT, Rigney U, Ycas J, et al. (2013). Baseline characteristics, weight and glycaemic change among patients in the United Kingdom with type 2 diabetes mellitus (T2DM) prescribed a new antidiabetic treatment class in a real world setting. Value in Health.
Blickensderfer A, Pencek R, Li Y, et al. (2011). Exenatide once weekly: A retrospective analysis of pooled exenatide clinical trial efficacy data stratified by race, age, duration of diabetes, BMI and gender. Diabetologia.
Blin P, Lassalle R, Dureau C, et al. (2012). Insulin glargine and risk of cancer: A cohort study in the french national healthcare insurance database. Pharmacoepidemiology and Drug Safety.
Blin P, Lassalle R, Dureau-Pournin C, et al. (2012). Insulin glargine and risk of cancer: a cohort study in the French National Healthcare Insurance Database. Diabetologia.
Blonde L, Pencek R, MacConell L. (2015). Association among weight change, glycemic control, and markers of cardiovascular risk with exenatide once weekly: a pooled analysis of patients with type 2 diabetes. Cardiovasc Diabetol.
Blonde L, Rosenstock J, Sesti G, et al. (2009). Liraglutide provides superior glycaemic control vs exenatide when added to metformin and/or sulphonylurea (SU) in type 2 diabetes (T2DM). Journal of Diabetes.
Blonde L, Woo V, Mathieu C, et al. (2014). Achievement of diabetes-related treatment goals with canagliflozin (CANA) in patients with type 2 diabetes mellitus (T2DM). Diabetes.
Bloomgarden ZT. (2011). Type 2 diabetes: Uses of thiazolidinediones and insulin. Diabetes Care.
Bloomgren G, Dore D, Patterson R, et al. (2009). Incidence of acute pancreatitis in exenatide initiators compared to other antidiabetic drug initiators: A retrospective, cohort study. Diabetes.
Bo S, Ciccone G, Rosato R, et al. (2012). Cancer mortality reduction and metformin: a retrospective cohort study in type 2 diabetic patients. Diabetes Obes Metab.
Boardman MK, Hanefeld M, Kumar A, et al. (2011). DURATION-4: Improvements in glucose control and cardiovascular risk factors in patients with type 2 diabetes treated with exenatide once weekly, metformin, pioglitazone, or sitagliptin. Diabetologia.
Bode B, DeFronzo R, Bergenstal R, et al. (2014). Effect of liraglutide 3.0/1.8 mg on body weight and cardiometabolic risk factors in overweight/obese adults with type 2 diabetes: SCALE diabetes randomised, double-blind, 56-week trial. Diabetologia.
Bode B, Stenlof K, Harris S, et al. (2014). Long-term efficacy and safety of canagliflozin (CANA) in older patients with type 2 diabetes mellitus (T2DM) over 104 weeks. Diabetes.
Bode B, Stenlof K, Harris S, et al. (2015). Long-term efficacy and safety of canagliflozin over 104 weeks in patients aged 55-80 years with type 2 diabetes. Diabetes Obes Metab.
Bode B, Stenlof K, Sullivan D, et al. (2012). Efficacy and safety of canagliflozin (CANA), a sodium glucose cotransporter 2 inhibitor (SGLT2), in older subjects with type 2 diabetes mellitus. Diabetologia.
Bode B, Stenlof K, Sullivan D, et al. (2013). Efficacy and safety of canagliflozin treatment in older subjects with type 2 diabetes mellitus: a randomized trial. Hosp Pract (1995).
Bode BW, Brett J, Falahati A, et al. (2011). Comparison of the efficacy and tolerability profile of liraglutide, a once-daily human GLP-1 analog, in patients with type 2 diabetes >/=65 and <65 years of age: a pooled analysis from phase III studies. Am J Geriatr Pharmacother.
Bode BW, Testa MA, Magwire M, et al. (2010). Patient-reported outcomes following treatment with the human GLP-1 analogue liraglutide or glimepiride in monotherapy: results from a randomized controlled trial in patients with type 2 diabetes. Diabetes Obes Metab.
Bodmer M, Meier C, Krahenbuhl S, et al. (2010). Long-term metformin use is associated with decreased risk of breast cancer. Diabetes Care.
Bolinder J, Ljunggren O, Johansson L, et al. (2012). Dapagliflozin produces long-term reductions in body weight, waist circumference and total fat mass in patients with type 2 diabetes inadequately controlled on metformin. Diabetologia.
Bolliger D, Seeberger MD, Lurati Buse G, et al. (2012). The influence of pre-admission hypoglycaemic therapy on cardiac morbidity and mortality in type 2 diabetic patients undergoing major non-cardiac surgery: A prospective observational study. Anaesthesia.
Bonds DE, Miller ME, Dudl J, et al. (2012). Severe hypoglycemia symptoms, antecedent behaviors, immediate consequences and association with glycemia medication usage: Secondary analysis of the ACCORD clinical trial data. BMC Endocrine Disorders.
Bonora E, Minervini G, Cook W, et al. (2014). Saxagliptin reduces A1C and is well tolerated in patients with type 2 diabetes and high framingham cardiovascular risk or albuminuria. Endocrine Practice.
Bosco JL, Antonsen S, Sorensen HT, et al. (2011). Metformin and incident breast cancer among diabetic women: a population-based case-control study in Denmark. Cancer Epidemiol Biomarkers Prev.
Bosi E, Ellis G, Moneuse P, et al. (2010). Addition of alogliptin vs uptitration of pioglitazone dose in type 2 diabetes mellitus patients on metformin plus pioglitazone therapy. Diabetologia.
Boule NG, Kenny GP, Larose J, et al. (2013). Does metformin modify the effect on glycaemic control of aerobic exercise, resistance exercise or both?. Diabetologia.
Bouzamondo H, Karyekar C, Berglind N, et al. (2011). Saxagliptin (SAXA) vs Glipizide (GLIP) as add-on therapy to metformin (MET) for type 2 diabetes (T2D): Assessment of HbA1c, hypoglycemia, and weight gain. Diabetes.
Bowker S, Yasui Y, Veugelers P, et al. (2009). Effect of glitazones on cancer mortality in type 2 diabetes. Canadian Journal of Diabetes.
Bowker SL, Yasui Y, Veugelers P, et al. (2010). Glucose-lowering agents and cancer mortality rates in type 2 diabetes: assessing effects of time-varying exposure. Diabetologia.
Boyko EJ, Wheeler S, Moore K, et al. (2013). Mortality among veterans with type 2 diabetes initiating metformin, sulfonylurea, or rosiglitazone monotherapy. Diabetes.
Boyle J, Fisher M. (2010). The addition of insulin to metformin and sulphonylureas: Results of the 4-T study. Practical Diabetes International.
Brady EM, Davies MJ, Gray LJ, et al. (2014). A randomized controlled trial comparing the GLP-1 receptor agonist liraglutide to a sulphonylurea as add on to metformin in patients with established type 2 diabetes during Ramadan: the Treat 4 Ramadan Trial. Diabetes Obes Metab.
Brady EM, Davies MJ, Gray LJ, et al. (2013). Treat 4 Ramadan trial: A randomised control trial comparing liraglutide vs a sulphonylurea as add-on to metformin in patients with established type 2 diabetes. Diabetologia.
Brake JA, Hopkins M, Greenwood A, et al. (2009). First three months data from an observational study in people with diabetes commenced on exenatide within a large diabetes centre in both insulin treated and insulin naive patients. Diabetic Medicine.
Bravis V, Hui E, Gohel B, et al. (2009). Impact of the READ (Ramadan focused Education and Awareness in Diabetes) programme on HbA1c, weight and hypoglycaemia. Diabetologia.
Bray GA, Smith SR, Banerji M, et al. (2012). Effect of pioglitazone on body fat and bone mineral content in the act now trial. Diabetes.
Breunig IM, Shaya FT, McPherson ML, et al. (2014). Development of heart failure in medicaid patients with type 2 diabetes treated with pioglitazone, rosiglitazone, or metformin. J Manag Care Pharm.
Brixner D, McAdam-Marx C, Ye X, et al. (2009). 18 Month A1C and weight outcomes of exenatide therapy in patients with type-2 diabetes in a real-world study. Value in Health.
Brodovicz KG, Kou TD, Alexander CM, et al. (2013). Recent trends in the characteristics of patients prescribed sitagliptin and other oral antihyperglycaemic agents in a large U.S. claims database. Int J Clin Pract.
Bron M, Chen K, Cheng D, et al. (2012). Comparison of clinical and economic outcomes associated with dpp4 inhibitors (DPP4I) versus sulfonylurea (SU) in combination with metformin (MET) or pioglitazone (PIO) for the treatment of type 2 diabetes mellitus (T2DM). Value in Health.
Bron M, Marynchenko M, Yang H, et al. (2011). Hypoglycaemia in adult vs. elderly type 2 diabetes mellitus patients: Risks, costs, and impact on treatment persistence in a U.S. population. Diabetologia.
Bron M, Marynchenko M, Yang H, et al. (2011). Hypoglycemia in adult vs elderly type 2 diabetes mellitus patients: Risks, costs, and impact on treatment persistence. Diabetes.
Bron M, Marynchenko M, Yang H, et al. (2012). Hypoglycemia, treatment discontinuation, and costs in patients with type 2 diabetes mellitus on oral antidiabetic drugs. Postgrad Med.
Brouwer ES, West SL, Kluckman M, et al. (2012). Initial and subsequent therapy for newly diagnosed type 2 diabetes patients treated in primary care using data from a vendor-based electronic health record. Pharmacoepidemiol Drug Saf.
Brown B, Sharp P. (2009). Predictive factors in glycaemic response to exenitide and sitagliptin treatment. Diabetic Medicine.
Bruderer SG, Bodmer M, Jick SS, et al. (2014). Incidence of and risk factors for severe hypoglycaemia in treated type 2 diabetes mellitus patients in the UK - a nested case-control analysis. Diabetes Obes Metab.
Bruderer SG, Jick SS, Bader G, et al. (2013). Incidence of and risk factors for severe hypoglycemia in treated type 2 diabetes mellitus patients in the United Kingdom. International Journal of Clinical Pharmacy.
Bruhn C. (2011). Treatment of type 2 diabetes: Exenatide for once weekly application. Deutsche Apotheker Zeitung.
Brunell SC, Pencek R, Li Y, et al. (2012). Exenatide once weekly was associated with improved glycemic control regardless of baseline body weight. Diabetes.
Bryzinski B, Allen E, Cook W, et al. (2014). Saxagliptin efficacy and safety in patients with type 2 diabetes receiving concomitant statin therapy. J Diabetes Complications.
Bunck MC, Cornér A, Eliasson B, et al. (2011). Effects of exenatide on measures of ?-cell function after 3 years in metformin-treated patients with type 2 diabetes. Diabetes care.
Bunck MC, Corner A, Eliasson B, et al. (2011). Effects of exenatide on measures of beta-cell function after 3 years in metformin-treated patients with type 2 diabetes. Diabetes Care.
Bunck MC, Corner A, Eliasson B, et al. (2010). Extended, 3-year, exenatide therapy shows sustainable effects on beta cell disposition index in metformin treated patients with type 2 diabetes. Diabetologia.
Bunck MC, Diamant M, Corner A, et al. (2009). One-year treatment with exenatide improves beta-cell function, compared with insulin glargine, in metformin-treated type 2 diabetic patients: a randomized, controlled trial. Diabetes Care.
Bunck MC, Corner A, Eliasson B, et al. (2009). One year exenatide therapy, compared with insulin glargine, reduces postprandial oxidative stress in metformin-treated patients with type 2 diabetes. Diabetes.
Bunck MC, Diamant M, Eliasson B, et al. (2009). Beneficial changes on body composition and circulating adiponectin and hsCRP Levels following one year of exenatide therapy, compared with insulin glargine, in metformin-treated patients with type 2 diabetes. Diabetes.
Burant C, Fleck P, Wilson C, et al. (2009). Effect of alogliptin combined with pioglitazone on beta cell function and insulin resistance in metformin-treated patients with type 2 diabetes. Diabetologia.
Burant CF, Viswanathan P, Marcinak J, et al. (2012). TAK-875 versus placebo or glimepiride in type 2 diabetes mellitus: a phase 2, randomised, double-blind, placebo-controlled trial. Lancet.
Burr N, Talboys R, Savva S, et al. (2012). Type 2 diabetes as a positive risk factor in the aetiology of cholangiocarcinoma: A case-control study in two UK centres. Gut.
Buse J, Sesti G, Schmidt WE, et al. (2009). Glycaemic control improves in type 2 diabetes patients when switching from twice-daily exenatide to once-daily liraglutide. Canadian Journal of Diabetes.
Buse JB, Garber A, Rosenstock J, et al. (2011). Liraglutide treatment is associated with a low frequency and magnitude of antibody formation with no apparent impact on glycemic response or increased frequency of adverse events: results from the Liraglutide Effect and Action in Diabetes (LEAD) trials. J Clin Endocrinol Metab.
Buse JB, Nauck M, Forst T, et al. (2013). Exenatide once weekly versus liraglutide once daily in patients with type 2 diabetes (DURATION-6): a randomised, open-label study. Lancet.
Buse JB, Nauck MA, Forst T, et al. (2011). Efficacy and safety of exenatide once weekly versus liraglutide in subjects with type 2 diabetes (DURATION-6): A randomised, open-label study. Diabetologia.
Buse JB, Peters A, Russell-Jones D, et al. (2015). Is insulin the most effective injectable antihyperglycaemic therapy?. Diabetes Obes Metab.
Buse JB, Wolffenbuttel BHR, Herman WH, et al. (2011). The DURAbility of basal versus lispro mix 75/25 insulin efficacy (DURABLE) trial: Comparing the durability of lispro mix 75/25 and glargine. Diabetes Care.
Buysschaert M, Claessens A, Damoiseaux P, et al. (2010). Short and medium term effects of exenatide treatment in a cohort of type 2 diabetic patients: Results of a multicentric study within the diabetologists network of UCL. Louvain Medical.
Cai B, Katz L, Alexander CM, et al. (2010). Characteristics of patients prescribed sitagliptin and other oral antihyperglycaemic agents in a large US claims database. Int J Clin Pract.
Calvo Romero JM, Ramiro Lozano JM. (2012). Vitamin B(12) in type 2 diabetic patients treated with metformin. Endocrinol Nutr.
Camisasca R, Bron M, Fleck P, et al. (2014). Alogliptin superior to glipizide in composites of a1c reduction, no hypoglycemia, and no weight gain in patients with T2DM. Diabetes.
Campia U, Barac A, Matuskey LA, et al. (2010). Oral hypoglycemic treatment may lower vascular endothelin-1 activity in type 2 diabetic patients: A pilot study. Arteriosclerosis, Thrombosis, and Vascular Biology.
Carney GA, Bassett K, Wright JM, et al. (2012). Is thiazolidinediones use a factor in delaying the need for insulin therapy in type 2 patients with diabetes? A population-based cohort study. BMJ Open.
Cefalu WT, Gause-Nilsson IA, De Bruin TW, et al. (2014). Long-term efficacy and safety of dapagliflozin in patients with type 2 diabetes, cardiovascular disease, and hypertension. Diabetes.
Cefalu WT, Leiter LA, Debruin TW, et al. (2012). Dapagliflozin treatment for type 2 diabetes mellitus patients with comorbid cardiovascular disease and hypertension. Diabetes.
Cerdas S, Leiter LA, Blonde L, et al. (2014). Glycaemic efficacy of canagliflozin by baseline HbA1c and known duration of type 2 diabetes mellitus. Diabetologia.
Chaiteerakij R, Baichoo E, Roberts LR. (2013). Metformin use improves survival of cholangiocarcinoma (CC) patients with type II diabetes (DM). Hepatology.
Chakraborty A, Chowdhury S, Bhattacharyya M. (2011). Effect of metformin on oxidative stress, nitrosative stress and inflammatory biomarkers in type 2 diabetes patients. Diabetes Res Clin Pract.
Chakreeyarat S, Saetung S, Chailurkit LO, et al. (2011). Elevated vitamin D status in postmenopausal women on thiazolidinediones for type 2 diabetes. Endocrine.
Chang CH, Chang YC, Lin JW, et al. (2014). Comparative effectiveness of several second-line dual oral antidiabetic combinations in reducing cardiovascular events in type 2 diabetes-a nationwide study. Diabetes.
Chang CH, Lin JW, Wu LC, et al. (2012). Association of thiazolidinediones with liver cancer and colorectal cancer in type 2 diabetes mellitus. Hepatology.
Chang CH, Lin JW, Wu LC, et al. (2012). Oral insulin secretagogues, insulin, and cancer risk in type 2 diabetes mellitus. J Clin Endocrinol Metab.
Chao TF, Leu HB, Huang CC, et al. (2012). Thiazolidinediones can prevent new onset atrial fibrillation in patients with non-insulin dependent diabetes. Int J Cardiol.
Chaudhuri A, Rosenstock J, DiGenio A, et al. (2012). Comparing the effects of insulin glargine and thiazolidinediones on plasma lipids in type 2 diabetes: a patient-level pooled analysis. Diabetes Metab Res Rev.
Chavez AO, Guardado-Mendoza R, Cortez L, et al. (2011). Differential effect of pioglitazone, exenatide and combination of pioglitazone and exenatide on adipocyte insulin resistance in type 2 diabetes. Diabetes.
Chavez AO, Guardado-Mendoza R, King JW, et al. (2011). Differential effect of pioglitazone, exenatide and combination of pioglitazone and exenatide on adipocyte insulin resistance in type 2 diabetes. Diabetologia.
Chen DY, Wang SH, Mao CT, et al. (2014). Sitagliptin and cardiovascular outcomes in diabetic patients with chronic kidney disease and acute myocardial infarction: A nationwide cohort study. Int J Cardiol.
Chen R, Xu Z, Duan Y, et al. (2009). Reaching HbA1c goals with saxagliptin in combination with metformin or sulfonylurea. Diabetologia.
Chen SW, Tsan YT, Chen JD, et al. (2013). Use of thiazolidinediones and the risk of colorectal cancer in patients with diabetes: a nationwide, population-based, case-control study. Diabetes Care.
Chen TM, Lin CC. (2012). Metformin associated with lower mortality in diabetic patients with early stage hepatocellular carcinoma after radiofrequency ablation. Hepatology International.
Chen Y, Ning G, Wang C, et al. (2013). Efficacy and safety of linagliptin monotherapy in Asian patients with inadequately controlled type 2 diabetes mellitus: A 24-Week, randomized, phase III clinical trial. Diabetes.
Cheng YY, Leu HB, Chen TJ, et al. (2014). Metformin-inclusive therapy reduces the risk of stroke in patients with diabetes: a 4-year follow-up study. J Stroke Cerebrovasc Dis.
Cherney D, Von Eynatten M, Lund SS, et al. (2014). Sodium glucose cotransporter 2 inhibition with empagliflozin reduces microalbuminuria in patients with type 2 diabetes. Diabetologia.
Chiang HH, Tseng FY, Wang CY, et al. (2014). All-cause mortality in patients with type 2 diabetes in association with achieved hemoglobin A1c, systolic blood pressure, and low-density lipoprotein cholesterol levels. PLoS ONE.
Chiefari E, Capula C, Vero A, et al. (2015). Add-On Treatment with Liraglutide Improves Glycemic Control in Patients with Type 2 Diabetes on Metformin Therapy. Diabetes Technol Ther.
Chien CY, Fang FM, Huang CC. (2011). Improved survival among advanced oral cancer patients taking metformin for diabetes mellitus control. Oral Oncology.
Chilton R, Tikkanen I, Crowe S, et al. (2014). Empagliflozin reduces systolic blood pressure in dipper and non-dipper patients with type 2 iabetes and hypertension. Circulation.
Chilton RJ, MacConell LA, Han JC, et al. (2013). Characterization of heart rate increases with glucagon-like peptide-1 agonist therapy. Circulation.
Chiquette E, Toth PP, Ramirez G, et al. (2012). Treatment with exenatide once weekly or twice daily for 30 weeks is associated with changes in several cardiovascular risk markers. Vasc Health Risk Manag.
Chirila C, Ziemiecki R, Davenport E, et al. (2014). Health-related quality of life analysis for patients with type 2 diabetes mellitus treated with empagliflozin. Value in Health.
Cho SJ, Kim YI, Kim SY, et al. (2014). Long-term metformin use reduces gastric cancer risk in type 2 diabetics without insulin treatment: A nationwide cohort study. Cancer Research.
Chou HC, Chen WW, Hsiao FY. (2014). Acute pancreatitis in patients with type 2 diabetes mellitus treated with dipeptidyl peptidase-4 inhibitors: a population-based nested case-control study. Drug Saf.
Choy-Shan A, Zinn A, Shah B, et al. (2012). Effect of rosiglitazone on survival in patients with diabetes mellitus treated for coronary artery disease. Coron Artery Dis.
Chraibi A, Ajdi F, Belkhadir J, et al. (2013). Safety and effectiveness of insulin analogues in Moroccan patients with type 2 diabetes: A sub-analysis of the A1chieve study. Diabetes Research and Clinical Practice.
Clemens KK, McArthur E, Fleet JL, et al. (2015). The risk of pancreatitis with sitagliptin therapy in older adults: a population-based cohort study. CMAJ Open.
Colette C, Boegner C, Michel F, et al. (2009). Comparative effects of glimepiride and rosiglitazone on glycemic disorders and oxidative stress in type 2 diabetes. Journal of Diabetes.
Colhoun HM, Livingstone SJ, Looker HC, et al. (2012). Hospitalised hip fracture risk with rosiglitazone and pioglitazone use compared with other glucose-lowering drugs. Diabetologia.
Cook W, Bryzinski B, Slater J, et al. (2012). Efficacy and safety of saxagliptin (SAXA) in patients with type 2 diabetes and a history of cardiovascular disease. Diabetologia.
Cook W, Bryzinski B, Slater J, et al. (2013). Saxagliptin efficacy and safety in patients with type 2 diabetes mellitus and cardiovascular disease history or cardiovascular risk factors: results of a pooled analysis of phase 3 clinical trials. Postgrad Med.
Cooper M, Von Eynatten M, Emser A, et al. (2011). Efficacy and safety of linagliptin in patients with type 2 diabetes with or without renal impairment: Results from a global phase 3 program. Diabetes.
Cotugno M, Nosso G, Saldalamacchia G, et al. (2014). Clinical efficacy of bariatric surgery versus liraglutide in patients with type 2 diabetes and severe obesity: a 12-month retrospective evaluation. Acta Diabetol.
Cucinotta D, Caputo S, Mannucci E, et al. (2012). Safety and efficacy of insulin aspart and soluble human insulin in Type 2 diabetes mellitus. Minerva Endocrinol.
Cuddihy R, Tack CJ, Heise T, et al. (2010). Once-daily use of a new generation ultra-long acting basal insulin with a bolus boost in insulin-naive people with type 2 diabetes: Comparison with insulin glargine. Diabetologia.
Cuddihy RM, Russell-Jones D, Hanefeld M, et al. (2011). Efficacy and safety of exenatide once weekly versus metformin, pioglitazone, and sitagliptin used as monotherapy in drug-naive patients with type 2 diabetes. Diabetes.
Currie CJ, Evans M, Poole CD, et al. (2011). Retrospective evaluation of the safety of exogenous insulin in people with type 2 diabetes: Cardiovascular events, stroke, cancers, all-cause mortality and a combined endpoint. Diabetologia.
Currie CJ, Jenkins-Jones S, Mukherjee J, et al. (2013). Combination therapy with metformin plus sulfonylureas versus metformin plus DPP-4 inhibitors and risk of all-cause mortality. Diabetologia.
Currie CJ, Poole CD, Evans M, et al. (2013). Mortality and other important diabetes-related outcomes with insulin vs other antihyperglycemic therapies in type 2 diabetes. J Clin Endocrinol Metab.
Currie CJ, Poole CD, Jenkins-Jones S, et al. (2012). Mortality after incident cancer in people with and without type 2 diabetes: impact of metformin on survival. Diabetes Care. Currie CJ. (2009). The longest ever randomised controlled trial of insulin glargine: Study design and HbA1c findings. Diabetologia.
Cusi K, Orsak B, Lomonaco R, et al. (2013). Extended treatment with pioglitazone improves liver histology in patients with prediabetes or type 2 diabetes mellitus and NASH. Hepatology.
D'Alessio D, Haring HU, Charbonnel B, et al. (2015). Comparison of insulin glargine and liraglutide added to oral agents in patients with poorly controlled type 2 diabetes. Diabetes Obes Metab.
Daniele G, Perez-Cadena Z, Chavez-Velasquez A, et al. (2012). Low-dose (15 mg/day) pioglitazone treatment improves glycemic and sub-inflammatory state in obese type 2 diabetic subjects in 24 week intervention study. Diabetes.
Danyarova L, Raisova A. (2013). Experience of using sitagliptin in Kazakhstan. Diabetes Technology and Therapeutics.
Das P, Das BP, Rauniar GP, et al. (2011). Drug utilization pattern and effectiveness analysis in diabetes mellitus at a tertiary care centre in eastern Nepal. Indian J Physiol Pharmacol.
Davidson JA, Lajara R, Aguilar RB, et al. (2014). Efficacy and safety of linagliptin in Hispanic/Latino patients with type 2 diabetes mellitus: a pooled analysis from six randomized placebo-controlled phase 3 trials. BMJ Open Diabetes Res Care.
Davidson M, McNair D, Mattison D, et al. (2013). Clinical and pharmacovigilance approaches for exploring an electronic medical record dataset of Type II diabetics and thiazolidinedione drug safety. European Journal of Epidemiology.
Davidson MH, Beam CA, Haffner S, et al. (2010). Pioglitazone versus glimepiride on coronary artery calcium progression in patients with type 2 diabetes mellitus: a secondary end point of the CHICAGO study. Arterioscler Thromb Vasc Biol.
Davies M, Atkin S, Bain SC, et al. (2014). Efficacy and safety of liraglutide vs. placebo as add-on to existing diabetes medication in subjects with type 2 diabetes (T2DM) and moderate renal impairment (LIRA-RENAL). Diabetes.
Davies M, Bode BW, Kushner RF, et al. (2014). Liraglutide 3.0 mg for weight management in obese/overweight adults with type 2 diabetes: Results from the Scale(trademark) diabetes 56-week randomized, double-blind, placebo-controlled trial. Diabetes.
Davies M, Heller S, Sreenan S, et al. (2013). Once-weekly exenatide vs once- or twicedaily insulin detemir: Randomised, openlabel clinical trial of efficacy and safety in patients with Type 2 diabetes inadequately controlled with metformin alone or with sulphonylureas. Diabetic Medicine.
Davies M, Nauck M, Bailey T, et al. (2010). Better glycaemic control and weight reduction with liraglutide, a once-daily human GLP-1 analogue, compared with sitagliptin, a DPP-4 inhibitor, both in combination with metformin in type 2 diabetes. Diabetic Medicine.
Davies M, Nauck M, Bailey T, et al. (2011). Liraglutide treatment for 1 year offers more effective glycaemic control and weight reduction compared with sitagliptin, both in combination with metformin, in type 2 diabetes. Journal of Diabetes.
Davies M, Nauck M, Bailey T, et al. (2011). The GLP-1 analogue liraglutide provides more effective glycaemic control and weight reduction over one year compared with sitagliptin, a DPP-4 inhibitor, In patients with Type 2 diabetes inadequately controlled with metformin. Diabetic Medicine.
Davies M, Pratley R, Montanya E, et al. (2011). Liraglutide reduces hba1c to a greater extent than sitagliptin regardless of baseline hba1c. Journal of Diabetes.
Davies MJ, Brady EM, Gray LJ, et al. (2013). Treat 4 ramadan: A randomised control trial comparing liraglutide vs. A sulphonylurea as add-on to metformin in patients with established type 2 diabetes. Diabetes.
Davies MJ, Pratley RE, Nauck MA, et al. (2012). Improved treatment satisfaction in patients with Type 2 diabetes who switched from sitagliptin to liraglutide, both added to metformin. Diabetic Medicine.
de Boer RA, Martens FM, Kuipers I, et al. (2010). The effects of the PPAR-gamma agonist pioglitazone on plasma concentrations of circulating vasoactive factors in type II diabetes mellitus. J Hum Hypertens.
De Bruin TW, Leiter LA, Cefalu WT, et al. (2013). Dapagliflozin in patients with type 2 diabetes and established cardiovascular disease: Hypotension and volume-related safety. Circulation.
De Fronzo R, Burant CF, Fleck P, et al. (2009). Combination alogliptin plus pioglitazone treatment in patients with type 2 diabetes receiving metformin. Canadian Journal of Diabetes.
DeFronzo R, Burant C, Fleck P, et al. (2009). Effect of alogliptin combined with pioglitazone on glycaemic control in metformin-treated patients with type 2 diabetes. Diabetologia.
Defronzo RA, Bode BW, Kushner RF, et al. (2014). Effects of liraglutide 3.0 mg cessation on efficacy and safety/ tolerability following a 56-week randomized treatment period in obese/overweight adults with type 2 diabetes (Scale(trademark) diabetes). Diabetes.
Defronzo RA, Burant CF, Fleck P, et al. (2009). Effect of alogliptin combined with pioglitazone on glycemic control in metformin-treated patients with type 2 diabetes. Diabetes.
DeFronzo RA, Fleck PR, Wilson CA, et al. (2008). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor alogliptin in patients with type 2 diabetes and inadequate glycemic control: a randomized, double-blind, placebo-controlled study. Diabetes Care.
DeFronzo RA, Lewin A, Patel S, et al. (2015). Combination of empagliflozin and linagliptin as second-line therapy in subjects with type 2 diabetes inadequately controlled on metformin. Diabetes Care.
Defronzo RA, Triplitt C, Qu Y, et al. (2009). Effects of exenatide plus rosiglitazone on beta cell function and insulin sensitivity in subjects with type 2 diabetes on metformin. Diabetes.
Degli Esposti L, Saragoni S, Buda S, et al. (2014). Clinical outcomes and health care costs combining metformin with sitagliptin or sulphonylureas or thiazolidinediones in uncontrolled type 2 diabetes patients. Clinicoecon Outcomes Res.
Del Prato S, Barnett AH, Huisman H, et al. (2011). Effect of linagliptin monotherapy on glycaemic control and markers of beta-cell function in patients with inadequately controlled type 2 diabetes: a randomized controlled trial. Diabetes Obes Metab.
Del Prato S, Camisasca R, Wilson C, et al. (2013). Durability of the efficacy and safety of alogliptin compared to glipizide over 2 years when used in combination with metformin. Diabetologia.
Del Prato S, Camisasca R, Wilson C, et al. (2013). Durability of the efficacy and safety of alogliptin compared to glipizide when used in combination with metformin: 1 year interim analysis. Diabetes.
Del Prato S, Lucchesi D, Pucci L, et al. (2013). Effects of pioglitazone on endothelial progenitor cells in type 2 diabetic patients with vascular complications: The splendor study. Diabetes.
Del Prato S, Nauck M, Rohwedder K, et al. (2014). Durability of glycaemic response with dapagliflozin as add-on therapy in type 2 diabetes inadequately controlled with metformin; 4-year data versus glipizide. Diabetologia.
Del Prato S, Nauck MA, Rohwedder K, et al. (2011). Long-term efficacy and safety of add-on dapagliflozin vs add-on glipizide in patients with type 2 diabetes mellitus inadequately controlled with metformin: 2-year results. Diabetologia.
Del Prato S, Taskinen MR, Owens D, et al. (2011). Efficacy and safety of linagliptin in patients with type 2 diabetes and poor glycemic control. Diabetes.
Delgado E. (2012). Outcomes with insulin glargine in patients with type 2 diabetes previously on NPH insulin: Evidence from clinical practice in Spain. International Journal of Clinical Practice.
Derosa G, Putignano P, Bossi AC, et al. (2011). Exenatide or glimepiride on insulin resistance in type 2 diabetic patients. Diabetes.
Derosa G, Ragonesi PD, Salvadeo SAT, et al. (2009). Effects of exenatide compared to glibenclamide on glycemic control and on insulin resistance in type 2 diabetic patients with metformin therapy. Diabetes.
Detournay B, Dejager S, Robert J. (2014). Hospitalisation frequency for hypoglycaemia and emergency calls in type 2 diabetes mellitus patients exposed to vildagliptin vs insulin-secretagogues in the French Health Insurance database. Diabetologia.
Devineni D, Morrow L, Hompesch M, et al. (2012). Canagliflozin improves glycaemic control over 28 days in subjects with type 2 diabetes not optimally controlled on insulin. Diabetes Obes Metab.
DeVries JH, Meneghini L, Barnett AH, et al. (2014). A patient-level analysis of efficacy and hypoglycaemia outcomes across treat-to-target trials with insulin glargine added to oral antidiabetes agents in people with type 2 diabetes. European Endocrinology.
Dhananjayan R, Srivani Koundinya KS, Malati T, et al. (2014). Effect of metformin, glimepiride and gliclazide on intimal medial thickening of carotid artery in type 2 diabetes mellitus. Biomedicine (India).
Dhar K, Chopra VS, Raina RS. (2013). Drug prescribing pattern of oral antidiabetic drugs and their comparative efficacy in glycemic control in type-2 diabetes mellitus. International Journal of Pharmaceutical Research.
Diamant M, Van Gaal L, Guerci B, et al. (2014). Exenatide once weekly versus insulin glargine for type 2 diabetes (DURATION-3): 3-year results of an open-label randomised trial. Lancet Diabetes Endocrinol.
Diamant M, Van Gaal LF, Stranks SN, et al. (2010). Impact of exenatide once weekly and insulin glargine on glucose control and cardiovascular risk f actors in subjects with type 2 diabetes. Diabetologia.
Diamant M, VanGaal L, Stranks S, et al. (2011). DURATION-3: Changes in cardiovascular risk factors observed in patients with type 2 diabetes after 84-week therapy with exenatide once weekly or insulin glargine. Diabetologia.
Diels J, Angermund R, Schroeder M, et al. (2014). The efficacy and effectiveness in HbA1c-lowering is dependent on baseline body mass index (BMI) for sitagliptin but not canagliflozin in the treatment of type 2 diabetes mellitus (T2DM). Value in Health.
Diop SN, Wade A, Lokrou A, et al. (2013). Management of type 2 diabetes in clinical practices in sub-Saharan Africa: Results of the AMAR-AFO study in Senegal and Ivory Cost. Medecine des Maladies Metaboliques.
Distiller LA, Polakow ES, Joffe BI. (2014). Type 2 diabetes mellitus and hypothyroidism: the possible influence of metformin therapy. Diabet Med.
Dittrich S, Bazelier MT, Vestergaard P, et al. (2013). Use of biguanides and the risk of colorectal cancer. Pharmacoepidemiology and Drug Safety.
Doehner W, Erdmann E, Cairns R, et al. (2009). Effects of pioglitazone on body weight in the PROactive study population: The obesity paradox in type 2 DM patents with high risk of cardiovascular events. European Heart Journal.
Donadon V, Balbi M, Mas MD, et al. (2010). Metformin and reduced risk of hepatocellular carcinoma in diabetic patients with chronic liver disease. Liver Int.
Donadon V, Balbi M, Valent F, et al. (2010). Glycated hemoglobin and antidiabetic strategies as risk factors for hepatocellular carcinoma. World J Gastroenterol.
Dore DD, Bloomgren GL, Wenten M, et al. (2011). A cohort study of acute pancreatitis in relation to exenatide use. Diabetes Obes Metab.
Dormuth CR, Carney G, Sutherland J. (2010). Delayed progression to insulin in patients with type 2 diabetes mellitus treated with thiazolidinediones: A population-based cohort study. Pharmacoepidemiology and Drug Safety.
Dormuth CR, Maclure M, Carney G, et al. (2009). Rosiglitazone and myocardial infarction in patients previously prescribed metformin. PLoS One.
Doucet J, Chacra A, Maheux P, et al. (2011). Efficacy and safety of saxagliptin in older patients with type 2 diabetes mellitus. Curr Med Res Opin.
Doucet J, Kerlan V, Verges B, et al. (2010). LIGHT study: Initiation of long-acting insulin analogues in elderly type 2 diabetic patients. Journal of the American Geriatrics Society.
Dover A, Kockum L, Walker J, et al. (2012). Efficacy and side effects of liraglutide compared with exenatide therapy. Diabetic Medicine.
Drake T, Hire D, Seaquist E. (2013). Achieving goal hemoglobin A1C in the standard therapy group of the ACCORD trial. Diabetes.
Driessen JHM, Van Onzenoort HA, Lalmohamed A, et al. (2013). Use of glucagon-like peptide 1 analogues and the risk of fracture in type 2 diabetes patients. Pharmacoepidemiology and Drug Safety.
Dworak M, Gruenberger JB, Bader G, et al. (2012). Incidence of cardiovascular events in patients with type 2 diabetes mellitus treated with DPP-4 inhibitors and sulfonylureas in clinical practice in Germany and the UK: A retrospective analysis. Diabetologia.
Echtay A, Tsur A, Hasan MI, et al. (2013). Clinical experience with insulin detemir in patients with type 2 diabetes from the near East Countries. Diabetes Therapy.
Ekstrom N, Miftaraj M, Svensson AM, et al. (2012). Glucose-lowering treatment and clinical results in 163 121 patients with type 2 diabetes: an observational study from the Swedish national diabetes register. Diabetes Obes Metab.
Ekstrom N, Schioler L, Svensson AM, et al. (2012). Benefits and risks of glucose-lowering treatments with particular emphasis on metformin: Nationwide epidemiological study. Diabetes.
Eliasson B, Moller-Goede D, Eeg-Olofsson K, et al. (2012). Lowering of postprandial lipids in individuals with type 2 diabetes treated with alogliptin and/or pioglitazone: a randomised double-blind placebo-controlled study. Diabetologia.
Engel S, Arjona Ferreira JC, Guo H, et al. (2012). Consistency of HbA1c-lowering effects of sitagliptin vs glipizide in patients with type 2 diabetes and chronic renal insufficiency across a variety of baseline characteristics. Diabetologia.
Engel SS, Golm GT, Shapiro D, et al. (2013). Cardiovascular safety of sitagliptin in patients with type 2 diabetes mellitus: a pooled analysis. Cardiovasc Diabetol.
Engel SS, Round E, Golm GT, et al. (2013). Safety and tolerability of sitagliptin in type 2 diabetes: pooled analysis of 25 clinical studies. Diabetes Ther.
Engel SS, Seck TL, Golm GT, et al. (2013). Assessment of AACE/ACE recommendations for initial dual antihyperglycemic therapy using the fixed-dose combination of sitagliptin and metformin versus metformin. Endocr Pract.
Engel SS, Teng R, Davies MJ, et al. (2011). Influence of baseline glycemic control on sitagliptin-induced weight loss in patients with type 2 diabetes. Diabetes.
Engel SS, Williams-Herman DE, Golm GT, et al. (2010). Sitagliptin: review of preclinical and clinical data regarding incidence of pancreatitis. Int J Clin Pract.
Engel SS, Xu L, Golm GT, et al. (2013). Comparison of treatment with sitagliptin (SITA) or sulfonylurea (SU) in patients with type 2 diabetes mellitus (T2DM) and mild renal insufficiency. Diabetes.
Erdmann E, Song E, Spanheimer R, et al. (2014). Observational follow-up of the PROactive study: a 6-year update. Diabetes Obes Metab.
Erdmann E, Song E, Spanheimer R, et al. (2012). Pioglitazone and bladder malignancy during observational follow-up of proactive: 6-Year update. Diabetes.
Erdmann E, Song E, Spanheimer R, et al. (2012). Pioglitazone and macrovascular outcomes during observational follow-up of proactive: 6-year update. Diabetes.
Erdmann E, Song E, Spanheimer R, et al. (2012). Pioglitazone and macrovascular outcomes during observational followup of PROactive: 6-year update. Diabetologia.
Erdmann E, Spanheimer R, Charbonnel B. (2010). Pioglitazone and the risk of cardiovascular events in patients with Type 2 diabetes receiving concomitant treatment with nitrates, renin-angiotensin system blockers, or insulin: results from the PROactive study (PROactive 20). J Diabetes.
Esbah O, Oksuzoglu B, Eren T, et al. (2013). Metformin in diabetic pancreatic cancer patients: Benefit or not-Multicenter experience. Journal of Clinical Oncology.
Esteghamati A, Afarideh M, Feyzi S, et al. (2014). Comparative effects of metformin and pioglitazone on fetuin-A and osteoprotegerin concentrations in patients with newly diagnosed diabetes: A randomized clinical trial. Diabetes Metab Syndr.
Esteghamati A, Noshad S, Rabizadeh S, et al. (2013). Comparative effects of metformin and pioglitazone on omentin and leptin concentrations in patients with newly diagnosed diabetes: a randomized clinical trial. Regul Pept.
Esteva FJ. (2011). Long-term metformin use is associated with decreased risk of breast cancer. Breast Diseases.
Evans M, McEwan P, O'Shea R, et al. (2014). Effectiveness in clinical practice of incretin-based therapies used for the treatment of type 2 diabetes: Results from a national, retrospective, UK case-note survey. Medecine des Maladies Metaboliques.
Faber-Heinemann G. (2012). Comparison between clinical efficacy of DPP-4 inhibitors and GLP-1 analogs in type 2 diabetics. Diabetes, Stoffwechsel und Herz.
Fadini GP, de Kreutzenberg SV, Mariano V, et al. (2011). Optimized glycaemic control achieved with add-on basal insulin therapy improves indexes of endothelial damage and regeneration in type 2 diabetic patients with macroangiopathy: A randomized crossover trial comparing detemir versus glargine. Diabetes, Obesity and Metabolism.
Faillie JL, Azoulay L, Patenaude V, et al. (2014). Incretin based drugs and risk of acute pancreatitis in patients with type 2 diabetes: Cohort study. BMJ (Online).
Faillie JL, Babai S, Crepin S, et al. (2013). Pancreatitis and use of GLP1 analogs and DPP4 inhibitors: A case/non-case study from the french pharmacovigilance database. Drug Safety.
Fattor B, Cretti A, Cristini M, et al. (2014). Treatment with GLP-1 analogue liraglutide is associated with improvement in HbA1c and weight loss in type 2 diabetic patients after early metformin failure. Italian Journal of Medicine.
Feldman L, Shani M, Efrati S, et al. (2010). Association between rosiglitazone use and decline in renal function in patients with type 2 diabetes mellitus. J Nephrol.
Feng P, Yu DM, Chen LM, et al. (2015). Liraglutide reduces the body weight and waist circumference in Chinese overweight and obese type 2 diabetic patients. Acta Pharmacol Sin.
Ferdinand KC, White WB, Calhoun DA, et al. (2014). Effects of the Once-Weekly Glucagon-Like Peptide-1 Receptor Agonist Dulaglutide on Ambulatory Blood Pressure and Heart Rate in Patients With Type 2 Diabetes Mellitus. Hypertension.
Ferrannini E, Ramos SJ, Salsali A, et al. (2010). Dapagliflozin monotherapy in type 2 diabetic patients with inadequate glycemic control by diet and exercise: a randomized, double-blind, placebo-controlled, phase 3 trial. Diabetes Care.
Ferrannini E, Seman LJ, Seewaldt-Becker E, et al. (2010). The potent and highly selective sodium-glucose co-cransporter (SGLT-2) inhibitor BI 10773 is safe and efficacious as monotherapy in patients with type 2 diabetes mellitus. Diabetologia.
Ferrara A, Lewis JD, Quesenberry CP, et al. (2011). Cohort study of pioglitazone and cancer incidence in patients with diabetes. Diabetes Care.
Ferreira JCA, Engel SS, Guo H, et al. (2012). Consistency of the A1C-lowering effects of sitagliptin versus glipizide in patients with type 2 diabetes and chronic renal insufficiency across a variety of baseline characteristics. Diabetes.
Ferreira JCA, Engel SS, Guo H, et al. (2012). Sitagliptin more effectively achieves a composite endpoint of a1c reduction, no body weight gain, and lack of hypoglycemia in patients with type 2 diabetes and renal insufficiency compared to glipizide. Diabetes.
Filion KB, Joseph L, Boivin JF, et al. (2011). Thiazolidinediones and the risk of incident congestive heart failure among patients with type 2 diabetes mellitus. Pharmacoepidemiol Drug Saf.
Fiorentino TV, Daniele G, Tripathy D, et al. (2013). Low dose pioglitazone-induced reduction in skeletal muscle TACE activity and TNFalpha is associated with an improvement of glycaemic control in type 2 diabetic patients. Diabetologia.
Fioretto P, De Bruin TW, Johnsson E, et al. (2013). Safety and efficacy of the SGLT2 inhibitor dapagliflozin in older patients with type 2 diabetes. Diabetologia.
Fitzpatrick L, Kravitz B, Northcutt A, et al. (2011). The effects of rosiglitazone on bone by multiple image modalities in postmenopausal women with type 2 diabetes mellitus. Osteoporosis International.
Fitzpatrick LA, Nino AJ, Kravitz B, et al. (2010). Understanding the effects of rosiglitazone on bone as measured by DXA and HSA: A mechanistic study in postmenopausal women with type 2 diabetes mellitus. Journal of Bone and Mineral Research.
Fleck P, Inzucchi S, Seufert J, et al. (2009). Initial therapy with combination alogliptin plus pioglitazone in type 2 diabetes patients inadequately controlled with diet and exercise. Diabetologia.
Fleck P, Wilson C. (2012). Effect of alogliptin combined with pioglitazone on lipids and lipoprotein particles in patients with type 2 diabetes. Diabetes.
Fleck P, Wilson C. (2012). Effect of alogliptin in combination with pioglitazone on glycemic control by baseline A1C. Diabetes.
Flint A, Kapitza C, Hindsberger C, et al. (2011). The once-daily human glucagon-like peptide-1 (GLP-1) analog liraglutide improves postprandial glucose levels in type 2 diabetes patients. Adv Ther.
Fonseca V, Desouza C, Khan AN. (2010). Adding subcutaneous liraglutide to metformin reduces HbA1c more than adding oral sitagliptin in patients whose type 2 diabetes is poorly controlled with metformin alone. Evidence-Based Medicine.
Fonseca V, Gill J, Zhou R, et al. (2011). An analysis of early insulin glargine added to metformin with or without sulfonylurea: impact on glycaemic control and hypoglycaemia. Diabetes Obes Metab.
Fonseca V, McDuffie R, Calles J, et al. (2013). Determinants of weight gain in the action to control cardiovascular risk in diabetes trial. Diabetes Care.
Fonseca V, Zhu T, Karyekar C, et al. (2011). Adding saxagliptin (SAXA) 5 mg is superior to uptitrating metformin extended release (MET XR) in type 2 diabetes mellitus (T2DM) patients with inadequate glycemic control on a stable dose of MET XR 1500 mg. Diabetes.
Forst T, Guthrie R, Goldenberg R, et al. (2014). Efficacy and safety of canagliflozin over 52 weeks in patients with type 2 diabetes on background metformin and pioglitazone. Diabetes Obes Metab.
Forst T, Larbig M, Hohberg C, et al. (2010). Adding insulin glargine vs. NPH insulin to metformin results in a more efficient postprandial beta-cell protection in individuals with type 2 diabetes. Diabetes Obes Metab.
Fragozo A, Puerta MF, Alfonso R, et al. (2009). Adherence to glimepiride for type 2 diabetics in Colombia. Value in Health.
Franco DR, Baptista J, Abreu FRM, et al. (2014). Starting glargine in insulin-naive type 2 diabetic patients based on body mass index is safe. World Journal of Diabetes.
Franek E, Haluzik M, Canecki Varzic S, et al. (2014). IDegAsp provides superior FPG control and reduced hypoglycaemia vs BIAsp 30 in insulin-naive adults with type 2 diabetes: A randomised phase 3 trial. Diabetologia.
Franek E, Haluzik M, Canecki-Varzic S, et al. (2014). Insulin degludec/insulin aspart (IDegASP) provides superior FPG control and reduced hypoglycaemia vs. biphasic insulin aspart 30 (BIAsp 30) in insulin-naive adults with type 2 diabetes in a randomized phase 3 trial. Diabetes.
Frederich R, McNeill R, Berglind N, et al. (2012). The efficacy and safety of the dipeptidyl peptidase-4 inhibitor saxagliptin in treatment-naive patients with type 2 diabetes mellitus: a randomized controlled trial. Diabetol Metab Syndr.
Frederich R, Ohman P, Berglind N, et al. (2011). Clinical characteristics and sustained glycaemic control: A 76-week, randomised, double-blind study of saxagliptin + metformin in treatment-naive patients with type 2 diabetes. Diabetologia.
Frederich R, Parikh SJ, Allen E, et al. (2013). Early onset of increased hypoglycemic incidence with glipizide (GLIP) vs. saxagliptin (SAXA) in type 2 diabetes patients on metformin. Diabetes.
Freeman MK. (2011). Efficacy and safety of linagliptin (tradjenta) in adults with type-2 diabetes mellitus. P T.
Fu AZ, Qiu Y, Davies MJ, et al. (2012). Initial sulfonylurea use and subsequent insulin therapy in older subjects with type 2 diabetes mellitus. Diabetes Ther.
Fu AZ, Qiu Y, Davies MJ, et al. (2011). Risk of cardiovascular disease associated with sulfonylurea or metformin use in older patients with type 2 diabetes. Diabetes. Fu AZ, Qiu Y, Davies MJ, et al. (2011). Risk of cardiovascular disease associated with sulphonylurea or metformin use in older patients with type 2 diabetes mellitus. Diabetologia.
Fu H, Curtis BH, Schuster D, et al. (2013). Treatment patterns among older patients with type 2 diabetes in the United States: A retrospective cohort study. Diabetes.
Fu H, Xie W, Curtis B, et al. (2014). Identifying factors associated with hypoglycemia-related hospitalizations among elderly patients with T2DM in the US: a novel approach using influential variable analysis. Curr Med Res Opin.
Fujimoto K, Hamamoto Y, Honjo S, et al. (2013). Pioglitazone increases the risk of diabetic macular oedema in patients with type 2 diabetes. Diabetologia.
Fujimoto K, Hamamoto Y, Honjo S, et al. (2013). Possible link of pioglitazone with bladder cancer in Japanese patients with type 2 diabetes. Diabetes Res Clin Pract.
Fujishima Y, Maeda N, Inoue K, et al. (2012). Efficacy of liraglutide, a glucagon-like peptide-1 (GLP-1) analogue, on body weight, eating behavior, and glycemic control, in Japanese obese type 2 diabetes. Cardiovasc Diabetol.
Fujiwara T, Yoshida M, Nakamura T, et al. (2014). Dipeptidyl peptidase-4 inhibitors are associated with improved left ventricular diastolic function after acute myocardial infarction in diabetic patients. Heart and Vessels.
Fumisawa Y, Funase Y, Yamashita K, et al. (2012). Systematic analysis of risk factors for coronary heart disease in Japanese patients with type 2 diabetes: a matched case-control study. J Atheroscler Thromb.
Funch D, Gydesen H, Tornoe K, et al. (2014). A prospective, claims-based assessment of the risk of pancreatitis and pancreatic cancer with liraglutide compared to other antidiabetic drugs. Diabetes, Obesity and Metabolism.
Furui H. (2013). Comparison examination of the clinical efficacy of 3 DPP-4 inhibitors on type 2 diabetes mellitus treatment: Combination effect with SU drug. Therapeutic Research.
Furukawa K, Hanyu O, Heianza Y, et al. (2013). High-dose metformin vs. Sitagliptin in addition to metformin 750mg in insufficiently controlled japanese type 2 diabetes patients with metformin 750mg. Diabetes.
Gada E, Owens AW, Gore MO, et al. (2013). Discordant effects of rosiglitazone on novel inflammatory biomarkers. Am Heart J.
Gallwitz B, Bohmer M, Segiet T, et al. (2011). Effects of exenatide vs. insulin aspart on glycaemic control and hypoglycaemia in patients with Type 2 diabetes treated with metformin: Primary results for the metformin arm of a 26-week, Randomised, Open-label study. Diabetic Medicine.
Gallwitz B, Bohmer M, Segiet T, et al. (2010). Exenatide vs. insulin aspart in patients with type 2 diabetes: Results of a randomised, open-label s tudy. Diabetologia.
Gallwitz B, Dotta F, Kazda C, et al. (2009). Changes in adipokines in type 2 diabetic patients treated with exenatide versus glimipiride on metformin background - Results of a prospective, randomized controlled study over 9 months. Diabetologia.
Gallwitz B, Kusterer K, Hildemann S. (2012). The therapy of type 2 diabetes in clinical practice - Results from a standardized non-interventional register (SIRTA). Diabetologie und Stoffwechsel.
Gallwitz B, Rosenstock J, Emser A, et al. (2012). Linagliptin is more effective than glimepiride at achieving a composite outcome of A1C target with no hypoglycemia and no weight gain over 2 years in mildly hyperglycemic T2D pts on metformin. Diabetes.
Gallwitz B, Rosenstock J, Emser A, et al. (2013). Linagliptin is more effective than glimepiride at achieving a composite outcome of target HbA(1)c < 7% with no hypoglycaemia and no weight gain over 2 years. Int J Clin Pract.
Gallwitz B, Rosenstock J, Patel S, et al. (2014). Regardless of the degree of glycemic control, Linagliptin (LINA) has lower hypoglycemia risk than all doses of Glimepiride (GLIM), at all timeg points over a 2-year trial. Diabetologie und Stoffwechsel.
Gallwitz B, Uhlig-Laske B, Bhattacharaya S, et al. (2011). Linagliptin has similar efficacy to glimepiride but improved cardiovascular safety over 2 years in patients with type 2 diabetes inadequately controlled on metformin. Diabetes, Stoffwechsel und Herz.
Ganz ML, Xu Y, Wintfeld NS, et al. (2013). Rates and costs of severe hypoglycemic events in type 2 diabetes in the United States: Findings from a systematic literature review and electronic health records. Diabetes.
Garber A, Falahati A, Toft AD. (2010). Meta-analysis of the effect of liraglutide, a once-daily human GLP-1 analogue, on lipids and markers of cardiovascular risk in type 2 diabetes. Diabetic Medicine.
Garber A, Henry R, Ratner R, et al. (2010). Liraglutide, a human GLP-1 analogue, offers sustained and greater reduction in HbA1c, fasting plasma glucose and weight compared with glimepiride over 2 years, with lower hypoglycaemic risk, in patients with Type 2 diabetes: LEAD-3 extension study. Diabetic Medicine.
Garber A, Henry R, Ratner R, et al. (2009). Significantly better glycaemic control and weight reduction with liraglutide, a once-daily human GLP-1 analogue, compared with glimepiride: All as monotherapy in type 2 diabetes. Journal of Diabetes.
Garber A, Henry R, Ratner RE, et al. (2009). Two years of treatment with liraglutide, a human GLP-1 analogue, offers sustained and greater reduction with HbA1c, FPG, PPG and weight compared with glimepiride, with lower glycaemic risk, in patients with type 2 diabetes: LEAD-3 extension study. Canadian Journal of Diabetes.
Garber A, Matthews D, Holst JJ, et al. (2011). The effect of diabetes duration on the response to liraglutide and glimepiride in type 2 diabetes. Journal of Diabetes.
Garber A, Thomsen A, Falahati A, et al. (2010). Liraglutide treatment provides greater weight loss with improved glycaemic control than sitagliptin, both combined with metformin. Diabetologia.
Garber AJ, Henry R, Ratner R, et al. (2009). Liraglutide, a human GLP-1 analogue, maintains greater reductions in HbA1c, FPG and weight than glimepiride over 2 years in patients with type 2 diabetes: LEAD-3 extension study. Diabetologia.
Garber AJ, Henry R, Ratner R, et al. (2009). Monotherapy with liraglutide, a once-daily human GLP-1 analog, provides sustained reductions in A1C, FPG, and weight compared with glimepiride in type 2 diabetes: LEAD-3 mono 2-year results. Diabetes.
Garcia-Garcia HM, Garg S, Brugaletta S, et al. (2012). Evaluation of in-stent restenosis in the APPROACH trial (Assessment on the Prevention of Progression by Rosiglitazone On Atherosclerosis in diabetes patients with Cardiovascular History). Int J Cardiovasc Imaging.
Garcia-Garcia HM, Serruys PW, Gerstein HC, et al. (2009). Serial assessments of coronary remodeling from the approach trial (assessment on the prevention of progression by rosiglitazone on atherosclerosis in diabetes patients with cardiovascular history). European Heart Journal.
Garcia-Hernandez P, Arechavaleta-Granell Mdel R, Yamamoto J, et al. (2010). Rev Med Inst Mex Seguro Soc.
Garg R, Chen W, Pendergrass M. (2010). Acute pancreatitis in type 2 diabetes treated with exenatide or sitagliptin: a retrospective observational pharmacy claims analysis. Diabetes Care.
Garofolo M, Pucci L, Lucchesi D, et al. (2013). Effects of pioglitazone vs glyburide on endothelial function in type 2 diabetic patients with vascular complications: The SPLENDOR study. Diabetologia.
Garrett CR, Hassabo HM, Bhadkamkar NA, et al. (2012). Survival advantage observed with the use of metformin in patients with type II diabetes and colorectal cancer. Br J Cancer.
Gastaldelli A, Brodows RG, D'Alessio D. (2014). The effect of chronic twice daily exenatide treatment on beta-cell function in new onset type 2 diabetes. Clin Endocrinol (Oxf).
Gatbonton P, Ko-De los Santos G, Domingo F, et al. (2013). Effectiveness and tolerability of vildagliptin versus other oral antidiabetic drugs in patients with type 2 diabetes mellitus in the Philippines: Results from one year observational study (EDGE). Phillippine Journal of Internal Medicine.
Gause-Nilsson I, De Bruin TW, Sugg JE, et al. (2014). Two-year efficacy and safety of dapagliflozin for T2DM patients with a history of cardiovascular disease. Diabetes.
Gavin IJR, Davies MJ, Davies M, et al. (2014). Consistent effects of canagliflozin (CANA) across racial subgroups of patients with type 2 diabetes mellitus (T2DM). Diabetes.
Geiger MJ, Skrivanek Z, Gaydos B, et al. (2012). An adaptive, dose-finding, seamless phase 2/3 study of a long-acting glucagon-like peptide-1 analog (dulaglutide): trial design and baseline characteristics. J Diabetes Sci Technol.
Gejl M, Starup-Linde J, Scheel-Thomsen J, et al. (2014). Diabetes treatment and composite endpoint: A nested case-control study. Diabetes.
Gejl M, Starup-Linde J, Scheel-Thomsen J, et al. (2014). Risk of cardiovascular disease events: The impact of diabetes and anti-diabetic drugs: A nested case-control study. Diabetologia.
Geraldine N, Marc A, Carla T, et al. (2012). Relation between diabetes, metformin treatment and the occurrence of malignancies in a Belgian primary care setting. Diabetes Res Clin Pract.
Gerstein HC, Ratner RE, Cannon CP, et al. (2010). Effect of rosiglitazone on progression of coronary atherosclerosis in patients with type 2 diabetes mellitus and coronary artery disease: the assessment on the prevention of progression by rosiglitazone on atherosclerosis in diabetes patients with cardiovascular history trial. Circulation.
Ghotbi AA, Kober L, Finer N, et al. (2013). Association of hypoglycemic treatment regimens with cardiovascular outcomes in overweight and obese subjects with type 2 diabetes: a substudy of the SCOUT trial. Diabetes Care.
Gianturco V, Gianturco L, Bodini BD, et al. (2014). Long term effects of therapy with DPP-4 Inhibitors on fitness, cardiovascular function and mortality: A cohort study in elder population. European Heart Journal.
Gilbert RE, Weir M, Januszewicz A, et al. (2013). Lower blood pressure (BP) with canagliflozin (CANA) in subjects with type 2 diabetes mellitus (T2DM). Canadian Journal of Diabetes.
Gilbert RE, Weir MR, Fioretto P, et al. (2014). Effect of canagliflozin (CANA) in patients with type 2 diabetes mellitus (T2DM) based on age and estimated glomerular filtration rate (EGFR). Diabetes.
Giles TD, Elkayam U, Bhattacharya M, et al. (2010). Comparison of pioglitazone vs glyburide in early heart failure: insights from a randomized controlled study of patients with type 2 diabetes and mild cardiac disease. Congest Heart Fail.
Gill A, Hoogwerf BJ, Burger J, et al. (2010). Effect of exenatide on heart rate and blood pressure in subjects with type 2 diabetes mellitus: a double-blind, placebo-controlled, randomized pilot study. Cardiovasc Diabetol.
Giorda CB, Picariello R, Nada E, et al. (2014). Incretin therapies and risk of hospital admission for acute pancreatitis in an unselected population of European patients with type 2 diabetes: a case-control study. Lancet Diabetes Endocrinol.
Gitt AK, Bramlage P, Binz C, et al. (2012). Herz.
Gitt AK, Bramlage P, Binz C, et al. (2013). Clinical impact on target achievement and complications of intensified glucose control on top of metformin: Sulfonylurea and insulin vs. incretin-based treatment in clinical practice. European Heart Journal.
Gitt AK, Bramlage P, Binz C, et al. (2012). Hypoglycaemia is more frequent in type 2 diabetic patients with co-morbid vascular disease: an analysis of the DiaRegis registry. Eur J Prev Cardiol.
Gitt AK, Bramlage P, Binz C, et al. (2014). Outcome of sulfonylurea and insulin versus incretin-based treatment in type 2 diabetes patients uncontrolled on prior metformin mono therapy: Results of diaregis. Journal of the American College of Cardiology.
Gitt AK, Bramlage P, Deeg E, et al. (2012). Higher incidence of hypoglycaemia under oral anti-diabetic therapy in patients with type 2 diabetes and manifest vascular disease: 12-months follow-up of DiaRegis. European Heart Journal.
Gitt AK, Bramlage P, Deeg E, et al. (2011). Higher incidence of hypoglycaemia under oral anti-diabetic therapy in patients with type 2 diabetes and manifest vascular disease: Results of DiaRegis. European Heart Journal.
Gitt AK, Bramlage P, Schneider S, et al. (2014). Incidence and impact of hypoglycemia in diabetic patients with intensified glycaemic control in clinical practice-results of DiaRegis. European Heart Journal.
Gitt AK, Bramlage P, Schneider S, et al. (2014). Outcome of sulfonylurea and insulin vs. Incretin-based treatment in type 2 diabetes patients uncontrolled on prior metformin mono therapy-results of DiaRegis. European Heart Journal.
Gitt AK, Bramlage P, Schneider S, et al. (2013). Performance of DPP-4-inhhibitors versus sulfonylureas on top of metformin in a real world setting - Results of 2 years FU of DiaRegis. European Heart Journal.
Glass LC, Triplitt C, Lewis MS, et al. (2009). Effects of exenatide plus rosiglitazone on measures of beta cell function and insulin sensitivity in subjects with type 2 diabetes previously treated with metformin. Diabetologia.
Goke B, Gallwitz B, Eriksson J, et al. (2011). Saxagliptin vs glipizide as add-on therapy to metformin for type 2 diabetes mellitus (T2DM): Long-term safety and efficacy. Diabetes.
Gokhale M, Funk MJ, Wyss R, et al. (2012). Comparative evaluation of short-term risk of cardiovascular events with antidiabetic step-up therapies among older adults. Pharmacoepidemiology and Drug Safety.
Goldstein BJ, Seck T, Chen Y, et al. (2010). Sitagliptin compared with glimepiride provides similar efficacy with weight loss and less hypoglycaemia when added to metformin therapy in patients with type 2 diabetes mellitus. Diabetologia.
Gomez-Samano MA, Gulias-Herrero A, Cuevas-Ramos D, et al. (2012). Metformin and improvement of the hepatic insulin resistance index independent of anthropometric changes. Endocrine Practice.
Gomis R, Espadero RM, Jones R, et al. (2011). Efficacy and safety of initial combination therapy with linagliptin and pioglitazone in patients with inadequately controlled type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab.
Gomis R, Owens DR, Taskinen MR, et al. (2012). Long-term safety and efficacy of linagliptin as monotherapy or in combination with other oral glucose-lowering agents in 2121 subjects with type 2 diabetes: up to 2 years exposure in 24-week phase III trials followed by a 78-week open-label extension. Int J Clin Pract.
Gonzalez-Galvez G, Jodar E, Kim K, et al. (2014). Efficacy and safety of canagliflozin in patients with type 2 diabetes mellitus who were, or were not, on antihyperglycaemic agents at screening. Diabetologia.
Gonzalez-Galvez G, Kim KA, Jodar E, et al. (2014). Effect of canagliflozin (CANA) in patients with type 2 diabetes mellitus (T2DM) who were, or were not, on antihyperglycemic agents (AHAS) at screening. Diabetes.
Gonzalez-Perez A, Schlienger RG, Garcia Rodriguez LA. (2010). Acute pancreatitis in association with type 2 diabetes and antidiabetic drugs: A population-based cohort study. Diabetes Care.
Gosmanova EO, Canada RB, Wan J, et al. (2012). Different antidiabetic regimens and the development of renal dysfunction in US Veterans with type 2 diabetes mellitus. J Investig Med.
Gough S, Zinman B, Falahati A, et al. (2010). The proportion of patients reaching the composite outcome of HbA1c <7.0%, no hypoglycaemia and no weight gain with different Type 2 diabetes therapies in the Liraglutide Effect and Action in Diabetes (LEAD) programme. Diabetic Medicine.
Gough SC, Zinman B, Brett J, et al. (2012). Achievement of glycaemic control and weight loss with liraglutide, exenatide and sitagliptin. Diabetic Medicine.
Grabner M, Wei W, Raparla S, et al. (2012). Real-world comparative effectiveness analysis of patients initiating injectable treatments for type 2 diabetes mellitus (T2DM): Pilot data from the initiator study. Value in Health.
Graham DJ, Ouellet-Hellstrom R, MaCurdy TE, et al. (2010). Risk of acute myocardial infarction, stroke, heart failure, and death in elderly Medicare patients treated with rosiglitazone or pioglitazone. JAMA.
Grandy S, Fox KM, Hardy E. (2013). Association of Weight Loss and Medication Adherence Among Adults With Type 2 Diabetes Mellitus: SHIELD (Study to Help Improve Early evaluation and management of risk factors Leading to Diabetes). Curr Ther Res Clin Exp.
Grandy S, Hashemi M, Langkilde AM, et al. (2014). Changes in weight loss-related quality of life among type 2 diabetes mellitus patients treated with dapagliflozin. Diabetes Obes Metab.
Grandy S, Ingelganullrd A, Langkilde A, et al. (2013). Weight loss-related quality of life among type 2 diabetes mellitus (T2DM) patients treated with dapagliflozin. Diabetes.
Grandy S, Ingelgard A, Sjostrom CD, et al. (2013). Treatment with dapagliflozin over 52 weeks maintains health-related quality of life in high cardiovascular risk patients with type 2 diabetes mellitus. Circulation: Cardiovascular Quality and Outcomes.
Grandy S, Langkilde AM, Ingelganullrd A, et al. (2012). Quality of life (EQ-5D) among type 2 diabetes mellitus patients treated with dapagliflozin for 24 weeks. Diabetes.
Grandy S, Langkilde AM, Sugg JE, et al. (2014). Health-related quality of life (EQ-5D) among type 2 diabetes mellitus patients treated with dapagliflozin over 2 years. Int J Clin Pract.
Greco D, Pisciotta M, Gambina F, et al. (2010). Severe hypoglycaemia leading to hospital admission in type 2 diabetic patients aged 80 years or older. Exp Clin Endocrinol Diabetes.
Grey A, Beckley V, Doyle A, et al. (2012). Pioglitazone increases bone marrow fat in type 2 diabetes: results from a randomized controlled trial. Eur J Endocrinol.
Grey A, Bolland M, Fenwick S, et al. (2014). The skeletal effects of pioglitazone in type 2 diabetes or impaired glucose tolerance: a randomized controlled trial. Eur J Endocrinol.
Grimm M, Han J, Weaver C, et al. (2013). Efficacy, safety, and tolerability of exenatide once weekly in patients with type 2 diabetes mellitus: an integrated analysis of the DURATION trials. Postgrad Med.
Groop PH, Cooper M, Perkovic V, et al. (2012). Effects of the DPP-4 inhibitor linagliptin on albuminuria in patients with type 2 diabetes and diabetic nephropathy. Diabetologia.
Groop PH, Cooper M, Perkovic V, et al. (2012). Linagliptin lowers albuminuria on top of recommended standard treatment for diabetic nephropathy. Diabetes.
Groop PH, Cooper ME, Perkovic V, et al. (2013). Linagliptin lowers albuminuria on top of recommended standard treatment in patients with type 2 diabetes and renal dysfunction. Diabetes Care.
Groop PH, Del Prato S, Taskinen MR, et al. (2014). Linagliptin treatment in subjects with type 2 diabetes with and without mild-to-moderate renal impairment. Diabetes Obes Metab.
Groop PH, Laakso M, Rosenstock J, et al. (2013). Linagliptin versus placebo followed by glimepiride in type 2 diabetes patients with moderate to severe renal impairment. Diabetologia.
Groop PH, Perkovic V, Cooper M, et al. (2014). Long-term efficacy and safety of linagliptin in type 2 diabetes patients with moderate to severe renal disease. Diabetes.
Groop PH, Von Eynatten M, Emser A, et al. (2011). Efficacy and safety of linagliptin in type 2 diabetes patients at high risk of renal complications: Results from a large phase 3 program. Diabetes.
Gross P. (2011). Influence of pioglitazone for renal transplant function in diabetics - a double blind randomised placebo controlled cross over study.
Grunberger G, Chang A, Garcia Soria G, et al. (2012). Monotherapy with the once-weekly GLP-1 analogue dulaglutide for 12 weeks in patients with Type 2 diabetes: dose-dependent effects on glycaemic control in a randomized, double-blind, placebo-controlled study. Diabet Med.
Grunberger G, Chang A, Soria MGG, et al. (2011). Monotherapy with the once weekly long-acting GLP-1 analog LY2189265 for 12 weeks in patients with type 2 diabetes: Dose-dependent effects on glycemic control in a randomized, double-blind, placebo-controlled study. Diabetes.
Gruntmanis U, Fordan S, Ghayee HK, et al. (2010). The peroxisome proliferator-activated receptor-gamma agonist rosiglitazone increases bone resorption in women with type 2 diabetes: a randomized, controlled trial. Calcif Tissue Int.
Gudipaty L, Rosenfeld NK, Fuller CS, et al. (2014). Effect of Exenatide Sitagliptin or Glimepiride on beta-Cell Secretory Capacity in Early Type 2 Diabetes. Diabetes Care.
Guerci B, Weinstock R, Umpierrez G, et al. (2013). Safety and efficacy of dulaglutide versus sitagliptin after 104 weeks in type 2 diabetes (award-5). Canadian Journal of Diabetes.
Guerci B, Weinstock RS, Umpierrez G, et al. (2013). Safety and efficacy of dulaglutide vs sitagliptin after 104 weeks in type 2 diabetes (AWARD-5). Diabetologia.
Guo M, Mi J, Jiang QM, et al. (2014). Metformin may produce antidepressant effects through improvement of cognitive function among depressed patients with diabetes mellitus. Clin Exp Pharmacol Physiol.
Gupta AK, Bray GA, Greenway FL, et al. (2010). Pioglitazone, but not metformin, reduces liver fat in Type-2 diabetes mellitus independent of weight changes. J Diabetes Complications.
Gupta M, Teoh H, Kajil M, et al. (2012). The effects of rosiglitazone on inflammatory biomarkers and adipokines in diabetic, hypertensive patients. Exp Clin Cardiol.
Gurieva I, Pfuetzner A, Antsiferov M, et al. (2009). Saxagliptin improves glycaemic control either as add-on therapy to metformin or as initial combination therapy with metformin in patients with type 2 diabetes. European Heart Journal.
Gusmao G, Moureira M, Sosa F. (2014). Combination with linagliptin improves the tolerability of metformin in type 2 diabetic patients previously labelled as intolerant to metformin. Diabetologia.
Haak T, Meinicke T, Jones R, et al. (2011). Combination of linagliptin and metformin improves glycemic control in type 2 diabetes: A randomized trial with an open-label arm in patients with poor glycemic control. Diabetes.
Habib ZA, Havstad SL, Wells K, et al. (2010). Thiazolidinedione use and the longitudinal risk of fractures in patients with type 2 diabetes mellitus. J Clin Endocrinol Metab.
Habib ZA, Tzogias L, Havstad SL, et al. (2009). Relationship between thiazolidinedione use and cardiovascular outcomes and all-cause mortality among patients with diabetes: A time-updated propensity analysis. Pharmacoepidemiology and Drug Safety.
Hach T, Gerich J, Salsali A, et al. (2013). Empagliflozin improves glycaemic parameters and cardiovascular risk factors in patients with type 2 diabetes: Pooled data from four pivotal phase III trials. Diabetologia.
Hach T, Gerich J, Salsali A, et al. (2014). Empagliflozin improves glycaemic parameters and cardiovascular risk factors in patients with type 2 diabetes: Pooled data from four pivotal phase III trials. Giornale Italiano di Cardiologia.
Hach T, Gerich J, Salsali A, et al. (2014). Empagliflozin improves glycaemic parameters and cardiovascular risk factors in patients with Type 2 diabetes: Pooled data from four randomised, placebo-controlled phase III trials. Diabetic Medicine.
Hach T, Gerich J, Salsali A, et al. (2014). Empagliflozin improves glycemic parameters and cardiovascular risk factors in patients with Type 2 Diabetes (T2DM): Pooled data from four pivotal phase III trials. Diabetologie und Stoffwechsel.
Hach T, Lambers Heerspink HJ, Pfarr E, et al. (2012). The sodium glucose cotransporter-2 (SGLT-2) inhibitor empagliflozin lowers blood pressure independent of weight or HbA1c changes. Diabetologia.
Hage C, Brismar K, Lundman P, et al. (2014). The DPP-4 inhibitor sitagliptin and endothelial function in patients with acute coronary syndromes and newly detected glucose perturbations: A report from the BEGAMI study. Diab Vasc Dis Res.
Halimi S, Aubert JP, Fontbonne A, et al. (2012). A real-life study of the use, effectiveness and tolerability of rosiglitazone in France: the AVANCE study. Diabetes Metab.
Hammar N, Farahmand B, Andersson S, et al. (2009). Incidence of urinary tract infection in subjects with type 2 diabetes. Experience from adverse event reporting in diabetes clinical trials. Pharmacoepidemiology and Drug Safety (PDS).
Hammar N, Farahmand B, Gran M, et al. (2010). Incidence of urinary tract infection in patients with type 2 diabetes. Experience from adverse event reporting in clinical trials. Pharmacoepidemiology and Drug Safety.
Hanefeld M, Fleischmann H, Landgraf W, et al. (2012). EARLY study: Early basal insulin therapy under real-life conditions in type 2 diabetics. Diabetes, Stoffwechsel und Herz.
Hanefeld M, Kleine I, Fuchs W, et al. (2011). Comparison of pioglitazone vs metformin and effects of the combina tion of both on cardiovascular risk factors in type 2 diabetes with stable insulin therapy: The PIOCOMB study. Diabetes.
Hansen L, Zee P, Li Y, et al. (2014). Randomised, double-blind trial of dual add-on saxagliptin plus dapagliflozin vs saxagliptin or dapagliflozin add-on alone in poorly controlled type 2 diabetes on metformin. Diabetologia.
Haque AF, Haque MZ, Ekram AS, et al. (2011). Comparison between effect of glimepiride and pioglitazone on the C-reactive protein level of type 2 diabetic patient. Journal of Medicine.
Hardy E, Ptaszynska A, De Bruin TWA, et al. (2013). Dapagliflozin effects on the lipid profile of patients with type 2 diabetes mellitus. Diabetes.
Hardy E, Rohwedder K, Hrub V, et al. (2011). Dapagliflozin, a selective SGLT2 inhibitor, reduces serum levels of uric acid in patients with type 2 diabetes. Diabetologia.
Hardy E, Salsali A, Hruba V, et al. (2012). Efficacy increases with increasing baseline HbA1c category with dapagliflozin therapy. Diabetes.
Haring HU, Merker L, Seewaldt-Becker E, et al. (2013). Empagliflozin as add-on to metformin for 24 weeks improves glycemic control in patients with type 2 diabetes (T2DM). Diabetes.
Haring HU, Merker L, Seewaldt-Becker E, et al. (2013). Empagliflozin as add-on to metformin plus sulfonylurea in patients with type 2 diabetes: A 24-week, randomized, double-blind, placebo-controlled trial. Diabetes Care.
Haring HU, Merker L, Seewaldt-Becker E, et al. (2014). Improved glycaemic control with empagliflozin as add-on to metformin in a 24-week phase III trial in patients with Type 2 diabetes (EMPA-REG MET(trademark)). Diabetic Medicine.
Harris S, Sinclair A, Bode B, et al. (2013). Efficacy and safety of canagliflozin (CANA) in older subjects with type 2 diabetes mellitus (T2DM). Canadian Journal of Diabetes.
Hassabo HM, Hassan M, George B, et al. (2011). Survival advantage associated with metformin usage in patients with colorectal cancer (CRC) and type II noninsulin-dependent diabetes (NIDDM). Journal of Clinical Oncology.
Hassan MM, Curley SA, Li D, et al. (2010). Association of diabetes duration and diabetes treatment with the risk of hepatocellular carcinoma. Cancer.
He X, Esteva FJ, Ensor J, et al. (2012). Metformin and thiazolidinediones are associated with improved breast cancer-specific survival of diabetic women with HER2+ breast cancer. Ann Oncol.
He XX, Tu SM, Lee MH, et al. (2011). Thiazolidinediones and metformin associated with improved survival of diabetic prostate cancer patients. Ann Oncol.
Heggie AJ, Walker M. (2013). Renal function in patients with Type 2 diabetes treated with glucagon-like peptide 1 (GLP-1) analogues. Diabetic Medicine.
Heise T, Mathieu C, Hey-Hadavi J, et al. (2010). Glycemic control with preprandial versus basal insulin in patients with type 2 diabetes mellitus poorly controlled by oral antidiabetes agents. Diabetes Technology and Therapeutics.
Heller S, Adetunji O, Tahbaz A, et al. (2013). Patient-reported outcomes in a trial of exenatide once weekly vs insulin detemir in patients with Type 2 diabetes treated with metformin alone or with sulphonylurea. Diabetic Medicine.
Henriksen K, Byrjalsen I, Qvist P, et al. (2011). Efficacy and safety of the partial PPAR{gamma} agonist balaglitazone compared with pioglitazone and placebo: A Phase III, randomized, parallel-group study in patients with type 2 diabetes on stable insulin therapy. Endocrine Reviews.
Henry R, Buse J, Sesti G, et al. (2011). Efficacy of anthiyperglycemic therapies and the influence of baseline hemoglobin A1C: A meta-analysis of the liraglutide development program. Endocrine Practice.
Henry RR, Buse JB, Sesti G, et al. (2011). Efficacy of antihyperglycemic therapies and the influence of baseline hemoglobin A(1C): a meta-analysis of the liraglutide development program. Endocr Pract.
Henry RR, Murray AV, Herrera Marmolejo M, et al. (2011). Dapagliflozin, Metformin-XR, or both together to initiate pharmacologic therapy for type 2 diabetes. Diabetologia.
Henry RR, Smith SR, Schwartz SL, et al. (2011). Effects of saxagliptin on beta-cell stimulation and insulin secretion in patients with type 2 diabetes. Diabetes Obes Metab.
Hense HW, Kajueter H, Wellmann J, et al. (2011). Cancer incidence in a cohort of type 2 diabetics. American Journal of Epidemiology.
Hense HW, Kajuter H, Wellmann J, et al. (2011). Cancer incidence in type 2 diabetes patients - first results from a feasibility study of the D2C cohort. Diabetol Metab Syndr.
Henson K, Hight R, Welborn D, et al. (2009). Initial therapy for type 2 diabetes. Examination of a combination approach. Adv Nurse Pract.
Hermans MP, Delibasi T, Farmer I, et al. (2011). Effects of saxagliptin added to sub-maximal doses of metformin compared with dose escalation of metformin in type 2 diabetes: Results from the PROMPT study. Diabetologia.
Hermansen K, Kolotkin RL, Hammer M, et al. (2010). Patient-reported outcomes in patients with type 2 diabetes treated with liraglutide or glimepiride, both as add-on to metformin. Prim Care Diabetes.
Hess G, Kaltheuner M, Scheper N, et al. (2011). Characteristics of 833 patients newly treated with GLP-1 analogs or DPP-IV inhibitors in 38 diabetes specialized medical practices in Germany. Diabetes.
Hess G. (2012). Clinical outcome of treatment with DPP-4-inhibitors or GLP-1-analogues in patients with type 2 diabetes treated in diabetes specialised medical practices in Germany. Diabetologia.
Hibuse T, Maeda N, Kishida K, et al. (2014). A pilot three-month sitagliptin treatment increases serum adiponectin level in Japanese patients with type 2 diabetes mellitus--a randomized controlled trial START-J study. Cardiovasc Diabetol.
Hirshberg B, Bryzinski B, Xu J, et al. (2014). Efficacy and safety of saxagliptin as monotherapy in patients with type 2 diabetes: A pooled analysis. Diabetes.
Hirshberg B, Fonseca V, Minervini G, et al. (2012). Saxagliptin vs uptitrated metformin extended release: Effect of baseline HbA1c on efficacy and safety. Endocrine Reviews.
Hirshberg B, Parker A, Edelberg H, et al. (2013). Safety of saxagliptin: events of special interest in 9156 patients with type 2 diabetes mellitus. Diabetes Metab Res Rev.
Hisada M, Munsaka M, Streit J, et al. (2012). An integrated, multi study analysis of alogliptin safety. Diabetologia.
Hitron A, Adams V, Talbert J, et al. (2012). The influence of antidiabetic medications on the development and progression of prostate cancer. Cancer Epidemiol.
Hohberg C, Larbig M, Pfutzner A, et al. (2009). (beta)-cell-relieving effects of basal insulin plus metformin (MET) treatment in type 2 diabetes (T2D) patients (Pts) using insulin glargine (GLA) or NPH insulin (NPH). Diabetes.
Holman R. (2009). DRN251 (TECOS). A Randomized, Placebo Controlled Clinical Trial to Evaluate Cardiovascular Outcomes after Treatment with Sitagliptin in Patients with Type 2 Diabetes Mellitus and Inadequate Glycemic Control.
Hong SJ, Kim JS, Park JH, et al. (2011). Three-year cardiovascular event rates were lower in type 2 diabetic patients with pioglitazone treatment after zotarolimus-eluting stent implantation. Journal of the American College of Cardiology.
Honjo S, Kawasaki Y, Hamamoto Y, et al. (2011). Incidence and type of cancer in Japanese subjects with type 2 diabetes. Diabetologia.
Horne L, Ming EE, Karyekar C, et al. (2011). Saxagliptin in combination with metformin allows more patients to reach a composite end point of HbA1c <7% without weight gain or hypoglycemia. Diabetes.
Horowitz M, Flint A, Jones KL, et al. (2012). Effect of the once-daily human GLP-1 analogue liraglutide on appetite, energy intake, energy expenditure and gastric emptying in type 2 diabetes. Diabetes Res Clin Pract.
Horsdal HT, Mehnert F, Rungby J, et al. (2012). Type of preadmission antidiabetic treatment and outcome among patients with ischemic stroke: a nationwide follow-up study. J Stroke Cerebrovasc Dis.
Horton E, Taylor K, Booker Porter T, et al. (2011). Once-weekly exenatide used for six months provided improved glycaemic control and weight loss compared with sitagliptin, pioglitazone or insulin glargine in metformin-treated patients with Type 2 diabetes. Diabetic Medicine.
Horton ES, Silberman C, Davis KL, et al. (2009). Weight loss and changes in cardiovascular biomarkers in patients with type 2 diabetes receiving incretin therapies in a large cohort database. Diabetes.
Horton ES, Silberman C, Davis KL, et al. (2010). Weight loss, glycemic control, and changes in cardiovascular biomarkers in patients with type 2 diabetes receiving incretin therapies or insulin in a large cohort database. Diabetes Care.
Hsia SH. (2011). Insulin glargine compared to NPH among insulin-naive, U.S. inner city, ethnic minority type 2 diabetic patients. Diabetes Research and Clinical Practice.
Hsiao FY, Mullins CD, Huang WF. (2010). Economic evaluation of thiazolidinediones as add-on therapy for treatment of type 2 diabetic patients in the Taiwanese national health insurance system. Value in Health.
Hsiao FY. (2009). Does cardiovascular risk decrease after discontinuing rosiglitazone use? Early and late effects of rosiglitazone on the risk of myocardial infarction in type 2 diabetic patients. Drug Information Journal.
Hsieh MC, Lee TC, Cheng SM, et al. (2012). The influence of type 2 diabetes and glucose-lowering therapies on cancer risk in the Taiwanese. Exp Diabetes Res.
Hsu CC, Wahlqvist ML, Lee MS, et al. (2011). Incidence of dementia is increased in type 2 diabetes and reduced by the use of sulfonylureas and metformin. J Alzheimers Dis.
Hsu YHE, Yang YT, Chen PN, et al. (2014). Association between pioglitazone and bladder cancer among patients with type II diabetes: A propensity score matched cohort study. Value in Health.
Hu M, Luo Y, Zhang L, et al. (2010). Sheng Wu Yi Xue Gong Cheng Xue Za Zhi.
Hu Y, Li L, Xu Y, et al. (2011). Short-term intensive therapy in newly diagnosed type 2 diabetes partially restores both insulin sensitivity and (beta)-cell function in subjects with long-term remission. Diabetes Care.
Hu YY, Ye SD, Zhao LL, et al. (2010). Hydrochloride pioglitazone decreases urinary cytokines excretion in type 2 diabetes. Clin Endocrinol (Oxf).
Hu YY, Ye SD, Zhao LL, et al. (2010). Hydrochloride pioglitazone decreases urinary TGF-beta1 excretion in type 2 diabetics. Eur J Clin Invest.
Huang ES, Karter AJ, Danielson KK, et al. (2010). The association between the number of prescription medications and incident falls in a multi-ethnic population of adult type-2 diabetes patients: The diabetes and aging study. Journal of General Internal Medicine.
Huang ES, Laiteerapong N, Liu JY, et al. (2014). Rates of complications and mortality in older patients with diabetes mellitus : the diabetes and aging study. JAMA Internal Medicine.
Hughes AD, Park C, March K, et al. (2013). A randomized placebo controlled double blind crossover study of pioglitazone on left ventricular diastolic function in type 2 diabetes. Int J Cardiol.
Hughes AD, Park CM, Khir AW, et al. (2011). Pioglitazone treatment improves left ventricular function in type 2 diabetics. Circulation.
Huskinson AC, Bottomley MJ, Clapham L, et al. (2012). A 5 year study of severe treatment-induced hypoglycaemia in diabetes: Patient characteristics and first year mortality. Diabetologia.
Idorn T, Knop FK, Jorgensen MB, et al. (2014). Safety and efficacy of liraglutide in patients with type 2 diabetes and end-stage renal disease: An investigator-initiated, randomised, placebocontrolled trial. Diabetologia.
Idris I, Warren G, Donnelly R. (2012). Association between thiazolidinedione treatment and risk of macular edema among patients with type 2 diabetes. Arch Intern Med.
Igata S, Tahara N, Tahara A, et al. (2014). Visceral fat metabolic activity is independently associated with coronary artery inflammation in patients with impaired glucose intolerance or type 2 diabetes. Circulation.
Ikeda H, Ida K, Usami M, et al. (2013). Efficacy and safety of low-dose sitagliptin (25 mg) in elderly ((greater-than or equal to)70 years old) Japanese patients with type 2 diabetes. Diabetologia.
Inagaki N, Atsumi Y, Oura T, et al. (2012). Efficacy and safety profile of exenatide once weekly compared with insulin once daily in Japanese patients with type 2 diabetes treated with oral antidiabetes drug(s): results from a 26-week, randomized, open-label, parallel-group, multicenter, noninferiority study. Clin Ther.
Inagaki N, Kondo K, Iwasaki T, et al. (2011). Canagliflozin, a novel inhibitor of sodium glucose co-transporter 2 (SGLT2) improves glycemic control and reduces body weight in Japanese type 2 diabetes mellitus (T2DM). Diabetes.
Inagaki N, Kondo K, Yoshinari T, et al. (2013). Efficacy and safety of canagliflozin in Japanese patients with type 2 diabetes: a randomized, double-blind, placebo-controlled, 12-week study. Diabetes Obes Metab.
Inagaki N, Watada H, Murai M, et al. (2012). Linagliptin added to sulphonylurea or (alpha)-glucosidase inhibitor therapy provides similar long-term safety and efficacy to metformin in Japanese patients with type 2 diabetes. Diabetologia.
Inagaki N, Watada H, Murai M, et al. (2013). Linagliptin provides effective, well-tolerated add-on therapy to pre-existing oral antidiabetic therapy over 1 year in Japanese patients with type 2 diabetes. Diabetes Obes Metab.
Ingelganullrd A, Grandy S, Langkilde A, et al. (2012). Health-related quality of life (EQ-5D) among type 2 diabetes mellitus patients treated with dapagliflozin for 24 weeks. Diabetologia.
Inzucchi SE, Rosenstock J, Seufert J, et al. (2009). Effect of combination therapy with alogliptin and pioglitazone in drug-naive patients with type 2 diabetes on (beta)-cell function and insulin resistance. Diabetes.
Ioacara S, Guja C, Ionescu-Tirgoviste C, et al. (2012). Glucose lowering treatment and cancer specific mortality in type 2 diabetes. Diabetes.
Ioacara S, Roden M, Guja C, et al. (2014). Cardiovascular safety of metformin and sulphonylureas in type 2 diabetes patients. Diabetologia.
Ionova TI, Nikitina TP, Kurbatova KA, et al. (2013). Usefulness of the hypoglycemia perspectives questionnaire (HPQ) in management of patients with type 2 diabetes. Value in Health.
Iqbal N, Allen E, Donovan M, et al. (2012). Saxagliptin monotherapy or combination therapy: Outcomes by duration of type 2 diabetes. Diabetes.
Iqbal N, Allen E, Ohman P. (2014). Long-term safety and tolerability of saxagliptin add-on therapy in older patients (aged >/= 65 years) with type 2 diabetes. Clin Interv Aging.
Iqbal N, Parker A, Frederich R, et al. (2014). Assessment of the cardiovascular safety of saxagliptin in patients with type 2 diabetes mellitus: pooled analysis of 20 clinical trials. Cardiovasc Diabetol.
Iqbal N, Weber MA, Mansfield TA, et al. (2014). Dapagliflozin lowered ambulatory BP in patients with type 2 diabetes mellitus and hypertension inadequately controlled by a reninangiotensin system blocker (plus or minus) another agent. Diabetologia.
Irace C, Fiorentino R, Carallo C, et al. (2011). Exenatide improves glycemic variability assessed by continuous glucose monitoring in subjects with type 2 diabetes. Diabetes Technol Ther.
Ishikawa S, Shimano M, Watarai M, et al. (2014). Impact of Sitagliptin on Carotid Intima-Media Thickness in Patients With Coronary Artery Disease and Impaired Glucose Tolerance or Mild Diabetes Mellitus. Am J Cardiol.
Ito H, Abe M, Antoku S, et al. (2015). Comparison of the antidiabetic effects of linagliptin among groups with a normal renal function and a mild or severe renal impairment - retrospective observation study of Japanese patients with type 2 diabetes mellitus. Expert Opin Pharmacother.
Iwamoto Y, Taniguchi T, Nonaka K, et al. (2010). Dose-ranging efficacy of sitagliptin, a dipeptidyl peptidase-4 inhibitor, in Japanese patients with type 2 diabetes mellitus. Endocr J.
Jabbour S, Hardy E, De Bruin TW, et al. (2013). Dapagliflozin helps reduce HbA1c and body weight in patients with type 2 diabetes as part of triple combination therapy: A subanalysis of four clinical studies. Diabetologia.
Jaiswal M, Martin CL, Pop-Busui R. (2014). Effects of exenatide on measures of small fiber neuropathy in patients with type 2 diabetes. Diabetes.
Janssen J, Van Den Berg E, Mattheus M, et al. (2014). Relationship between glycaemic control and cognitive function in patients with type 2 diabetes at elevated cardiovascular risk. Alzheimer's and Dementia.
Jansson SP, Svardsudd K, Andersson DK. (2014). Effects of fasting blood glucose levels and blood pressure and treatment of diabetes and hypertension on the incidence of cardiovascular disease: a study of 740 patients with incident Type 2 diabetes with up to 30 years' follow-up. Diabet Med.
Januszewicz A, Lavalle Gonzalez F, Davidson J, et al. (2013). Efficacy and safety of Canagliflozin in subjects with type 2 diabetes mellitus on background metformin. Diabetologie und Stoffwechsel.
Jariwala K, Banahan BF, Yang Y, et al. (2010). Adherence and persistence among type II diabetic patients starting monotherapy on oral hypoglycemic agents. Value in Health.
Jenkins-Jones S, Currie CJ, Mukherjee J, et al. (2013). Association between first-line monotherapy with sulfonylurea versus metformin and risk of all-cause mortality. Diabetologia.
Jensen TM, Saha K, Steinberg W. (2013). Assessment of acute pancreatitis in liraglutide type 2 diabetes trials. Pancreatology.
Jensen TM, Saha K, Steinberg WM. (2014). Is There a Link Between Liraglutide and Pancreatitis? A Post Hoc Review of Pooled and Patient-Level Data From Completed Liraglutide Type 2 Diabetes Clinical Trials. Diabetes Care.
Ji L, Han P, Liu Y, et al. (2015). Canagliflozin in Asian patients with type 2 diabetes on metformin alone or metformin in combination with sulphonylurea. Diabetes Obes Metab.
Ji L, Ma J, Li H, et al. (2014). Dapagliflozin as monotherapy in drug-naive Asian patients with type 2 diabetes mellitus: a randomized, blinded, prospective phase III study. Clin Ther.
Ji Q, Han P, Li C, et al. (2013). Efficacy and safety of alogliptin in subjects with type 2 diabetes: A randomised, double-blind, placebo-controlled, phase 3 study in mainland China, Taiwan and Hong Kong. Diabetologia.
Jin P, Peng J, Zou H, et al. (2014). The 5-year onset and regression of diabetic retinopathy in Chinese type 2 diabetes patients. PLoS ONE.
Johansen O, Neubacher D, Seck T, et al. (2013). Cardiovascular (CV) safety of linagliptin in patients with type 2 diabetes: A pooled comprehensive analysis of prospectively adjudicated CV events in phase 3 studies. Diabetologia.
Johansen OE, Neubacher D, Sech T, et al. (2014). Cardiovascular (CV) safety of linagliptin in patients with type 2 diabetes (T2D): A pooled comprehensive analysis of prospectively adjudicated CV events in phase 3 studies. Giornale Italiano di Cardiologia.
Johansen OE, Neubacher D, Seck T, et al. (2013). Cardiovascular (CV) safety of linagliptin in patients with type 2 diabetes (T2D): A pooled comprehensive analysis of prospectively adjudicated CV events in phase 3 studies. Diabetes.
Johansen OE, Neubacher D, Von Eynatten M, et al. (2012). Low cardiovascular (CV) risk hazard ratio observed with linagliptin in type 2 diabetes: Further insights from a predefined cv meta-analysis. Endocr Rev.
Johnson S, Ahren B, Stewart M, et al. (2013). HARMONY 3: 104 week efficacy of albiglutide compared to sitagliptin and glimepiride in patients with type 2 diabetes mellitus on metformin. Diabetologia.
Johnsson E, Johnsson KM, Mansfield TA, et al. (2014). Diuresis-related safety and tolerability of dapagliflozin in type 2 diabetes mellitus over 24 weeks. Diabetologia.
Johnsson K, Ptaszynska A, Apanovitch A, et al. (2012). Safety of dapagliflozin in clinical trials for type 2 diabetes mellitus. Diabetologia.
Johnsson KM, Ptaszynska A, Mansfield TA, et al. (2014). Dapagliflozin, a selective sodium-glucose cotransporter-2 inhibitor, does not increase risk of fractures. Diabetologia.
Johnston SS, Nguyen H, Felber E, et al. (2014). Retrospective study of adherence to glucagon-like peptide-1 receptor agonist therapy in patients with type 2 diabetes mellitus in the United States. Adv Ther.
Joly D, Choukroun G, Combe C, et al. (2015). Glycemic control according to glomerular filtration rate in patients with type 2 diabetes and overt nephropathy: A prospective observational study. Diabetes Res Clin Pract.
Jong GWT, Simon A, Valkhoff V, et al. (2013). Use of glucose lowering drugs and the risk of adenocarcinoma among patients with type 2 diabetes: A case-control study in the netherlands. Clinical Pharmacology and Therapeutics.
Jonker JT, Lamb HJ, van der Meer RW, et al. (2010). Pioglitazone compared with metformin increases pericardial fat volume in patients with type 2 diabetes mellitus. J Clin Endocrinol Metab.
Jonker JT, Meer RWVD, Rijzewijk LJ, et al. (2009). A differential effect of pioglitazone versus metformin on fat depots in patients with type 2 diabetes mellitus. Diabetes.
Jorgensen CH, Gislason GH, Andersson C, et al. (2010). Effects of oral glucose-lowering drugs on long term outcomes in patients with diabetes mellitus following myocardial infarction not treated with emergent percutaneous coronary intervention--a retrospective nationwide cohort study. Cardiovasc Diabetol.
Jovanovic L, Peters AL, Jiang HH, et al. (2014). Durability of glycemic control with insulin lispro mix 75/25 versus insulin glargine for older patients with type 2 diabetes. Aging Clinical and Experimental Research.
Jun Hong S, Sang Kim J, Hyoung Park J, et al. (2011). Rates of cardiovascular events were lower in type 2 diabetic patients with pioglitazone treatment after zotarolimus-eluting stent implantation during the three-year follow-up. Circulation.
Juurlink DN, Gomes T, Lipscombe LL, et al. (2009). Adverse cardiovascular events during treatment with pioglitazone and rosiglitazone: population based cohort study. BMJ.
Kadowaki T, Haneda M, Inagaki N, et al. (2013). Empagliflozin monotherapy for 12 weeks improves glycemic control in Japanese patients with type 2 diabetes (T2DM). Diabetes.
Kadowaki T, Haneda M, Inagaki N, et al. (2014). Empagliflozin Monotherapy in Japanese Patients with Type 2 Diabetes Mellitus: a Randomized, 12-Week, Double-Blind, Placebo-Controlled, Phase II Trial. Adv Ther.
Kadowaki T, Namba M, Imaoka T, et al. (2011). Improved glycemic control and reduced bodyweight with exenatide: A double-blind, randomized, phase 3 study in Japanese patients with suboptimally controlled type 2 diabetes over 24 weeks. J Diabetes Investig.
Kahl S. (2014). Improvement of pancreatic (beta)-cell function in type 2 diabetes by treatment with liraglutide: The LIBRA Trial. Diabetologe.
Kahn SE, Haffner SM, Viberti G, et al. (2010). Rosiglitazone decreases C-reactive protein to a greater extent relative to glyburide and metformin over 4 years despite greater weight gain: observations from a Diabetes Outcome Progression Trial (ADOPT). Diabetes Care.
Kahn SE, Lachin JM, Zinman B, et al. (2011). Effects of rosiglitazone, glyburide, and metformin on beta-cell function and insulin sensitivity in ADOPT. Diabetes.
Kaku K, Daida H, Kashiwagi A, et al. (2009). Long-term effects of pioglitazone in Japanese patients with type 2 diabetes without a recent history of macrovascular morbidity. Curr Med Res Opin.
Kaku K, Inoue S, Matsuoka O, et al. (2013). Efficacy and safety of dapagliflozin as a monotherapy for type 2 diabetes mellitus in Japanese patients with inadequate glycaemic control: a phase II multicentre, randomized, double-blind, placebo-controlled trial. Diabetes Obes Metab.
Kaku K, Kiyosue A, Inoue S, et al. (2013). Efficacy and safety of dapagliflozin monotherapy in Japanese patients with type 2 diabetes inadequately controlled with diet and exercise. Diabetes.
Kalra S, Deepak MC, Narang P, et al. (2014). Correlation between measures of hypoglycemia and glycemic improvement in sulfonylurea treated patients with type 2 diabetes in India: results from the OBSTACLE hypoglycemia study. J Postgrad Med.
Kalra S, Deepak MC, Narang P, et al. (2013). Usage pattern, glycemic improvement, hypoglycemia, and body mass index changes with sulfonylureas in real-life clinical practice: results from OBSTACLE Hypoglycemia Study. Diabetes Technol Ther.
Kamoi K, Takeda K, Hashimoto K, et al. (2013). Identifying risk factors for clinically significant diabetic macula edema in patients with type 2 diabetes mellitus. Curr Diabetes Rev.
Kanada S, Koiwai K, Taniguchi A, et al. (2013). Pharmacokinetics, pharmacodynamics, safety and tolerability of 4 weeks' treatment with empagliflozin in Japanese patients with type 2 diabetes mellitus. J Diabetes Investig.
Kanadiya MK, Gohel TD, Sanaka MR, et al. (2013). Relationship between type-2 diabetes and use of metformin with risk of colorectal adenoma in an American population receiving colonoscopy. J Diabetes Complications.
Kanamori A, Matsuba I. (2013). Factors associated with reduced efficacy of sitagliptin therapy: analysis of 93 patients with type 2 diabetes treated for 1.5 years or longer. J Clin Med Res.
Kanazawa I, Yamaguchi T, Yamamoto M, et al. (2010). Relationship between treatments with insulin and oral hypoglycemic agents versus the presence of vertebral fractures in type 2 diabetes mellitus. J Bone Miner Metab.
Kanazawa I, Yamaguchi T, Yano S, et al. (2010). Baseline atherosclerosis parameter could assess the risk of bone loss during pioglitazone treatment in type 2 diabetes mellitus. Osteoporos Int.
Kanazawa I, Yamamoto M, Yamaguchi T, et al. (2011). Effects of metformin and pioglitazone on serum pentosidine levels in type 2 diabetes mellitus. Exp Clin Endocrinol Diabetes.
Kao CH, Sun LM, Chen PC, et al. (2013). A population-based cohort study in Taiwan-use of insulin sensitizers can decrease cancer risk in diabetic patients?. Annals of Oncology.
Karagianni P, Polyzos SA, Kartali N, et al. (2013). Comparative efficacy of exenatide versus insulin glargine on glycemic control in type 2 diabetes mellitus patients inadequately treated with metformin monotherapy. Adv Med Sci.
Karamanos B, Thanopoulou A, Drossinos V, et al. (2011). Study comparing the effect of pioglitazone in combination with either metformin or sulphonylureas on lipid profile and glycaemic control in patients with type 2 diabetes (ECLA). Curr Med Res Opin.
Kariadi SHKS. (2013). Hypoglycaemia and weight gain in diabetes management. Obesity Research and Clinical Practice.
Karl DM, Gill J, Zhou R, et al. (2011). Clinical predictors of risk of hypoglycaemia during addition and titration of insulin glargine for type 2 diabetes. Diabetologia.
Karnieli E, Baeres FMM, Dzida G, et al. (2013). Observational study of once-daily insulin detemir in people with type 2 diabetes aged 75 years or older: A sub-analysis of data from the study of once-daily levemir (SOLVE). Drugs and Aging.
Karyekar C, Frederich R, Donovan M, et al. (2011). Achieving reductions in HbA1c (greater-than or equal to)1% without hypoglycemia with saxagliptin combination therapy: Post HOC analysis of 4 randomized controlled studies in patients with type 2 diabetes. Diabetes.
Karyekar CS, Frederich R, Ravichandran S. (2013). Clinically relevant reductions in HbA1c without hypoglycaemia: results across four studies of saxagliptin. Int J Clin Pract.
Karyekar CS, Ravichandran S, Allen E, et al. (2013). Tolerability and efficacy of glycemic control with saxagliptin in older patients (aged >/= 65 years) with inadequately controlled type 2 diabetes mellitus. Clin Interv Aging.
Kashiwagi A, Kazuta K, Goto K, et al. (2014). Ipragliflozin in combination with metformin for the treatment of Japanese patients with type 2 diabetes: ILLUMINATE, a randomised, double-blind, placebo-controlled study. Diabetes Obes Metab.
Katz A, Ptaszynska A, Mansfield T, et al. (2014). Time course of changes in glycemic parameters and body weight in patients receiving dapagliflozin as add-on or as initial combination therapy with metformin. Diabetes.
Katz A, Yeh H, Sugg JE, et al. (2014). Efficacy of dapagliflozin in patients with type 2 diabetes mellitus and baseline HbA1c =9.0%. Diabetes.
Kawaguchi T, Taniguchi E, Morita Y, et al. (2010). Association of exogenous insulin or sulphonylurea treatment with an increased incidence of hepatoma in patients with hepatitis C virus infection. Liver Int.
Kawamori R, Inagaki N, Araki E, et al. (2012). Linagliptin monotherapy provides superior glycaemic control versus placebo or voglibose with comparable safety in Japanese patients with type 2 diabetes: a randomized, placebo and active comparator-controlled, double-blind study. Diabetes Obes Metab.
Kawamori R, Node K, Hanafusa T, et al. (2013). Baseline and 1-year interim follow-up assessment of Japanese patients initiating insulin therapy who were enrolled in the cardiovascular risk evaluation in people with type 2 diabetes on insulin therapy study: An international, multicenter, observational study. Cardiovascular Diabetology.
Keoki Williams L, Padhukasahasram B, Ahmedani BK, et al. (2014). Differing Effects of Metformin on Glycemic Control by Race-Ethnicity. J Clin Endocrinol Metab.
Khalangot M, Kovtun V. (2014). Evaluation approach can significantly influence oral glucose-lowering drugs total mortality risks in retrospective cohorts of type 2 diabetes mellitus patients. Curr Diabetes Rev.
Khimani F, Shah N, Curley BF, et al. (2014). Metformin use and renal cell cancer outcomes among patients with diabetes. Journal of Clinical Oncology.
Kim DL. (2013). Metformin based dual-combination therapies in drug naive type 2 diabetic patients. Diabetes Metab J.
Kim G, Gerich J, Salsali A, et al. (2014). Urinary tract infections and genital infections in patients with Type 2 diabetes treated with empagliflozin: Pooled data from four randomised, placebo-controlled phase III trials. Diabetic Medicine.
Kim HS, Kim DM, Cha BS, et al. (2011). Efficacy of glimepiride/metformin fixed-dose combination versus metformin uptration in type 2 diabetic patients inadequately controlled on metformin monotherapy, a randomized, multicenter, parallel-group, open study in Korea. Diabetes.
Kim HS, Shin JA, Lee SH, et al. (2013). A comparative study of the effects of a dipeptidyl peptidase-IV inhibitor and sulfonylurea on glucose variability in patients with type 2 diabetes with inadequate glycemic control on metformin. Diabetes Technol Ther.
Kim MK, Ko SH, Baek KH, et al. (2009). Long-term effects of rosiglitazone on the progressive decline in renal function in patients with type 2 diabetes. Korean J Intern Med.
Kim SC, Glynn R, Liu J, et al. (2014). Dipeptidyl peptidase-4 inhibitors do not increase the risk of cardiovascular events in type 2 diabetes. Pharmacoepidemiology and Drug Safety.
Kim SC, Schneeweiss S, Glynn RJ, et al. (2013). Dipeptidyl peptidase-4 inhibitors in type 2 diabetes may reduce the risk of autoimmune diseases. Arthritis and Rheumatism.
Kim SC, Schneeweiss S, Glynn RJ, et al. (2014). Dipeptidyl peptidase-4 inhibitors in type 2 diabetes may reduce the risk of autoimmune diseases: a population-based cohort study. Ann Rheum Dis.
Kim WJ, Park CY, Jeong EH, et al. (2011). Retrospective analysis on the efficacy, safety and treatment failure group of sitagliptin for mean 10-month duration. Diabetes Metab J.
Kim YI, Kim SY, Cho SJ, et al. (2014). Long-term metformin use reduces gastric cancer risk in type 2 diabetics without insulin treatment: a nationwide cohort study. Aliment Pharmacol Ther.
King AB, Montanya E, Pratley RE, et al. (2013). Liraglutide achieves A1C targets more often than sitagliptin or exenatide when added to metformin in patients with type 2 diabetes and a baseline A1C <8.0%. Endocr Pract.
King DE, Player M, Everett CJ. (2012). The impact of pioglitazone on ADMA and oxidative stress markers in patients with type 2 diabetes. Prim Care Diabetes.
Kirk JK, Davis SW, Lawrence K, et al. (2014). Outcomes and medication use in a longitudinal cohort of type 2 diabetes patients, 2006 to 2012. Journal of Clinical Outcomes Management.
Klubo-Gwiezdzinska J, Costello J, Patel A, et al. (2013). Treatment with metformin is associated with higher remission rate in diabetic patients with thyroid cancer. Journal of Clinical Endocrinology and Metabolism.
Kodama N, Tahara N, Tahara A, et al. (2013). Effects of pioglitazone on visceral fat metabolic activity in impaired glucose tolerance or type 2 diabetes mellitus. J Clin Endocrinol Metab.
Kodama N. (2012). Effects of pioglitazone versus glimepiride on abdominal fat glucose metabolism in patients with impaired glucose tolerance and/or type 2 diabetes mellitus. Circulation.
Kohan DE, Fioretto P, Tang W, et al. (2014). Long-term study of patients with type 2 diabetes and moderate renal impairment shows that dapagliflozin reduces weight and blood pressure but does not improve glycemic control. Kidney Int.
Komajda M, McMurray JJ, Beck-Nielsen H, et al. (2010). Heart failure events with rosiglitazone in type 2 diabetes: data from the RECORD clinical trial. Eur Heart J.
Kooy A, Jager JD, Lehert P, et al. (2009). Increase in value of adding metformin to insulin therapy in type 2 diabetes: More favorable weight with less macrovascular complications. Nederlands Tijdschrift voor Geneeskunde.
Koro CE, Sowell MO, Stender M, et al. (2013). The risk of acute pancreatitis with GLP-1 receptor agonists and DPP-4 inhibitors: A retrospective observational cohort study. Diabetologia.
Kos E, Liszek MJ, Emanuele MA, et al. (2012). Effect of metformin therapy on vitamin D and vitamin B(1)(2) levels in patients with type 2 diabetes mellitus. Endocr Pract.
Kosi L, Chmelik M, Kautzky-Willer A. (2011). Impact of a DPP4-inhibitor on liver and heart lipid content and cardiovascular risk in type 2 diabetic patients. Diabetes.
Kostev K, Dippel FW, Rathmann W. (2015). Glycemic control after initiating basal insulin therapy in patients with type 2 diabetes: a primary care database analysis. Diabetes Metab Syndr Obes.
Kostev K, Dippel FW. (2012). Predictors for the initiation of a basal supported oral therapy (BOT) in type 2 diabetic patients under real-life conditions in Germany. Primary Care Diabetes.
Kovacs CS, Seshiah V, Merker L, et al. (2014). Empagliflozin (EMPA) for (greater-than or equal to)76 weeks as add-on to pioglitazone with or without metformin in patients with type 2 diabetes (T2DM). Diabetes.
Kovacs CS, Seshiah V, Swallow R, et al. (2014). Empagliflozin improves glycaemic and weight control as add-on therapy to pioglitazone or pioglitazone plus metformin in patients with type 2 diabetes: A 24-week, randomized, placebo-controlled trial. Diabetes, Obesity and Metabolism.
Kowall B, Rathmann W, Kostev K. (2015). Are sulfonylurea and insulin therapies associated with a larger risk of cancer than metformin therapy? A retrospective database analysis. Diabetes Care.
Kozawa J, Kitamura T, Nishizawa H, et al. (2013). Dipeptidyl peptidase-4 inhibitors are effective in Japanese type 2 diabetic patients with sustained endogenous insulin-secreting capacity, a higher body mass index and insulin resistance. J Diabetes Investig.
Krishnarajah G, Bhosle M, Chapman R. (2009). Patterns of up-titration in type 2 diabetes (T2DM) patients taking oral anti-diabetic drugs (OADs). Diabetes.
Krzymien J, Karnafel W. (2013). Lactic acidosis in patients with diabetes. Pol Arch Med Wewn. Kumar AA, Palamaner Subash Shantha G, Kahan S, et al. (2012). Intentional weight loss and dose reductions of anti-diabetic medications--a retrospective cohort study. PLoS One.
Kumar N, Kshitiz KK, Patra SK. (2010). Evaluation of role of oral anti-diabetic drugs on lipid profile in type 2 diabetes mellitus patients. International Journal of Pharma and Bio Sciences.
Kunte H, Busch MA, Trostdorf K, et al. (2012). Hemorrhagic transformation of ischemic stroke in diabetics on sulfonylureas. Ann Neurol.
Kuo CN, Lin YL, Wu MT. (2014). Cardiovascular risk associated with dipeptidyl peptidase-4 inhibitors compared with metformin. Pharmacotherapy.
Kuribayashi N. (2013). Clinical study of insulin secretagogues in Japanese patients with type 2 diabetes: One-year comparison between the dipeptidyl peptidase 4 inhibitor sitagliptin and the sulfonylurea glimepiride. Therapeutic Research.
Kusama M, Nakashima E, Kouchi Y, et al. (2013). Long-term clinical efficacy and safety of GLP-1 analogue liraglutide vs. DPP-4 inhibitor sitagliptin in Japanese obese adults with type 2 diabetes. Journal of Diabetes.
Kusama M, Watarai A, Kawamura T, et al. (2014). The effects of DPP-4 inhibitor and postprandial hyperglycemia on vascular endothelial function in patients with type 2 diabetes mellitus. Diabetes.
Kutoh E, Ukai Y. (2012). Alogliptin as an initial therapy in patients with newly diagnosed, drug naive type 2 diabetes: a randomized, control trial. Endocrine.
Laakso M, Rosenstock J, Groop PH, et al. (2013). Linagliptin vs. placebo followed by glimepiride in type 2 diabetes patients with moderate to severe renal impairment. Diabetes.
Laakso M, Rosenstock J, Groop PH, et al. (2015). Treatmentwith the dipeptidyl peptidase-4 inhibitor linagliptin or placebo followed by glimepiride in patients with type 2 diabetes with moderate to severe renal impairment: A 52-week, randomized, double-blind clinical trial. Diabetes Care.
Lachin JM, Viberti G, Zinman B, et al. (2011). Renal function in type 2 diabetes with rosiglitazone, metformin, and glyburide monotherapy. Clin J Am Soc Nephrol.
Lafata JE, Dobie EA, Divine GW, et al. (2009). Sustained hyperglycemia among patients with diabetes: what matters when action is needed?. Diabetes Care.
Lai YC, Li HY, Wu TJ, et al. (2014). Correlation of Circulating Acid-Labile Subunit Levels with Insulin Sensitivity and Serum LDL Cholesterol in Patients with Type 2 Diabetes: Findings from a Prospective Study with Rosiglitazone. PPAR Res.
Lajara R, Aguilar R, Hehnke U, et al. (2014). Efficacy and safety of linagliptin in subjects with long-standing type 2 diabetes mellitus (>10 years): evidence from pooled data of randomized, double-blind, placebo-controlled, phase III trials. Clin Ther.
Lamberts EJF, Souverein PC, Hugtenburg JG, et al. (2013). Achieving glycemic control differs between patients with type 2 diabetes mellitus starting on metformin and sulfonylureas. Pharmacoepidemiology and Drug Safety.
Landman GW, Kleefstra N, van Hateren KJ, et al. (2010). Metformin associated with lower cancer mortality in type 2 diabetes: ZODIAC-16. Diabetes Care.
Langkilde A, Rohwedder K, Iqbal N, et al. (2012). Measures of beta cell function and insulin sensitivity over time in patients with type 2 diabetes receiving dapagliflozin versus glipizide as add-on therapy to metformin. Diabetologia.
Langslet G, Cefalu WT, Leiter LA, et al. (2013). Canagliflozin demonstrates durable glycaemic improvements over 104 weeks compared with glimepiride in subjects with type 2 diabetes mellitus on metformin. Diabetologia.
Langslet G, Davidson JA, Valentine V, et al. (2014). Canagliflozin reduces both HbA1c and body weight in patients with type 2 diabetes mellitus on background metformin. Diabetologia.
Lavalle Gonzalez FJ, Januszewicz A, Davidson J, et al. (2013). Canagliflozin (CANA) compared with sitagliptin (SITA) in subjects with type 2 diabetes mellitus (T2DM) on metformin (MET) over 52 weeks. Diabetes.
Lavalle-Gonzalez FJ, Chiquete E, de la Luz J, et al. (2012). Achievement of therapeutic targets in Mexican patients with diabetes mellitus. Endocrinol Nutr.
Lee BW. (2013). Efficacy and safety of biphasic insulin aspart 30/70 in type 2 diabetes suboptimally controlled on oral antidiabetic therapy in Korea: A multicenter, open-label, single-arm study (Diabetes Metab J 2013;37:117-24). Diabetes and Metabolism Journal.
Lee D, Han J, Brown C, et al. (2011). Safety and tolerability of exenatide once weekly pooled summary of 1095 patients from DURATION-1, 2 and 3. Diabetologie und Stoffwechsel.
Lee EY, Hwang S, Lee SH, et al. (2014). Postprandial C-peptide to glucose ratio as a predictor of (beta)-cell function and its usefulness for staged management of type 2 diabetes. Journal of Diabetes Investigation.
Lee MS, Hsu CC, Wahlqvist ML, et al. (2011). Type 2 diabetes increases and metformin reduces total, colorectal, liver and pancreatic cancer incidences in Taiwanese: a representative population prospective cohort study of 800,000 individuals. BMC Cancer.
Lee MY, Hsiao PJ, Yang YH, et al. (2014). The association of pioglitazone and urinary tract disease in type 2 diabetic Taiwanese: bladder cancer and chronic kidney disease. PLoS One.
Lee P, Chang A, Blaum C, et al. (2012). Comparison of safety and efficacy of insulin glargine and neutral protamine hagedorn insulin in older adults with type 2 diabetes mellitus: Results from a pooled analysis. Journal of the American Geriatrics Society.
Lee WC, Dekoven M, Bouchard J, et al. (2014). Improved real-world glycaemic outcomes with liraglutide versus other incretin-based therapies in type 2 diabetes. Diabetes Obes Metab.
Lehrke M, Marx N, Patel S, et al. (2013). Safety and tolerability of linagliptin in 7400 patients with type 2 diabetes: A pooled comprehensive analysis of prospective safety reporting in placebo-controlled studies. Diabetologia.
Lehrke M, Marx N, Patel S, et al. (2014). Safety and Tolerability of Linagliptin in Patients With Type 2 Diabetes: A Comprehensive Pooled Analysis of 22 Placebo-controlled Studies. Clin Ther.
Lehrke M. (2014). Corrections: Safety and tolerability of linagliptin in patients with type 2 diabetes: A comprehensive pooled analysis of 22 placebo-controlled studies (Clinical Therapeutics (2014) 36 (1130-1146)). Clinical Therapeutics.
Leibovitz E, Gottlieb S, Goldenberg I, et al. (2013). Sitagliptin pretreatment in diabetes patients presenting with acute coronary syndrome: results from the Acute Coronary Syndrome Israeli Survey (ACSIS). Cardiovasc Diabetol.
Leiter L, Carr MC, Stewart M, et al. (2013). HARMONY 8: Once-weekly glucagon-like peptide 1 receptor agonist albiglutide vs sitagliptin for patients with type 2 diabetes with renal impairment: Week 26 results. Diabetologia.
Leiter L, Cefalu W, DeBruin T, et al. (2012). Dapagliflozin treatment for type 2 diabetes mellitus patients with a history of cardiovascular disease. Diabetologia.
Leiter LA, Carr MC, Stewart M, et al. (2013). Harmony 8: Once weekly (QW) GLP1 Agonist Albiglutide (Albi) vs. Sitagliptin (Sita) in Type 2 Diabetes (T2D) Pts With Renal Impairment (RI): Week 26 Results. Diabetes.
Leiter LA, Cefalu WT, de Bruin TW, et al. (2014). Dapagliflozin Added to Usual Care in Individuals with Type 2 Diabetes Mellitus with Preexisting Cardiovascular Disease: A 24-Week, Multicenter, Randomized, Double-Blind, Placebo-Controlled Study with a 28-Week Extension. J Am Geriatr Soc.
Leiter LA, Cefalu WT, Debruin TW, et al. (2012). Efficacy and safety of dapagliflozin for type 2 diabetes mellitus patients with a history of cardiovascular disease [abstract]. Diabetes.
Leiter LA, Langslet G, Cefalu WT, et al. (2013). Canagliflozin demonstrates durable glycemic improvements over 104 weeks compared with glimepiride in subjects with type 2 diabetes mellitus on metformin. Canadian Journal of Diabetes.
Leproust S, Dallongeville J, Valensi P, et al. (2014). Treatment maintenance duration of dual therapy with metformin and sitagliptin in type 2 diabetes-real-world data from odyssee study. Value in Health.
Levesque LE, Brophy JM, Dell'Aniello S, et al. (2010). Comparative cardiovascular morbidity and mortality of metformin in older adults with diabetes: A population-based cohort study. Pharmacoepidemiology and Drug Safety.
Levin PA, Wei W, Buysman E, et al. (2014). The INITIATOR study: Real-world treatment patterns and outcomes in patients with type 2 diabetes initiating insulin glargine or liraglutide. Diabetologia.
Lewin A, DeFronzo R, Patel S, et al. (2014). Fixed dose combinations of empagliflozin and linagliptin for 52 weeks in drug-naive subjects with type 2 diabetes. Diabetologia.
Lewin A, DeFronzo RA, Patel S, et al. (2015). Initial combination of empagliflozin and linagliptin in subjects with type 2 diabetes. Diabetes Care.
Lewin AJ, Arvay L, Liu D, et al. (2012). Efficacy and tolerability of linagliptin added to a sulfonylurea regimen in patients with inadequately controlled type 2 diabetes mellitus: an 18-week, multicenter, randomized, double-blind, placebo-controlled trial. Clin Ther.
Lewin AJ, Arvay L, Liu D, et al. (2010). Safety and efficacy of linagliptin as add-on therapy to a sulphonylurea in inadequately controlled type 2 diabetes. Diabetologia.
Lewis J, Ferrara A, Peng T, et al. (2010). Relative risk of bladder cancer with pioglitazone for diabetes mellitus: Mid-way report of a 10-year follow-up study. Pharmacoepidemiology and Drug Safety.
Lewis JD, Ferrara A, Peng T, et al. (2011). Risk of bladder cancer among diabetic patients treated with pioglitazone: interim report of a longitudinal cohort study. Diabetes Care.
Lewis JD, Habel L, Quesenberry C, et al. (2014). Proteinuria testing among patients with diabetes mellitus is associated with bladder cancer diagnosis: potential for unmeasured confounding in studies of pioglitazone and bladder cancer. Pharmacoepidemiol Drug Saf.
Li D, Yeung SC, Hassan MM, et al. (2009). Antidiabetic therapies affect risk of pancreatic cancer. Gastroenterology.
Li H, Cui R, Cai H, et al. (2010). The effect of thiazolidinediones on bone mineral density in Chinese older patients with type 2 diabetes. J Bone Miner Metab.
Li P, Chen W, Li L, et al. (2011). Glyburide/metformin therapy for patients with type 2 diabets-a multi-center, randomized double-masked study. Chinese Pharmaceutical Journal.
Li Q, Chitnis A, Hammer M, et al. (2014). Real-world clinical and economic outcomes of liraglutide versus sitagliptin in patients with type 2 diabetes mellitus in the United States. Diabetes Ther.
Li Y, Hu Y, Rajpathak S, et al. (2014). Sulfonylurea use and risk of coronary heart disease among patients with type 2 diabetes: A prospective cohort study among women. Diabetes.
Liang H, Perez A, Yang J, et al. (2012). Event rate assessment of myocardial infarction and stroke for pioglitazone relative to insulin in patients with type 2 diabetes mellitus. Diabetologia.
Lieverse L, Rodriguez M, Czupryniak L, et al. (2012). Improved glycaemic control with once-daily insulin glargine in people with type 2 diabetes inadequately controlled on insulin detemir/OAD combination therapy (RESOLUTE). Diabetologia.
Lin HC, Hsu YT, Kachingwe BH, et al. (2014). Dose effect of thiazolidinedione on cancer risk in type 2 diabetes mellitus patients: a six-year population-based cohort study. J Clin Pharm Ther.
Lin HC, Kachingwe BH, Lin HL, et al. (2014). Effects of metformin dose on cancer risk reduction in patients with type 2 diabetes mellitus: a 6-year follow-up study. Pharmacotherapy.
Lin J, Wei W, Vlajnic A, et al. (2012). Real-world practice pattern and outcomes of patients with type 2 diabetes (T2DM) initiating injectable therapy via insulin glargine disposable pen (GLA-P) or liraglutide (LIRA). Diabetes.
Lind M, Hirsch IB, Tuomilehto J, et al. (2015). Design and methods of a randomised double-blind trial of adding liraglutide to control HbA1c in patients with type 2 diabetes with impaired glycaemic control treated with multiple daily insulin injections (MDI-Liraglutide trial). Prim Care Diabetes.
Lind M, Jendle J, Torffvit O, et al. (2012). Glucagon-like peptide 1 (GLP-1) analogue combined with insulin reduces HbA1c and weight with low risk of hypoglycemia and high treatment satisfaction. Prim Care Diabetes.
Lipscombe LL. (2009). Rosiglitazone was non-inferior to metformin plus sulphonylurea for CV events but increased risk of HF and fractures in type 2 diabetes. Evidence-Based Medicine.
Lipska KJ, Bailey CJ, Inzucchi SE. (2011). Use of metformin in the setting of mild-to-moderate renal insufficiency. Diabetes Care.
List J, Sonesson C, Gause-Nilsson I, et al. (2014). No increased risk of early or late adjudicated cardiovascular events with dapagliflozin. Circulation. Little MW, Pugh TFG, Carey FJ, et al. (2011). The potential protective effect of metformin against pancreatic cancer: A case-control study in two UK centres. Pancreatology.
Liu J, Oh R, Wilson C, et al. (2014). Improvement in postprandial glucose after 2-year treatment with alogliptin in patients with type 2 diabetes inadequately controlled with metformin. Diabetologia.
Liu J, Oh R, Wilson C, et al. (2014). Improvement in postprandial glucose after a 2-year treatment with alogliptin in patients with type 2 diabetes inadequately controlled with metformin. Diabetes.
Liu J, Raanan M, Spanheimer R, et al. (2009). Pioglitazone improves 2-hour glucose level after OGTT in patients with type 2 diabetes. Canadian Journal of Diabetes.
Liu YL, Chiang CW, Tsai TR, et al. (2014). Comparing the risk for atrial fibrillation in patients with diabetes initiating metformin or sulfonylureas: A nationwide population-based cohort study in Taiwan. Pharmacoepidemiology and Drug Safety.
Liu Z, Brodovicz KG, Kou D, et al. (2012). Influence of time dependent covariates on estimation of risk of acute myocardial infarction comparing sulfonylurea with metformin in type 2 diabetes. Pharmacoepidemiology and Drug Safety.
Ljunggren O, Bolinder J, Johansson L, et al. (2012). Dapagliflozin has no long-term effect on markers of bone turnover or bone mineral density in patients with inadequately controlled type 2 diabetes on metformin. Diabetologia.
Lockman KA, Teoh WL, Richards MG, et al. (2010). Exenatide does not improve liver enzymes despite promoting significant weight loss and HbA1c reduction. Diabetic Medicine.
Loebstein R, Dushinat M, Vesterman-Landes J, et al. (2011). Database evaluation of the effects of long-term rosiglitazone treatment on cardiovascular outcomes in patients with type 2 diabetes. J Clin Pharmacol.
Loebstein R, Vasterman-Landes J, Silverman B, et al. (2009). Database evaluation of adverse cardiovascular outcomes, related to rosiglitazone (RSG), in the treatment of type 2 diabetes mellitus (T2DM) patients in the community. Clinical Pharmacology and Therapeutics.
Lopez JM, Martin S, Ektare V, et al. (2014). Short-term economic and clinical outcomes of canagliflozin compared to sitagliptin in the management of type 2 diabetes mellitus (T2DM). Value in Health.
Lu CJ, Sun Y, Muo CH, et al. (2013). Risk of stroke with thiazolidinediones: a ten-year nationwide population-based cohort study. Cerebrovasc Dis.
Lu DY, Leu HB. (2014). Metformin and risk of deep vein thrombosis: A nonrandomized, pair-matched cohort study. Journal of the American College of Cardiology.
Lu Y, Mei-Qing S, Qiu-Ling Z, et al. (2014). Effect of Piglitazone and Metformin on Retinol-binding Protein-4 and Adiponcetin in Patients with Type 2 Diabetes Mellitus Complicated with Non-alcohol Fatty Acid Liver Diseases. Zhongguo Yi Xue Ke Xue Yuan Xue Bao.
Lu ZH, Pan CY, Gao Y, et al. (2011). Zhonghua Nei Ke Za Zhi.
Lundby-Christensen L, Almdal T, Tarnow L, et al. (2014). Effect of three insulin analogue regimens on carotid intima-media thickness in patients with type 2 diabetes-the randomized copenhagen insulin and metformin therapy (CIMT) trial. Diabetes.
Luo J, Beresford S, Chen C, et al. (2014). Association between diabetes, diabetes treatment and risk of developing endometrial cancer. Br J Cancer.
Ma L, Wu N, Russo PA, et al. (2012). Comparative study of rosiglitazone versus sulfonylurea as add-on therapy: Economic analysis of type 2 diabetes mellitus. American Journal of Pharmacy Benefits.
Macconell L, Brown C, Gurney K, et al. (2012). Safety and tolerability of exenatide twice daily in patients with type 2 diabetes: integrated analysis of 5594 patients from 19 placebo-controlled and comparator-controlled clinical trials. Diabetes Metab Syndr Obes.
MacConell L, Chen S, Gurney K, et al. (2012). Safety and tolerability of GLP-1 receptor agonists in patients with type 2 diabetes in comparator-controlled DURATION trials. Diabetologia.
Macconell L, Gurney K, Malloy J, et al. (2012). Safety and tolerability of exenatide once weekly in patients with type 2 diabetes: An integrated analysis of 4328 patients. Diabetes.
MacDonald MR, Eurich DT, Majumdar SR, et al. (2010). Treatment of type 2 diabetes and outcomes in patients with heart failure: a nested case-control study from the U.K. General Practice Research Database. Diabetes Care.
MacDonald MR, Petrie MC, Home PD, et al. (2011). Incidence and prevalence of unrecognized myocardial infarction in people with diabetes: a substudy of the Rosiglitazone Evaluated for Cardiac Outcomes and Regulation of Glycemia in Diabetes (RECORD) study. Diabetes Care.
Machado HA, Vieira M, Cunha MR, et al. (2012). Metformin, but not glimepiride, improves carotid artery diameter and blood flow in patients with type 2 diabetes mellitus. Clinics (Sao Paulo).
Maeda H, Kubota A, Kanamori A, et al. (2013). Long-term efficacy and safety of sitagliptin in the treatment of Japanese Type 2 diabetes (ASSET-K1) to a target of HbA1c <7%. J Endocrinol Invest.
Mafauzy M, Hussein Z, Chan SP. (2011). The Status of Diabetes Control in Malaysia: Results of Diabcare 2008. Medical Journal of Malaysia.
Maffioli P, D'Angelo A, Perrone T, et al. (2013). Ultrasonography modifications of visceral and subcutaneous adipose tissue after pioglitazone or glibenclamide therapy combined with rosuvastatin in type 2 diabetic patients not well controlled by metformin. Diabetes.
Maffioli P, Franzetti IG, Querci F, et al. (2012). Exenatide plus metformin compared to metformin alone on beta cell function in type 2 diabetic patients. Diabetologia.
Magliano DJ, Davis WA, Shaw JE, et al. (2012). Incidence and predictors of all-cause and site-specific cancer in type 2 diabetes: The Fremantle Diabetes Study. European Journal of Endocrinology.
Maguire A, Mitchell B. (2012). Effectiveness of oral antidiabetic drugs in treatment naive patients: Trends in HbA1c in the UK. Diabetologia.
Mahaffey KW, Hafley G, Dickerson S, et al. (2013). Results of a reevaluation of cardiovascular outcomes in the RECORD trial. Am Heart J.
Maheux P, Allen E, Ravichandran S, et al. (2010). Saxagliptin added to a thiazolidinedione, metformin or a sulphonylurea improves glycaemic control in patients with inadequately controlled type 2 diabetes mellitus. Endocrine Abstracts.
Maheux P, Doucet J, Allen E, et al. (2009). Efficacy and safety of saxagliptin 5 mg once-daily therapy in elderly patients with type 2 diabetes mellitus. Diabetologia.
Mahmood IH, Nazar W. (2011). Effects of glibenclamide and metformin on prevalence of metabolic syndrome in type 2 diabetic patients. Pakistan Journal of Medical Sciences.
Makdissi A, Ghanim H, Vora M, et al. (2012). Sitagliptin exerts an antinflammatory action. J Clin Endocrinol Metab.
Malloy J, Meloni A, Han J. (2013). Efficacy and tolerability of exenatide once weekly versus sitagliptin in patients with type 2 diabetes mellitus: a retrospective analysis of pooled clinical trial data. Postgrad Med.
Malone J, Walsh B, Pencek R, et al. (2011). Efficacy and safety of exenatide once weekly across background therapies: A pooled analysis of DURATION studies. Diabetologia.
Mamtani R, Haynes K, Bilker WB, et al. (2012). Association between longer therapy with thiazolidinediones and risk of bladder cancer: a cohort study. J Natl Cancer Inst.
Mamtani R, Haynes K, Bilker WB, et al. (2012). Long-term therapy with thiazolidinediones and the risk of bladder cancer: A cohort study. Journal of Clinical Oncology.
Mamtani R, Haynes K, Bilker WB, et al. (2012). Long-term therapy with thiazolidinediones may be associated with increased incidence of bladder cancer. Pharmacoepidemiology and Drug Safety.
Mamtani R, Pfanzelter N, Haynes K, et al. (2014). Incidence of bladder cancer in patients with type 2 diabetes treated with metformin or sulfonylureas. Diabetes Care.
Mancini T, Mazziotti G, Doga M, et al. (2009). Vertebral fractures in males with type 2 diabetes treated with rosiglitazone. Bone.
Mannucci E, Zinman B, Moses A, et al. (2012). Cardiovascular safety of liglutide: A pooled analysis from phase 2 and 3 liraglutide clinical development studies. High Blood Pressure and Cardiovascular Prevention.
Mansfield TA, De Bruin T, Hardy E, et al. (2012). Glycaemic and weight-reduction benefits with dapagliflozin in patients with type 2 diabetes mellitus: Pooled subgroup analysis of nine clinical trials. Diabetologia.
Marso S, Jensen T, Moses A, et al. (2011). Cardiovascular safety of liraglutide: A pooled analysis from phase 2 and 3 liraglutide clinical development studies. Journal of Diabetes.
Marso SP, Lindsey JB, Stolker JM, et al. (2011). Cardiovascular safety of liraglutide assessed in a patient-level pooled analysis of phase 2-3 liraglutide clinical development studies. Diabetes and Vascular Disease Research.
Martin CK, Gupta AK, Smith SR, et al. (2010). Effect of pioglitazone on energy intake and ghrelin in diabetic patients. Diabetes Care. Martin S, Henk H, Chow W. (2014). Clinical and demographic characteristics of people with type 2 diabetes mellitus (T2DM) initiating canagliflozin from a united states managed care sample. Value in Health.
Martinez L, Gourdy P, Eschwege E, et al. (2013). Baseline observations from the EVIDENCE Study: Characteristics of type 2 diabetes patients initiating liraglutide. Primary Care Diabetes.
Martin-Merino E, Fortuny J, Rivero E, et al. (2012). Risk factors for incident diabetic macular edema in type II diabetes in UK primary care. Pharmacoepidemiology and Drug Safety.
Marx N, Rosenstock J, Kahn S, et al. (2013). Baseline characteristics of participants enrolled in the cardiovascular outcome study of linagliptin versus glimepiride in early type 2 diabetes (Carolina). Diabetes.
Masica A, Daoud Y, West S. (2011). Impact of oral antidiabetic drugs on development of chronic kidney disease. Pharmacoepidemiology and Drug Safety.
Matsuhashi T, Sano M, Fukuda K, et al. (2012). Sitagliptin counteracts seasonal fluctuation of glycemic control. World J Diabetes.
Matsumoto Y. (2014). Retrospective survey evaluating exenatide twice daily in obese patients with type 2 diabetes mellitus. Therapeutic Research.
Matsushita T, Kaji A, Kaji K, et al. (2012). Effects of pioglitazone and metformin combination therapy on high-molecular-weight adiponectin compared with metformin monotherapy in type 2 diabetes mellitus patients. Diabetes.
Matthaei S. (2014). Dtsch Med Wochenschr.
Matthews D, Colagiuri S, Frid A, et al. (2009). Liraglutide, a once-daily human glucagon-like peptide 1 analogue, reduces systolic blood pressure in subjects with Type 2 diabetes. Diabetic Medicine.
Matthews D, Jendle J, Nauck M, et al. (2009). Liraglutide, a once-daily human GLP-1 analogue, reduces fat percentage and visceral and subcutaneous adipose tissue compared with glimepiride when added to metformin in subjects with Type 2 diabetes. Diabetic Medicine.
Matthews D, Zinman B, Tong C, et al. (2014). Glycemic efficacy of canagliflozin (CANA) is largely independent of baseline beta-cell function or insulin sensitivity. Diabetes.
Matthews JE, Ahren B, Ye J, et al. (2014). Harmony 3 year 3 Results: Albiglutide vs sitagliptin and glimepiride in patients with type 2 diabetes mellitus on metformin. Diabetologia.
Mawatari K, Tahara N, Yasukawa H, et al. (2012). Pioglitazone decreases plasma fibroblast growth factor-21 levels in patients with type 2 diabetes. Circulation.
McAdam-Marx C, Bellows BK, Wygant GD, et al. (2013). Association of (greater-than or equal to)5% weight loss and self-reported adherence with 6-month glycemic control in type 2 diabetes mellitus (T2DM): The DELTA study. Diabetes.
McAdam-Marx C, Brixner D, Ye X, et al. (2009). A1C and weight outcomes following 6 months of analog basal insulin in insulin naive patients with type-2 diabetes in an ambulatory care setting. Value in Health.
McAdam-Marx C, Mukherjee J, Bellows BK, et al. (2014). Evaluation of the relationship between weight change and glycemic control after initiation of antidiabetic therapy in patients with type 2 diabetes using electronic medical record data. Diabetes Res Clin Pract.
McAdam-Marx C, Yu J, Shankar V, et al. (2009). Average daily dose of analog basal insulins in patients with type 2 diabetes: A matched case control analysis. Canadian Journal of Diabetes.
McCall TB, Bron M, Liu J, et al. (2009). High-density lipoprotein cholesterol-improving advantage of pioglitazone compared with non-TZD oral medications. Diabetes.
McCormic LM, Kyd AC, Rea PA, et al. (2012). Chronic DPP-4 inhibition by sitagliptin enhances both global and regional myocardial function during dobutamine stress in patients with type 2 diabetes mellitus and coronary artery disease. Heart.
McCormick LM, Kydd AC, Read PA, et al. (2014). Chronic dipeptidyl peptidase-4 inhibition with sitagliptin is associated with sustained protection against ischemic left ventricular dysfunction in a pilot study of patients with type 2 diabetes mellitus and coronary artery disease. Circ Cardiovasc Imaging.
McEwan P, Evans ML, Nyeland ME, et al. (2014). Impact of UK guidelines on clinical prescribing in patients with Type 2 diabetes: A comparative effectiveness analysis of liraglutide vs sitagliptin in the UK. Diabetic Medicine.
McGavock J, Szczepaniak LS, Ayers CR, et al. (2012). The effects of rosiglitazone on myocardial triglyceride content in patients with type 2 diabetes: a randomised, placebo-controlled trial. Diab Vasc Dis Res.
McGill JB, Sloan L, Newman J, et al. (2013). Long-term efficacy and safety of linagliptin in patients with type 2 diabetes and severe renal impairment: A 1-year, randomized, double-blind, placebo-controlled study. Diabetes Care.
McGill JB, Sloan L, Newman J, et al. (2013). Long-term efficacy and safety of linagliptin in patients with type 2 diabetes and severe renal impairment: a 1-year, randomized, double-blind, placebo-controlled study. Diabetes Care.
McGuire DK, Abdullah SM, See R, et al. (2010). Randomized comparison of the effects of rosiglitazone vs. placebo on peak integrated cardiovascular performance, cardiac structure, and function. Eur Heart J.
Medin J, Grandy S, Rohwedder K, et al. (2011). Effects of dapagliflozin on patient reported treatment satisfaction in patients with type 2 diabetes mellitus: Results from two double-blind trials. Diabetologia.
Megarbane B, Adjibade AN, Touizer E, et al. (2009). Metformin-associated lactic acidosis (MALTA) in the intensive care unit: Outcome and toxicokinetic analysis. Clinical Toxicology.
Meichun Ko E, Franasiak J, Clark LH, et al. (2012). Impact of metformin use on risk of recurrence in high-grade endometrial cancers. Journal of Clinical Oncology.
Meier JJ, Nauck MA. (2014). Risk of pancreatitis in patients treated with incretin-based therapies. Diabetologia.
Meininger G, Wysham C, Woo V, et al. (2013). Canagliflozin added on to dipeptidyl peptidase-4 inhibitors or glucagon-like peptide-1 agonists with or without other antihyperglycaemic agents in type 2 diabetes mellitus. Diabetologia.
Meloni AR, DeYoung MB, Han J, et al. (2013). Treatment of patients with type 2 diabetes with exenatide once weekly versus oral glucose-lowering medications or insulin glargine: achievement of glycemic and cardiovascular goals. Cardiovasc Diabetol.
Meneghini LF, Rosenberg N, Hollander P, et al. (2009). Effects of insulin glargine vs thiazolidinediones on glycemic and lipid variables in type 2 diabetes mellitus (T2DM): The impact of obesity. Diabetes.
Meneghini LF, Traylor L, Schwartz SL. (2010). Improved glycemic control with insulin glargine versus pioglitazone as add-on therapy to sulfonylurea or metformin in patients with uncontrolled type 2 diabetes mellitus. Endocr Pract.
Mensberg P, Nyby S, Jorgensen PG, et al. (2014). Near-normalization of glycemic control in patients with type 2 diabetes with a glucagon-like peptide-1 receptor agonist in combina tion with exercise training: A randomized, double-blinded, placebo-controlled clinical trial. Diabetes.
Merker L, Haring HU, Christiansen AV, et al. (2014). Empagliflozin (EMPA) for (greater-than or equal to)76 weeks as add-on to metformin in patients with type 2 diabetes (T2DM). Diabetes.
Merker L, Lund SS, Hantel S, et al. (2014). Efficacy and safety of empagliflozin (EMPA) in younger, overweight/ obese patients with type 2 diabetes (T2DM) with HbA1c (greater-than or equal to)8%. Diabetes.
Mijares AH. (2010). DPP-4 inhibitors vs GLP-1 receptor agonists after failure of metformin monotherapy in type 2 diabetes. Avances en Diabetologia.
Miller CG, Nino AJ, Bilezikian JP, et al. (2012). Evaluation of QCT cortical hip parameters in a clinical trial with rosiglitazone: Potential for a new study endpoint. Osteoporosis International.
Miller LA, Burudpakdee C, Zagar A, et al. (2011). Exenatide (BID) and liraglutide (QD) treatment patterns among type-2 diabetes patients in Germany. Value in Health.
Miller LA, Burudpakdee C, Zagar A, et al. (2012). Exenatide BID and liraglutide QD treatment patterns among type 2 diabetes patients in Germany. J Med Econ.
Minervini G, Cook W, Bryzinski B, et al. (2014). Efficacy and safety of saxagliptin in patients with type 2 diabetes mellitus and cardiovascular disease history or cardiovascular risk factors. Endocrine Practice.
Mirmiranpour H, Mousavizadeh M, Noshad S, et al. (2013). Comparative effects of pioglitazone and metformin on oxidative stress markers in newly diagnosed type 2 diabetes patients: a randomized clinical trial. J Diabetes Complications.
Mishra M, Kumar H, Pokharia D, et al. (2009). Effect of pioglitazone, rosiglitazone and glipizide on NOx, TNF-(alpha), VEGF, angiogenin in type 2 diabetes mellitus with cardiovascular complications. Diabetes.
Mitchell BD, Eby EL, Lage MJ. (2013). Glycemic control and the first use of oral antidiabetic agents among patients with type 2 diabetes mellitus. Curr Med Res Opin.
Mithal A, Barnett AH, Manassie J, et al. (2013). Empagliflozin in patients with type 2 diabetes mellitus and stage 3A, 3B and 4 chronic kidney disease (CKD). Diabetologia.
Mitry M, Forst T, Michelson G, et al. (2011). Addition of liraglutide improves retinal endothelial function and vascular risk profile in type 2 diabetic patients well controlled by metformin monotherapy. Diabetologia.
Mitry M, Forst T, Michelson G, et al. (2011). Pilot study on the effect of liraglutide on retinal microvascular function in type 2 diabetic patients. Diabetes.
Mitsutake R, Urata H, Okamura K, et al. (2014). Effect of alogliptin on blood pressure in patients with type 2 diabetes mellitus. Journal of the American Society of Hypertension.
Mizoguchi M, Tahara N, Tahara A, et al. (2011). Pioglitazone attenuates atherosclerotic plaque inflammation in patients with impaired glucose tolerance or diabetes a prospective, randomized, comparator-controlled study using serial FDG PET/CT imaging study of carotid artery and ascending aorta. JACC Cardiovasc Imaging.
Mogensen UM, Andersson C, Fosbol EL, et al. (2013). DPP-4 inhibitors and GLP-1 agonists in type 2 diabetes - Early assessment of cardiovascular safety in a nationwide setting. European Heart Journal.
Monami M, Colombi C, Balzi D, et al. (2011). Metformin and cancer occurrence in insulin-treated type 2 diabetic patients. Diabetes Care.
Monami M, Dicembrini I, Kundisova L, et al. (2014). A meta-analysis of the hypoglycaemic risk in randomized controlled trials with sulphonylureas in patients with type 2 diabetes. Diabetes Obes Metab.
Montanya E, Colagiuri S, Blonde L, et al. (2013). A1C improvement with liraglutide evaluated by baseline BMI. Canadian Journal of Diabetes.
Montanya E, Pratley R, Nauck M, et al. (2011). Switching from sitagliptin to liraglutide, in combination with metformin, improves treatment satisfaction in patients with type 2 diabetes. Diabetes.
Montilla S, Marchesini G, Sammarco A, et al. (2014). Drug utilization, safety, and effectiveness of exenatide, sitagliptin, and vildagliptin for type 2 diabetes in the real world: data from the Italian AIFA Anti-diabetics Monitoring Registry. Nutr Metab Cardiovasc Dis.
Morgan CL, Jenkins-Jones S, Evans M, et al. (2012). Weight change in people with type 2 diabetes: secular trends and the impact of alternative antihyperglycaemic drugs. Diabetes Obes Metab.
Morgan CL, Mukherjee J, Jenkins-Jones S, et al. (2014). Association between first-line monotherapy with sulphonylurea versus metformin and risk of all-cause mortality and cardiovascular events: a retrospective, observational study. Diabetes Obes Metab.
Morgan CL, Mukherjee J, Jenkins-Jones S, et al. (2014). Combination therapy with metformin plus sulphonylureas versus metformin plus DPP-4 inhibitors: association with major adverse cardiovascular events and all-cause mortality. Diabetes Obes Metab.
Morgan CL, Poole CD, Jenkins-Jones S, et al. (2010). Weight change for patients with type 2 diabetes: Secular trends and impact of different combinations of therapy. Value in Health.
Mori H, Okada Y, Arao T, et al. (2014). Sitagliptin improves albuminuria in patients with type 2 diabetes mellitus. J Diabetes Investig.
Mori H, Okada Y, Tanaka Y. (2012). Sitagliptin reduces microalbuminuria in patients with type 2 diabetes mellitus. Journal of Diabetes Science and Technology.
Morikawa A, Ishizeki K, Iwashima Y, et al. (2011). Pioglitazone reduces urinary albumin excretion in renin-angiotensin system inhibitor-treated type 2 diabetic patients with hypertension and microalbuminuria: the APRIME study. Clin Exp Nephrol.
Morling J, Strachan MWJ, Williamson RM, et al. (2012). Thiozolidinedione use in people with Type 2 diabetes is associated with regression of hepatosteatosis: The Edinburgh Type 2 Diabetes Study. Diabetic Medicine.
Mosenzon O, Bhatt DL, Litwak L, et al. (2014). Effect of saxagliptin on renal outcomes. Diabetes.
Mosenzon O, Davidson J, Scirica BM, et al. (2014). Incidence of fractures in patients with type 2 diabetes in the SAVOR-TIMI 53 trial. Diabetes.
Motoshima H, Igata M, Takaki Y, et al. (2012). Anti-hypertensive effect of sitagliptin in japanese subjects with type 2 diabetes (T2DM) and hypertension (HT)-a continuous Blood Pressure (BP)-lowing effect during one year. Diabetes.
Mudaliar S, Henry RR, Boden G, et al. (2014). Changes in insulin sensitivity and insulin secretion with the sodium glucose cotransporter 2 inhibitor dapagliflozin. Diabetes Technol Ther.
Mullugeta Y, Chawla R, Kebede T, et al. (2012). Dyslipidemia associated with poor glycemic control in type 2 diabetes mellitus and the protective effect of metformin supplementation. Indian J Clin Biochem.
Murakami I. (2014). Effects of bidirectional switching in sitagliptin, vildagliptin and alogliptin on glucose control in type 2 diabetes mellitus. Therapeutic Research.
Murakami T, Kokado H. (2013). Antidiabetic monotherapy by linagliptin provides multiple antiatherosclerotic effects independent of diabetic improvement for type-2 diabetics with coronary artery disease. Circulation.
Murakami T, Mizuno S. (2013). Long-term treatment with sitagliptin provides multiple ultrasonic manifested antiatherosclerotic effects independent of diabetic improvement for type-2 diabetics. Circulation.
Naderi N, May HT, Horne BD, et al. (2009). Association of rosiglitazone and pioglitazone to death and myocardial infarction among diabetic patients with coronary artery disease. Journal of the American College of Cardiology.
Nagai Y, Kato H, Sada Y, et al. (2014). Effects of sitagliptin on body fat and intrahepatic lipid content in Japanese overweight patients with type 2 diabetes. Diabetologia.
Naka KK, Papathanassiou K, Bechlioulis A, et al. (2012). Effects of pioglitazone and metformin on vascular endothelial function in patients with type 2 diabetes treated with sulfonylureas. Diab Vasc Dis Res.
Naka KK, Papathanassiou K, Bechlioulis A, et al. (2011). Effects of pioglitazone versus metformin on endothelial function in patients with type 2 diabetes treated with sulfonylureas. European Heart Journal.
Naka KK, Pappas K, Papathanassiou K, et al. (2010). Lack of effects of pioglitazone on cardiac function in patients with type 2 diabetes and evidence of left ventricular diastolic dysfunction: a tissue doppler imaging study. Cardiovasc Diabetol.
Nakano K, Hasegawa G, Fukui M, et al. (2010). Effect of pioglitazone on various parameters of insulin resistance including lipoprotein subclass according to particle size by a gel-permeation high-performance liquid chromatography in newly diagnosed patients with type 2 diabetes. Endocr J.
Nandy D, Johnson C, Basu R, et al. (2014). The effect of liraglutide on endothelial function in patients with type 2 diabetes. Diab Vasc Dis Res.
Naravadi VVR, Balasubramanian G, Pandit A, et al. (2012). Impact of anti-diabetic medications on the prevalence of colorectal neoplasm in patients with type2 diabetes mellitus. American Journal of Gastroenterology.
Narayanan RP, Anderson SG, Onyekwelu E, et al. (2012). Vitamin B12 is lower in metformin treated patients but haemoglobin is unaffected. Diabetic Medicine.
Nauck M, del Prato S, Meier JJ, et al. (2013). Dtsch Med Wochenschr.
Nauck M, Del Prato S, Rohwedder K, et al. (2010). Dapagliflozin vs glipizide in patients with type 2 diabetes mellitus inadequately controlled on metformin: 52-week results of a double-blind, randomised, controlled trial. Diabetologia.
Nauck M, Hermansen K, Frid A, et al. (2009). Liraglutide, a once-daily human GLP-1 analogue, in type 2 diabetes provides similar glycaemic control with reduced body weight compared with glimepiride when added to metformin. Journal of Diabetes.
Nauck M, Weinstock R, Umpierrez G, et al. (2013). Efficacy and safety of dulaglutide versus sitagliptin after 52 weeks in type 2 diabetes (award-5). Canadian Journal of Diabetes.
Nauck M, Weinstock RS, Umpierrez GE, et al. (2014). Efficacy and Safety of Dulaglutide Versus Sitagliptin After 52 Weeks in Type 2 Diabetes in a Randomized Controlled Trial (AWARD-5). Diabetes Care.
Nauck MA, Petrie JR, Sesti G, et al. (2012). The once-weekly human GLP-1 analogue semaglutide provides significant reductions in HbA1c and body weight in patients with type 2 diabetes. Diabetologia.
Nauck MA, Weinstock RS, Umpierrez G, et al. (2013). Efficacy and safety of dulaglutide vs sitagliptin after 52 weeks in type 2 diabetes (AWARD5). Diabetologia.
Nauck MA, Weinstock RS, Umpierrez GE, et al. (2013). Efficacy and safety of dulaglutide vs. Sitagliptin after 52 weeks in type 2 diabetes (AWARD-5). Diabetes.
Nauck M, Weinstock RS, Umpierrez GE, et al. (2015). Erratum: efficacy and safety of dulaglutide versus sitagliptin after 52 weeks in type 2 diabetes in a randomized controlled trial (AWARD-5). Diabetes Care.
Nct. (2010). A Multicenter, Randomized, Double-Blind, Placebo-Controlled, Parallel Group, Phase 3 Trial to Evaluate the Safety and Efficacy of Dapagliflozin in Subjects With Type 2 Diabetes With Inadequately Controlled Hypertension on an Angiotensin-Converting Enzyme Inhibitor (ACEI) or Angiotensin Receptor Blocker (ARB).
Nct. (2013). A Randomized, Double-Blind, Placebo-Controlled, Parallel-Group, Multicenter Study to Evaluate the Blood Pressure Reduction With Ambulatory Blood Pressure Monitoring (ABPM), Safety, and Tolerability of Canagliflozin in the Treatment of Subjects With Hypertension and Type 2 Diabetes Mellitus.
Neal B, Perkovic V, de Zeeuw D, et al. (2013). Rationale, design, and baseline characteristics of the Canagliflozin Cardiovascular Assessment Study (CANVAS)--a randomized placebo-controlled trial. Am Heart J.
Neeland I, McGuire DK, Chilton RJ, et al. (2014). The sodium glucose co-transporter 2 inhibitor (sglt2i) empagliflozin reduces weight and markers of visceral adiposity (VA) in type 2 diabetes (T2D) in short-and intermediate term. Circulation.
Nerla R, Pitocco D, Zaccardi F, et al. (2010). Effect of pioglitazone on systemic inflammation is independent of metabolic control and cardiac autonomic function in patients with type 2 diabetes. Acta Diabetol.
Neumann A, Weill A, Ricordeau P, et al. (2012). Pioglitazone and risk of bladder cancer among diabetic patients in France: a population-based cohort study. Diabetologia.
Neutel JM, Zhao C, Karyekar CS. (2013). Adding Saxagliptin to Metformin Extended Release (XR) or Uptitration of Metformin XR: Efficacy on Daily Glucose Measures. Diabetes Ther.
Nevadunsky N, VanArsdale A, Kaur G, et al. (2013). Use of metformin is associated with improved endometrial cancer survival. Gynecologic Oncology.
Newman J, McGill JB, Patel S, et al. (2011). Long-term efficacy and safety of linagliptin in patients with type 2 diabetes and severe renal impairment. Diabetologia.
Ng JM, Mellor DD, Masson EA, et al. (2010). Sulphonyurea as a cause of severe hypoglycaemia in the community. Prim Care Diabetes.
Nicholls SJ, Tuzcu EM, Wolski K, et al. (2011). Lowering the triglyceride/high-density lipoprotein cholesterol ratio is associated with the beneficial impact of pioglitazone on progression of coronary atherosclerosis in diabetic patients: insights from the PERISCOPE (Pioglitazone Effect on Regression of Intravascular Sonographic Coronary Obstruction Prospective Evaluation) study. J Am Coll Cardiol.
Nichols GA, Conner C, Brown JB. (2009). Primary failure and initial success of metformin monotherapy in clinical practice. Diabetes.
Nicolle LE, Capuano G, Fung A, et al. (2013). Urinary tract infection (UTI) With canagliflozin (CANA) in subjects with type 2 diabetes mellitus (T2DM). Diabetes.
Nieto J, Yale JF, Bakris G, et al. (2013). Efficacy and safety of canagliflozin in subjects with type 2 diabetes mellitus and chronic kidney disease over 52 weeks. Diabetologia.
Nils E, Schioler L, Svensson AM, et al. (2012). Metformin and other glucose-lowering treatments: Risks and benefits. Nationwide epidemiological study. Diabetologia.
Ning G, Hong J, Zhang Y. (2012). Effect of anti-diabetic drugs on cardiovascular outcomes in patients with type 2 diabetes and coronary artery disease. Diabetes.
Nino AJ, Bilezikian J, Borges J, et al. (2010). Effects of RSG/MET FDC on glycaemic control and BMD after 80 weeks of treatment in drug-naive type 2 diabetes mellitus subjects. Diabetologia.
Nishikawa K, Yanagawa T, Akiyama T, et al. (2012). The effect of sitagliptin on glycemic control, adiponectin and lipid metabolism. Diabetes.
Niskanen L, Cefalu WT, Leiter LA, et al. (2012). Efficacy and safety of canagliflozin, a sodium glucose co-transporter 2 inhibitor, compared with glimepiride in patients with type 2 diabetes on background metformin. Diabetologia.
Niswender K, Pi-Sunyer X, Buse J, et al. (2013). Weight change with liraglutide and comparator therapies: an analysis of seven phase 3 trials from the liraglutide diabetes development programme. Diabetes Obes Metab.
Nitta Y, Tahara N, Honda A, et al. (2012). Effects of pioglitazone on coronary arterial inflammation evaluated by serial FDG-PET/CT in patients with impaired glucose tolerant or type 2 diabetes. Circulation.
Nitta Y, Tahara N, Tahara A, et al. (2013). Pioglitazone decreases coronary artery inflammation in impaired glucose tolerance and diabetes mellitus: evaluation by FDG-PET/CT imaging. JACC Cardiovasc Imaging.
Nomoto H, Miyoshi H, Nakamura A, et al. (2014). A comparison of the effects of the DPP-4 inhibitor sitagliptin and the sulfonylurea glimepiride on metabolic parameters and endothelial function. Diabetologia.
Noriega J, Botros F, Threlkeld R, et al. (2010). The impact of LY2189265 (GLP-1 analog) on glycemic control in hispanic and non-hispanic caucasians with uncontrolled type 2 diabetes: An ego study analysis. Journal of Investigative Medicine.
Nowicki M, Rychlik I, Haller H, et al. (2011). Long-term treatment with the dipeptidyl peptidase-4 inhibitor saxagliptin in patients with type 2 diabetes mellitus and renal impairment: a randomised controlled 52-week efficacy and safety study. Int J Clin Pract.
Nowicki M, Rychlik I, Haller H, et al. (2011). Saxagliptin improves glycaemic control and is well tolerated in patients with type 2 diabetes mellitus and renal impairment. Diabetes Obes Metab.
Nyeland ME, Ploug UJ, Richards A, et al. (2015). Evaluation of the effectiveness of liraglutide and sitagliptin in type 2 diabetes: a retrospective study in UK primary care. Int J Clin Pract.
Nyeland ME, Ploug UJ, Skovgaard R, et al. (2013). Comparative effectiveness of liraglutide versus sitagliptin in type 2 diabetes in the United Kingdom: A retrospective study in primary care. Value in Health.
Nyirjesy P, Sobel JD, Fung A, et al. (2014). Genital mycotic infections with canagliflozin, a sodium glucose co-transporter 2 inhibitor, in patients with type 2 diabetes mellitus: a pooled analysis of clinical studies. Curr Med Res Opin.
Obeid R, Herrmann W, Jung J, et al. (2012). Metformin treatment is associated with lower vitamin B12 in serum without any evidence for intracellular B12 deficiency. Clinical Chemistry and Laboratory Medicine.
Oguz A, Benroubi M, Brismar K, et al. (2013). Clinical outcomes after 24 months of insulin therapy in patients with type 2 diabetes in five countries: Results from the TREAT study. Current Medical Research and Opinion.
Ohi K, Hayashi N. (2014). Efficacy and safety of linagliptin in patients with type 2 diabetes inadequately controlled by metformin. Japanese Pharmacology and Therapeutics.
Ohira M, Yamaguchi T, Ban N, et al. (2011). Pioglitazone improved cardio-ankle vascular index (CAVI) in type 2 diabetes patients through reducing oxidative stress. Journal of Diabetes.
Ohira M, Yamaguchi T, Saiki A, et al. (2014). Pioglitazone improves the cardio-ankle vascular index in patients with type 2 diabetes mellitus treated with metformin. Diabetes Metab Syndr Obes.
Ohki T, Akihiro I, Ooga T, et al. (2012). The effectiveness of liraglutide in non-alcoholic fatty liver disease patients with type 2 diabetes mellitus compared to sitagliptin and pioglitazone. Hepatology.
Ohki T, Isogawa A, Iwamoto M, et al. (2012). The effectiveness of liraglutide in nonalcoholic fatty liver disease patients with type 2 diabetes mellitus compared to sitagliptin and pioglitazone. ScientificWorldJournal.
Ohki T, Isogawa A, Takeda T, et al. (2012). The effectiveness of glucagon like peptide 1 analogue in non-alcoholic fatty liver disease patients with type 2 diabetes mellitus compared to dipeptidyl peptidase-4 inhibitor. Hepatology International.
Ohki T, Isogawa A, Takeda T, et al. (2012). The effectiveness of glucagon like peptide 1 analogue in non-alcoholic fatty liver disease patients with type 2 diabetes mellitus compared to pioglitazone. Hepatology International.
Ohmura T, Hayashi N, Encinas J. (2012). Nihon Yakurigaku Zasshi.
Oishi M, Yamazaki K, Okuguchi F, et al. (2013). Changes in oral antidiabetic prescriptions and improved glycemic control during the years 2002-2011 in Japan (JDDM32). Journal of Diabetes Investigation. Okada K, Kotani K, Yagyu H, et al. (2014). Effects of treatment with liraglutide on oxidative stress and cardiac natriuretic peptide levels in patients with type 2 diabetes mellitus. Endocrine.
Okahata S, Sakamoto K, Mitsumatsu T, et al. (2013). Evolving manners of a DPP4 inhibitor alogliptin (ALO) action on japanese diabetes patiens along with continuous administration. Diabetes.
Okura H, Takagi T, Toda I. (2010). Pioglitazone affects left ventricular filling pressure in patients with ischemic heart disease and type 2 diabetes who underwent coronary intervention: An echo doppler sub-analysis from the prevention of in-stent neointimal proliferation by pioglitazone study (POPPS). Journal of the American College of Cardiology.
Olansky L, Reasner CA, Seck T, et al. (2009). A strategy implementing initial therapy with a fixed-dose combination tablet of sitagliptin and metformin in patients with type 2 diabetes provides superior glycaemic control compared with a strategy using initial metformin monotherapy over 44 weeks. Canadian Journal of Diabetes.
Ommen ES, Xu L, O'Neill EA, et al. (2015). Comparison of Treatment with Sitagliptin or Sulfonylurea in Patients with Type 2 Diabetes Mellitus and Mild Renal Impairment: A Post Hoc Analysis of Clinical Trials. Diabetes Ther.
(2009). Once-weekly exenatide more effective in glycaemic control than twice-daily. Australian Journal of Pharmacy.
Onishi Y, Koshiyama H, Imaoka T, et al. (2013). Safety of exenatide once weekly for 52 weeks in Japanese patients with type 2 diabetes mellitus. J Diabetes Investig.
Oppong BA, Pharmer LA, Oskar S, et al. (2014). The effect of metformin on breast cancer outcomes in patients with type 2 diabetes. Cancer Med.
Origasa H, Lee SH, Nakagawa H, et al. (2013). Pioglitazone use and bladder cancer - Hospital-based results from a nested case-control study in japan. Japanese Pharmacology and Therapeutics.
Ostenson CG, Matthaei S, Reaney M, et al. (2013). Treatment outcomes after initiation of exenatide twice daily or insulin in clinical practice: 12-month results from CHOICE in six European countries. Diabetes Metab Syndr Obes.
Ott C, Raff U, Schmidt S, et al. (2014). Effects of saxagliptin on early microvascular changes in patients with type 2 diabetes. Cardiovasc Diabetol.
Ou HT, Chen YT. (2014). Comparativeeffectivenessresearch ofmetformin-based oral hypoglycemic therapy in taiwan's population-based database. Pharmacoepidemiology and Drug Safety.
Pala S, Esen O, Akcakoyun M, et al. (2010). Rosiglitazone, but not pioglitazone, improves myocardial systolic function in type 2 diabetic patients: a tissue Doppler study. Echocardiography.
Pan C, Han P, Ji Q, et al. (2013). Efficacy and safety of alogliptin in subjects with type 2 diabetes: A multicenter, randomized, double-blind, placebo-controlled, phase 3 study in mainland China, Taiwan and Hong Kong. Diabetes.
Pan CY, Li WH, Zeng JE, et al. (2013). Zhonghua Nei Ke Za Zhi.
Pan CY, Yang W, Tou C, et al. (2012). Efficacy and safety of saxagliptin in drug-naive Asian patients with type 2 diabetes mellitus: a randomized controlled trial. Diabetes Metab Res Rev.
Panda A, Panigrahi M, Pradhan S, et al. (2014). Influence of different oral anti-diabetic drugs on health related quality of life in Type 2 Diabetes Mellitus patients. Biomedicine (India).
Pandya BJ, Bron M, McCall T, et al. (2011). Achieving glycemic goal with initial versus sequential combination therapy using metformin and pioglitazone in type 2 diabetes mellitus. Curr Med Res Opin.
Pantalone KM, Kattan MW, Yu C, et al. (2012). Increased risk of overall mortality in patients with type 2 diabetes receiving glipizide, Glyburide, and Glimepiride vs. Metformin. A Retrospective Analysis. Endocrine Reviews.
Pantalone KM, Kattan MW, Yu C, et al. (2012). The risk of overall mortality in patients with Type 2 diabetes receiving different combinations of sulfonylureas and metformin: a retrospective analysis. Diabet Med.
Pantalone KM, Kattan MW, Yu C, et al. (2011). The risk of overall mortality in patients with type 2 diabetes receiving different combinations of sulfonylureas and metformin: A retrospective analysis. Endocrine Reviews.
Parikh S, Hardy E, Wei L, et al. (2012). Dapagliflozin improves glycaemic control and reduces body weight across various patient populations with type 2 diabetes mellitus. Diabetologia.
Parikh SJ, Ingelgard A, Langkilde AM, et al. (2013). Weight loss related quality of life among type 2 diabetes mellitus patients treated with dapagliflozin. Diabetologia.
Patel S, Heise T, Larbig M, et al. (2013). The dipeptidyl peptidase (DPP)-4 inhibitor linagliptin improves (beta)-cell function and postprandial glucose in type 2 diabetes (T2D). Diabetes.
Patel S, Schernthaner G, Barnett AH, et al. (2013). Renal safety of linagliptin in elderly patients with type 2 diabetes: Analysis of pooled patient data from 7 phase 3 clinical trials. Diabetologia.
Patel S, Schernthaner G, Barnett AH, et al. (2012). Safety and efficacy of linagliptin in elderly patients with type 2 diabetes: Evidence from 1331 individuals aged (greater-than or equal to)65 years. Diabetologia.
Patel S, Von Eynatten M, Weber S, et al. (2011). Linagliptin improves glycaemic control in type 2 diabetes mellitus (T2DM) patients with increased cardiovascular (CV) risk. Diabetes, Stoffwechsel und Herz.
Patel S, Weber S, Emser A, et al. (2011). Linagliptin improves glycaemic control independently of diabetes duration and insulin resistance in patients with type 2 diabetes. Diabetologia.
Paul S, Best J, Klein K, et al. (2012). Effects of HbA1c and weight reduction on blood pressure in patients with type 2 diabetes mellitus treated with exenatide*. Diabetes Obes Metab.
Paul S, Best JH, Klein K, et al. (2011). Glycemic and weight lowering effects of exenatide once weekly are associated with blood pressure changes in patients with type 2 diabetes. Diabetes.
Paulus JK, Cossor FI, Williams CD, et al. (2014). Metformin (M), diabetes (DM), and colorectal cancer (CRC) survival among U.S. Veterans. Journal of Clinical Oncology.
Pavlicek V. (2011). Effect of dapagliflozin in patients with type 2 diabetes who have inadequate glycaemic control with metformin. Diabetologe.
Pawaskar M, Bonafede M, Johnson BH, et al. (2011). Time to treatment modification among patients with Type 2 diabetes who initiated exenatide twice daily or insulin glargine. Diabetic Medicine.
Pawaskar M, Li Q, Hoogwerf BJ, et al. (2012). Metabolic outcomes of matched patient populations initiating exenatide BID vs. insulin glargine in an ambulatory care setting. Diabetes Obes Metab.
Pawaskar M, Li Q. (2012). Clinical outcomes of elderly patients initiating exenatide twice daily compared to insulin glargine. Diabetes.
Pawaskar M, Tuttle KR, Li Q, et al. (2014). Observational study of kidney function and albuminuria in patients with type 2 diabetes treated with exenatide BID versus insulin glargine. Ann Pharmacother.
Pawaskar M, Zagar A, Sugihara T, et al. (2011). Healthcare resource utilization and costs assessment of type 2 diabetes patients initiating exenatide BID or glargine: a retrospective database analysis. J Med Econ.
Pencek R, Anderson PW, Blickensderfer A, et al. (2011). Exenatide twice daily: A retrospective analysis of pooled exenatide clinical trial efficacy data stratified by race, age, duration of diabetes, BMI and gender. Diabetologia.
Pencek R, Blickensderfer A, Li Y, et al. (2012). Exenatide once weekly for the treatment of type 2 diabetes: effectiveness and tolerability in patient subpopulations. Int J Clin Pract.
Pencek R, Blickensderfer A, Li Y, et al. (2012). Exenatide twice daily: analysis of effectiveness and safety data stratified by age, sex, race, duration of diabetes, and body mass index. Postgrad Med.
Pencek R, Brunell SC, Li Y, et al. (2012). Exenatide once weekly for the treatment of type 2 diabetes mellitus: clinical results in subgroups of patients using different concomitant medications. Postgrad Med.
Pencek R, Brunell SC, Li Y, et al. (2012). Use of concomitant glucose-lowering therapies and associated treatment results observed in clinical trials of twice-daily exenatide. Endocr Pract.
Pendergrass M, Fenton C, Haffner SM, et al. (2012). Exenatide and sitagliptin are not associated with increased risk of acute renal failure: a retrospective claims analysis. Diabetes Obes Metab.
Penfornis A, Bourdel-Marchasson I, Quere S, et al. (2012). Real life evaluation of DPP4-inhibitors versus other oral antidiabetics in elderly patients with type 2 diabetes mellitus treated with metformin: Results from the HYPOCRAS study. Diabetologia.
Penfornis A, Bourdel-Marchasson I, Quere S, et al. (2012). Real-life comparison of DPP4-inhibitors with conventional oral antidiabetics as add-on therapy to metformin in elderly patients with type 2 diabetes: the HYPOCRAS study. Diabetes Metab.
Penfornis A, Bourdel-Marchasson I, Quere S, et al. (2014). Real-life comparison of DPP4-inhibitors with conventional oral antidiabetics as add-on therapy to metformin in elderly patients with type 2 diabetes: The HYPOCRAS study. Medecine des Maladies Metaboliques.
Penno G, Pucci L, Lucchesi D, et al. (2013). Effects of pioglitazone on endothelial function in type 2 diabetic patients with vascular complications: The splendor study. Diabetes.
Perciaccante A, Balbi M, Casarin P, et al. (2009). Increased risk of hepatocellular carcinoma and therapy of type 2 diabetes mellitus. Journal of Hepatology.
Perez A, Franch J, Cases A, et al. (2012). Med Clin (Barc).
Perez A, Zhao Z, Spanheimer R. (2009). Effect of pioglitazone and metformin fixed-dose combination on biomarkers of inflammation and dyslipidemia in patients with type 2 diabetes. Canadian Journal of Diabetes.
Perez A, Zhao Z, Spanheimer R. (2009). Effect of pioglitazone and metformin fixed-dose combination on hs-CRP and adiponectin in patients with type 2 diabetes. Diabetes.
Perez-Cadena Z, Daniele G, Chavez A, et al. (2012). Low-dose (15 mg/day) pioglitazone improves glycemic control and insulin secretion/insulin sensitivity index with minimal weight gain in type 2 diabetes. Endocrine Reviews.
Perez-Cadena Z, Daniele G, Chavez A, et al. (2012). Low-dose (15 mg/day) pioglitazone treatment improves glycemic control, and whole-body and adipocyte insulin resistance with minimal weight gain in type 2 diabetic subjects. Diabetes.
Perez-Monteverd A, Seck T, Xu L, et al. (2010). Efficacy and safety of sitagliptin and the fixed-dose combination of sitagliptin and metformin versus pioglitazone in drug-naive patients with type 2 diabetes. Diabetologia.
Peters KE, Chubb SA, Davis WA, et al. (2013). The relationship between hypomagnesemia, metformin therapy and cardiovascular disease complicating type 2 diabetes: the Fremantle Diabetes Study. PLoS One.
Petrica L, Petrica M, Vlad A, et al. (2009). Does PPARg-agonist rosiglitazone exert nephro- and neuroprotective effects in normoalbuminuric type 2 diabetes mellitus patients?. Journal of the Neurological Sciences.
Petrica M, Petrica L, Vlad A, et al. (2012). Neuro-and renoprotective effects of pioglitazone versus glimepiride in normoalbuminuric patients with type-2 diabetes mellitus: A randomized controlled trial. European Journal of Neurology.
Pfister R, Cairns R, Erdmann E, et al. (2013). A clinical risk score for heart failure in patients with type 2 diabetes and macrovascular disease: an analysis of the PROactive study. Int J Cardiol.
Pfutzner A, Forst T. (2011). Elevated intact proinsulin levels are indicative of Beta-cell dysfunction, insulin resistance, and cardiovascular risk: impact of the antidiabetic agent pioglitazone. J Diabetes Sci Technol.
Pfutzner A, Forst T. (2012). Impact of oral antidiabetic drugs on a biomarker panel concept for treatment selection and monitoring in patients with type 2 diabetes. Journal of Diabetes Science and Technology.
Pfutzner A, Gurieva I, Antsiferov M, et al. (2010). Saxagliptin either as add-on therapy to metformin or as initial combination therapy with metformin improves glycaemic control in patients with type 2 diabetes. Endocrine Abstracts.
Pfutzner AH, Schorsch A, Forst T, et al. (2011). Metformin/saxagliptin combination therapy can replace insulin therapy in patients with type 2 diabetes: Interim results from the SAXAswitch study. Diabetologia.
Phey Ming Y, Lockman KA, Elton R, et al. (2011). Comparison of the effects of long-term pioglitazone and rosiglitazone therapy on liver enzymes in type 2 diabetes. British Journal of Diabetes and Vascular Disease.
Philis-Tsimikas A, Del Prato S, Satman I, et al. (2012). Insulin degludec is superior to sitagliptin in improving glycemic control in insulin-naive patients with type 2 diabetes. Diabetes.
Pirags V, El Damassy H, Dabrowski M, et al. (2012). Low risk of severe hypoglycaemia in patients with type 2 diabetes mellitus starting insulin therapy with premixed insulin analogues BID in outpatient settings. International Journal of Clinical Practice.
Pistrosch F, Herbrig K, Passauer J, et al. (2010). Influence of rosiglitazone on proteinuria and renal haemodynamic in type 2 diabetic patients with overt diabetic nephropathy. Diabetologia.
Pistrosch F, Passauer J, Herbrig K, et al. (2012). Effect of thiazolidinedione treatment on proteinuria and renal hemodynamic in type 2 diabetic patients with overt nephropathy. Horm Metab Res.
Polidori D, Mari A, Ferrannini E. (2014). Canagliflozin, a sodium glucose co-transporter 2 inhibitor, improves model-based indices of beta cell function in patients with type 2 diabetes. Diabetologia.
Polidori D, Sanghvi A, Seeley R, et al. (2014). Predicted temporal changes in energy intake and energy expenditure in subjects with type 2 diabetes treated with canagliflozin. Diabetologia.
Polidori D, Zhao Y, Alba M, et al. (2012). Treatment with canagliflozin (CANA), a sodium glucose co-transporter 2 (SGLT2) inhibitor, for 26 weeks improves indices of betacell function (BCF). Diabetes.
Pollack MF, Purayidathil FW, Bolge SC, et al. (2010). Patient-reported tolerability issues with oral antidiabetic agents: Associations with adherence; treatment satisfaction and health-related quality of life. Diabetes Research and Clinical Practice.
Polyzos SA, Zografou I, Karagianni P, et al. (2015). Exenatide versus insulin glargine in type 2 diabetes inadequately treated with metformin. Diabetes Technology and Therapeutics.
Ponzani P. (2013). Long-term effectiveness and safety of liraglutide in clinical practice. Minerva Endocrinol.
Pop-Busui R, Lombardero M, Lavis V, et al. (2009). Relation of severe coronary artery narrowing to insulin or thiazolidinedione use in patients with type 2 diabetes mellitus (from the Bypass Angioplasty Revascularization Investigation 2 Diabetes Study). Am J Cardiol.
Portillo Sanchez P, Bril F, Lomonaco R, et al. (2014). Effects of extended pioglitazone treatment (PIO) on bone metabolism in patients with prediabetes and type 2 diabetes mellitus (T2DM). Diabetes.
Pottegard A, Bjerregaard BK, Larsen MD, et al. (2014). Use of exenatide and liraglutide in Denmark: A drug utilization study. European Journal of Clinical Pharmacology.
Pradhan AD, Everett BM, Cook NR, et al. (2009). Effects of initiating insulin and metformin on glycemic control and inflammatory biomarkers among patients with type 2 diabetes: the LANCET randomized trial. JAMA.
Pratley R, McCall T, Fleck P, et al. (2009). Alogliptin use in the elderly: A pooled analysis from phase 2-3 studies. Diabetes.
Pratley R, Stewart M, Cirkel D, et al. (2013). HARMONY 4: 52-week efficacy of albiglutide vs insulin glargine in patients with type 2 diabetes mellitus. Diabetologia.
Pratley R, Wilson C, Fleck P. (2012). Alogliptin plus metformin combination therapy vs alogliptin or metformin monotherapy for type 2 diabetes mellitus. Diabetologia.
Pratley RE, Kipnes MS, Fleck PR, et al. (2009). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor alogliptin in patients with type 2 diabetes inadequately controlled by glyburide monotherapy. Diabetes Obes Metab.
Pratley RE, McCall T, Fleck PR, et al. (2009). Alogliptin use in elderly people: a pooled analysis from phase 2 and 3 studies. J Am Geriatr Soc.
Pratley RE, Reusch JE, Fleck PR, et al. (2009). Efficacy and safety of the dipeptidyl peptidase-4 inhibitor alogliptin added to pioglitazone in patients with type 2 diabetes: a randomized, double-blind, placebo-controlled study. Curr Med Res Opin.
Prato S. (2011). Linagliptin for the treatment of type 2 diabetes. Expert Opin Pharmacother.
Preston MA, Riis AH, Ehrenstein V, et al. (2014). Metformin use and prostate cancer risk. Journal of Urology.
Pscherer S, Larbig M, von Stritsky B, et al. (2012). In type 2 diabetes patients, insulin glargine is associated with lower postprandial release of intact proinsulin compared with sulfonylurea treatment. J Diabetes Sci Technol.
Ptaszynska A, Chalamandaris AG, Sugg J, et al. (2012). Dapagliflozin does not impact renal function in patients with type 2 diabetes. Diabetologia.
Ptaszynska A, Johnsson K, Apanovitch AM, et al. (2013). Safety of dapagliflozin in clinical trials for type 2 diabetes mellitus. Internal Medicine Journal.
Ptaszynska A, Johnsson KM, Parikh SJ, et al. (2014). Safety profile of dapagliflozin for type 2 diabetes: pooled analysis of clinical studies for overall safety and rare events. Drug Saf.
Ptaszynska A, Mansfield T, Johnsson E, et al. (2014). Long-term renal safety with dapagliflozin treatment. Diabetologia.
Ptaszynska A, Parikh S, Hardy E, et al. (2013). Dapagliflozin improves glycaemic control and reduces body weight across various patient populations with type 2 diabetes mellitus. Internal Medicine Journal.
Pulcina A, Veronesi G, Bonfadini S, et al. (2013). Effects of medium-long term regular treatment with exenatide in type 2 diabetic patients: A lombard multicenter initiative. Giornale Italiano di Diabetologia e Metabolismo.
Punthakee Z, Almeras N, Despres JP, et al. (2014). Impact of rosiglitazone on body composition, hepatic fat, fatty acids, adipokines and glucose in persons with impaired fasting glucose or impaired glucose tolerance: a sub-study of the DREAM trial. Diabet Med.
Punthakee Z, Bosch J, Dagenais G, et al. (2012). Design, history and results of the Thiazolidinedione Intervention with vitamin D Evaluation (TIDE) randomised controlled trial. Diabetologia.
Qiu H, Rhoads GG, Berlin JA, et al. (2013). Initial metformin or sulphonylurea exposure and cancer occurrence among patients with type 2 diabetes mellitus. Diabetes Obes Metab.
Quilliam BJ, Simeone JC, Ozbay AB. (2011). Risk factors for hypoglycemia-related hospitalization in patients with type 2 diabetes: a nested case-control study. Clin Ther.
Rafeiro E, Ross SA, Meinicke T, et al. (2011). Efficacy and safety of 5 mg daily dosing regimens with linagliptin in patients with type 2 diabetes inadequately controlled on metformin. Diabetologia.
Ragonesi PD, Maffioli P, Cicero AFG, et al. (2012). Sitagliptin added to previously taken anti-diabetic agents on insulinresistance and lipid profile: A two years study evaluation. Diabetologia.
Rahman IU, Malik SA, Bashir M, et al. (2011). Monotherapy with metformin or glimepiride and changes in serum sialic acid in type 2 diabetes mellitus. British Journal of Diabetes and Vascular Disease.
Rahman IU, Malik SA, Bashir M, et al. (2010). Serum sialic acid changes in type 2 diabetic patients on metformin or rosiglitazone treatment. J Clin Pharm Ther.
Rajpathak S, Fu C, Brodovicz K, et al. (2013). Sulfonylureas associated with higher emergency room use in elderly with diabetes. Diabetes.
Rajpathak SN, Fu C, Engel SS, et al. (2013). Sulfonylureas are associated with elevated risk of hip fractures among elderly men and women with type-2 diabetes. Value in Health.
Ramos-Coss M, Rodriguez-Rivera N, Molina-Guarneros JA, et al. (2013). Lack of therapeutic efficacy on type 2 diabetic patients treated with glibenclamide and metformin in Mexico city. Pharmacoepidemiology and Drug Safety.
Raparla S, Wei W, Grabner M, et al. (2012). Real-world practice patterns, clinical and economic outcomes among us patients with type 2 diabetes initiating once-daily injectable pen therapy with insulin glargine or liraglutide. Journal of General Internal Medicine.
Rascati KL, Richards KM, Lopez D, et al. (2011). Progression to insulin for patients with diabetes mellitus using the Texas Medicaid database. Clin Ther.
Rathmann W, Kostev K, Gruenberger JB, et al. (2013). Treatment persistence, hypoglycaemia and clinical outcomes in type 2 diabetes patients with dipeptidyl peptidase-4 inhibitors and sulphonylureas: a primary care database analysis. Diabetes Obes Metab.
Ratner R, Han J, Nicewarner D, et al. (2011). Cardiovascular safety of exenatide BID: an integrated analysis from controlled clinical trials in participants with type 2 diabetes. Cardiovasc Diabetol.
Rauch T, Graefe-Mody U, Deacon CF, et al. (2012). Linagliptin increases incretin levels, lowers glucagon, and improves glycemic control in type 2 diabetes mellitus. Diabetes Therapy.
Raval Amit D, Chovatiya K, Bhavsar Ankit B, et al. (2011). Dapagliflozin for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews.
Ravichandran S, DeFronzo R, Garber AJ, et al. (2009). Once-daily saxagliptin added to metformin is well tolerated and provides sustained glycaemic control over 102 weeks in patients with type 2 diabetes. Diabetologia.
Raz I, Bhatt DL, Hirshberg B, et al. (2014). Incidence of Pancreatitis and Pancreatic Cancer in a Randomized Controlled Multicenter Trial (SAVOR-TIMI 53) of the Dipeptidyl Peptidase-4 (DPP-4) Inhibitor Saxagliptin. Diabetes Care.
Raz I, Cahn A, Scirica BM, et al. (2014). Predisposing factors for hypoglycemia: Analysis from the savortimi 53 trial. Diabetes.
Raz I, Scirica BM, Braunwald E, et al. (2014). Saxagliptin and cardiovascular outcomes in patients with type 2 diabetes. Hypertension.
Reaney M, Mitchell BD, Wang P, et al. (2013). Patient-reported outcomes with dulaglutide vs. metformin (AWARD-3). Diabetes.
Reaney M, Wang P, Lakshmanan M, et al. (2013). Patient-reported outcomes with dulaglutide, exenatide, or placebo (AWARD-1). Diabetes.
Reaney M, Yu M, Adetunji O, et al. (2014). Patient-reported outcomes (PRO) from a 104 week, phase 3, randomised, placebo-controlled study comparing once weekly dulaglutide to sitagliptin and placebo in metformin-treated patients with Type 2 diabetes; the Assessment of Weekly Administration of Dulaglutide in Diabetes (AWARD-5) trial. Diabetic Medicine.
Reasner CA, Olansky L, Seck T, et al. (2009). Initial therapy with the Fixed-Dose Combination (FDC) of sitagliptin and metformin (JANUMET(trademark)) in patients with type 2 diabetes mellitus provides superior glycaemic control and HbA1c goal attainment with lower rates of abdominal pain and diarrhea vs metformin alone. Diabetologia.
Reasner CA, Olansky L, Seck TL, et al. (2009). Initial therapy with the fixed-dose combination (FDC) of sitagliptin and metformin (JANUMETTM) in patients with type 2 diabetes mellitus (T2DM) provides superior glycemic control and A1C goal attainment with lower rates of abdominal pain and diarrhea vs. metformin alone. Diabetes.
Redaniel MT, Jeffreys M, May MT, et al. (2012). Associations of type 2 diabetes and diabetes treatment with breast cancer risk and mortality: a population-based cohort study among British women. Cancer Causes Control.
Reinhardt R, Nauck MA, Stewart M, et al. (2013). HARMONY 2 results at week 52 primary endpoint: Once-weekly albiglutide monotherapy for patients with type 2 diabetes mellitus inadequately controlled with diet and exercise. Diabetologia.
Rendell M, Chrysant S, Emser A, et al. (2011). Linagliptin effectively reduces HbA1c independent of age in patients with type 2 diabetes. Pharmacotherapy.
Rendell M, Chrysant S, Trujillo A, et al. (2011). Linagliptin improves glycemic control independent of body mass index in patients with type 2 diabetes. Journal of General Internal Medicine.
Rendell M, Chrysant SG, Emser A, et al. (2011). Linagliptin effectively reduces blood glucose independent of age in patients with type 2 diabetes. Endocr Rev. Rendell M, Chrysant SG, Emser A, et al. (2011). Linagliptin improves glycemic control independent of gender in patients with type 2 diabetes. Endocrine Reviews.
Rendell M, Chrysant SG. (2011). Review of the safety and efficacy of linagliptin as add-on therapy to metformin in patients with type 2 diabetes: A randomized, double-blind, placebo-controlled study. Postgrad Med.
Retnakaran R, Kramer CK, Zinman B. (2014). Liraglutide and the preservation of pancreatic (beta)-cell function in early type 2 diabetes: The LIBRA trial. Diabetes Care.
Reusch J, Rosenstock J, Bush M, et al. (2009). A time course analysis of glycaemic improvements with albiglutide, a long-acting GLP-1-receptor agonist for the treatment of type 2 diabetes. Canadian Journal of Diabetes.
Reusch JEB, Rosenstock J, Bush MA, et al. (2009). Albiglutide, A long-acting GLP-1 receptor agonist, improves glycemia in type 2 diabetes: time-course analysis. Diabetes.
Rhoads GG, Dain MP, Zhang Q, et al. (2011). Two-year glycaemic control and healthcare expenditures following initiation of insulin glargine versus neutral protamine Hagedorn insulin in type 2 diabetes. Diabetes, Obesity and Metabolism.
Ridderstrale M, Svaerd R, Zeller C, et al. (2013). Rationale, design and baseline characteristics of a 4-year (208-week) phase III trial of empagliflozin, an SGLT2 inhibitor, versus glimepiride as add-on to metformin in patients with type 2 diabetes mellitus with insufficient glycemic control. Cardiovasc Diabetol.
Ridderstranullle M, Andersen KR, Zeller C, et al. (2014). Empagliflozin (EMPA) compared with glimepiride (GLIM) as addon to metformin (MET) for 2 years in patients with type 2 diabetes (T2DM). Diabetes.
Ridderstranullle M, Andersen KR, Zeller C, et al. (2014). Empagliflozin compared with glimepiride as add-on to metformin for 2 years in patients with type 2 diabetes. Diabetologia.
Rijzewijk LJ, Van Der Meer RW, Lubberink M, et al. (2009). Differential action of pioglitazone and metformin on hepatic fat, substrate metabolism and perfusion in type 2 diabetic patients. Diabetologia.
Rizzo MR, Barbieri M, Boccardi V, et al. (2014). Dipeptidyl Peptidase-4 Inhibitors Have Protective Effect on Cognitive Impairment in Aged Diabetic Patients With Mild Cognitive Impairment. J Gerontol A Biol Sci Med Sci.
Robin P, Bres V, Porokhov B, et al. (2014). Focus on medical history in incretin-based drugs inducing pancreatitis in patients with type 2 diabetes mellitus. Fundamental and Clinical Pharmacology.
Roden M, Merker L, Christiansen AV, et al. (2014). Safety and tolerability of empagliflozin (EMPA) in phase III trials and their extensions in patients with type 2 diabetes (T2DM). Diabetologia.
Roden M, Weng J, Eilbracht J, et al. (2013). Empagliflozin monotherapy improves glucose control in drug-naive patients with type 2 diabetes (T2DM). Diabetes.
Roden M, Weng J, Merker L, et al. (2014). Empagliflozin (EMPA) monotherapy for (greater-than or equal to)76 weeks in drug-naive patients with type 2 diabetes (T2DM). Diabetes.
Rodriguez A, Reviriego J, Karamanos V, et al. (2011). Management of cardiovascular risk factors with pioglitazone combination therapies in type 2 diabetes: an observational cohort study. Cardiovasc Diabetol.
Rohwedder K, Hruba V, Salsali A, et al. (2011). Dapagliflozin, a sodium-glucose cotransporter 2 inhibitor, has a low propensity to cause hypoglycemia in patients with type 2 diabetes. Diabetes.
Rohwedder K, Johnsson E, Parikh S. (2014). Reduced risk of hypoglycaemic events with dapagliflozin vs glipizide as add-on therapy in type 2 diabetes mellitus: 4-year data from a phase 3 study. Diabetologia.
Rohwedder K, Langkilde AM, Iqbal N, et al. (2012). Measures of (beta)-cell function and insulin sensitivity over time in patients with type 2 diabetes receiving dapagliflozin versus glipizide as add-on therapy to metformin. Endocr Rev.
Rohwedder K, Nauck MA, Duran-Garcia S, et al. (2013). Combined hba1c and weight reduction is achieved more frequently with add-on dapagliflozin than add-on glipizide in patients with type 2 diabetes inadequately controlled on metformin. Diabetes.
Rohwedder K, Nauck MA, Duran-Garcia S, et al. (2013). Combined HbA1c and weight reduction is more frequent with dapagliflozin vs glipizide add-on treatment in patients with type 2 diabetes inadequately controlled on metformin. Diabetologia.
Rohwedder K, Parikh SJ, Johnsson E. (2014). Lower risk of hypoglycemic events with dapagliflozin than glipizide over 4 years in a phase 3 study. Diabetes.
Rokeya B, Parvin M, Bhowmik A, et al. (2011). Randomized double-blind clinical trial comparaing efficacy and safety of pioglitazone and metformin in patients with type 2 diabetes. Diabetes.
Rombopoulos G, Hatzikou M, Panitti E, et al. (2014). Association of hypoglycemia with different oral antidiabetic treatments and its impact on quality of life and disease control in patients with type 2 diabetes mellitus (the hypo study). Value in Health.
Romero SP, Andrey JL, Garcia-Egido A, et al. (2013). Metformin therapy and prognosis of patients with heart failure and new-onset diabetes mellitus. A propensity-matched study in the community. International Journal of Cardiology.
Romley JA, Goldman DP, Solomon M, et al. (2012). Exenatide therapy and the risk of pancreatitis and pancreatic cancer in a privately insured population. Diabetes Technol Ther.
Romon I, Rey G, Mandereau-Bruno L, et al. (2014). The excess mortality related to cardiovascular diseases and cancer among adults pharmacologically treated for diabetes-the 2001-2006 ENTRED cohort. Diabetic Medicine.
Rosenstock J, Fonseca VA, Gross JL, et al. (2014). Advancing Basal Insulin Replacement in Type 2 Diabetes Inadequately Controlled With Insulin Glargine Plus Oral Agents: A Comparison of Adding Albiglutide, a Weekly GLP-1 Receptor Agonist, Versus Thrice-Daily Prandial Insulin Lispro. Diabetes Care.
Rosenstock J, Gross JL, Salinas CAA, et al. (2011). Long-term safety and efficacy of saxagliptin after 4-year follow-up of patients with type 2 diabetes. Diabetes.
Rosenstock J, Inzucchi S, Seufert J, et al. (2009). Efficacy and safety of alogliptin combined with pioglitazone in patients with type 2 diabetes inadequately controlled with diet and exercise. Diabetes.
Rosenstock J, Inzucchi SE, Seufert J, et al. (2009). Combination alogliptin plus pioglitazone treatment in patients with type 2 diabetes inadequately controlled with diet and exercise. Canadian Journal of Diabetes.
Rosenstock J, Jelaska A, Kim G, et al. (2014). Empagliflozin as add-on to basal insulin for 78 weeks improves glycaemic control with weight loss in patients with Type 2 diabetes: A phase III, randomised, double-blind trial (EMPA-REG BASAL(trademark)). Diabetic Medicine.
Rosenstock J, Jelaska A, Seman L, et al. (2011). Efficacy and safety of BI 10773, a new sodium glucose cotransporter-2 (SGLT-2) inhibitor, in type 2 diabetes inadequately controlled on metformin. Diabetes.
Rosenstock J, Polidori D, Zhao Y, et al. (2010). Canagliflozin, an inhibitor of sodium glucose co-transporter 2, improves glycaemic control, lowers body weight, and improves beta cell function in subjects with type 2 diabetes on background metformin. Diabetologia.
Rosenstock J, Rendell MS, Gross JL, et al. (2009). Alogliptin added to insulin therapy in patients with type 2 diabetes reduces HbA(1C) without causing weight gain or increased hypoglycaemia. Diabetes Obes Metab.
Rosenstock J, Reusch J, Bush M, et al. (2009). Potential of albiglutide, a long-acting GLP-1 receptor agonist, in type 2 diabetes: a randomized controlled trial exploring weekly, biweekly, and monthly dosing. Diabetes Care.
Rosenstock J, Reusch J, Bush M, et al. (2009). Weekly, biweekly, and monthly albiglutide improves measures of glycaemia in patients with type 2 diabetes on background metformin therapy. Canadian Journal of Diabetes.
Rosenstock J, Reusch JEB, Bush MA, et al. (2009). The potential of albiglutide, a long-acting GLP-1 receptor agonist, in type 2 diabetes: A randomized controlled trial exploring weekly, biweekly and monthly dosing. Diabetes.
Rosenstock J, Reusch JEB, Bush MA, et al. (2009). Weekly, biweekly and monthly efficacy of albiglutide, a long-acting GLP-1-receptor agonist, in patients with type 2 diabetes receiving concomitant background metformin. Diabetologia.
Rosenstock J, Rosenberg N, Riddle MC, et al. (2009). The impact of age and disease duration on glycemic control and lipid profile: Insulin glargine vs thiazolidinediones in type 2 diabetes. Diabetes.
Rosenstock J, Vico M, Wei L, et al. (2011). Dapagliflozin added-on to pioglitazone reduces HbA1c and mitigates weight gain with low incidence of hypoglycemia in type 2 diabetes. Diabetes.
Rosenstock J, Vico M, Wei L, et al. (2012). Effects of dapagliflozin, an SGLT2 inhibitor, on HbA(1c), body weight, and hypoglycemia risk in patients with type 2 diabetes inadequately controlled on pioglitazone monotherapy. Diabetes Care.
Rosenstock J, Wei W, Davis KL, et al. (2009). Effects of exenatide, sitagliptin, and insulin on weight and glycemic control in a real-world setting. Diabetes.
Ross S, Thamer C, Cescutti J, et al. (2014). Empagliflozin twice daily versus once daily as add-on to metformin in patients with type 2 diabetes. Diabetologia.
Ross SA, Caballero AE, Del Prato S, et al. (2015). Initial combination of linagliptin and metformin compared with linagliptin monotherapy in patients with newly diagnosed type 2 diabetes and marked hyperglycaemia: a randomized, double-blind, active-controlled, parallel group, multinational clinical trial. Diabetes Obes Metab.
Ross SA, Haak T, Patel S, et al. (2014). Safety and tolerability of linagliptin and metformin in combination for patients with type 2 diabetes mellitus (T2DM). Diabetes.
Roumie CL, Huizinga MM, Liu X, et al. (2011). The effect of incident antidiabetic regimens on lipid profiles in veterans with type 2 diabetes: a retrospective cohort. Pharmacoepidemiol Drug Saf.
Round EM, Engel SS, Golm GT, et al. (2014). Safety of sitagliptin in elderly patients with type 2 diabetes: a pooled analysis of 25 clinical studies. Drugs Aging.
Roussel R, De Zeeuw D, Law G, et al. (2014). Efficacy and safety of canagliflozin (CANA) in patients with type 2 diabetes mellitus (T2DM) who progressed to stage 3A chronic kidney disease during treatment. Diabetologia.
Roussel R, Hadjadj S, Pasquet B, et al. (2013). Thiazolidinedione use is not associated with worse cardiovascular outcomes: a study in 28,332 high risk patients with diabetes in routine clinical practice: brief title: thiazolidinedione use and mortality. Int J Cardiol.
Roussel R, Travert F, Pasquet B, et al. (2010). Metformin use and mortality among patients with diabetes and atherothrombosis. Arch Intern Med.
Rubin M, Manavalan J, Agarwal S, et al. (2014). Effects of Rosiglitazone vs Metformin on Circulating Osteoclast and Osteogenic Precursor Cells in Postmenopausal Women with Type 2 Diabetes Mellitus. J Clin Endocrinol Metab.
Ruiter R, Visser LE, van Herk-Sukel MP, et al. (2012). Lower risk of cancer in patients on metformin in comparison with those on sulfonylurea derivatives: results from a large population-based follow-up study. Diabetes Care.
Saab C, Al-Saber FA, Haddad J, et al. (2015). Effectiveness and tolerability of second-line treatment with vildagliptin versus other oral drugs for type 2 diabetes in a real-world setting in the middle east: Results from the edge study. Vascular Health and Risk Management.
Saadatnia M, Siavash M, Amini A, et al. (2009). Cognitive impairment in type 2 diabetic patients using metformin or sulfonylurea: A comparative study. Alzheimer's and Dementia.
Sabale U, Ekman M, Granstrom O, et al. (2014). Cost-effectiveness of dapagliflozin (Forxiga) added to metformin compared with sulfonylurea added to metformin in type 2 diabetes in the Nordic countries. Prim Care Diabetes.
Saglietti G, Placentino G, Schellino A. (2014). Observational Study on Dipeptidyl Peptidase-4 Inhibitors: A Real-Life Analysis on 360 Patients from the ASL VCO Territory in Italy. Clin Drug Investig.
Sahin IH, Hassabo HM, Shen Y, et al. (2013). Validation of the survival benefit from metformin use in patients with type 2 diabetes and colorectal cancer. Journal of Clinical Oncology.
Saiki A, Ohira M, Endo K, et al. (2010). Pioglitazone decreases plasma angiotensin II concentration in type 2 diabetes. J Atheroscler Thromb.
Sakai Y, Suzuki A, Mugishima K, et al. (2014). Effects of alogliptin in chronic kidney disease patients with type 2 diabetes. Intern Med.
Sakoda LC, Achacoso NS, Quesenberry CP, et al. (2013). Metformin use and risk of lung cancer in patients with diabetes. Cancer Research.
Salerno Soares RL, Cruz Filho RA, Parada B, et al. (2012). Correlation between gastrointestinal symptoms(GI) with clinical factors and the treatment with Metformin in Diabetis Type 2 (type2DM) patients. Neurogastroenterology and Motility.
Salsali A, Hruba V, Ying L, et al. (2011). Reduction in postprandial glucose with dapagliflozin in type 2 diabetes. Diabetes.
Salsali A, Tang W, List JF, et al. (2010). Efficacy of dapagliflozin as monotherapy administered in the morning or evening to treat type 2 diabetes mellitus. Diabetologia.
Salvadeo SAT, Maffio P, Ferrari I, et al. (2010). Comparison between exenatide and glimepiride on metabolic control and on insulin resistance in type 2 diabetic patients with metformin therapy. Diabetologia.
Sanaiha Y, Thompson C, Elashoff D, et al. (2013). Metformin use and recurrence in patients with oral cavity/oropharynx squamous cell carcinoma. Journal of Investigative Medicine.
Saravanan K, Manna PK, Mohanta GP. (2014). A study on assessment and comparison of anti diabetic effect of monotherapy and combination therapy involving in Metformine and Glimipride. Journal of Pharmaceutical Sciences and Research.
Sasaki S, Sako Y, Hirata E, et al. (2012). In Japanese patients with type 2 diabetes, clinical predictors for effectiveness of liraglutide treatment are different between obese and non-obese patients. Diabetes.
Satoh-Asahara N, Sasaki Y, Wada H, et al. (2013). A dipeptidyl peptidase-4 inhibitor, sitagliptin, exerts anti-inflammatory effects in type 2 diabetic patients. Metabolism.
Saunders W, Nguyen H, Kalsekar I. (2014). Real-world comparative effectiveness of exenatide once weekly and liraglutide in patients with type 2 diabetes mellitus. Diabetes.
Sayo Y, Ishiko T. (2011). Clinical efficacy of the dipeptidyl peptidase-4 inhibitor, sitagliptin, in patients with type 2 diabetes for 6 months. Therapeutic Research.
Scheel-Thomsen J, Starup-Linde J, Gejl M, et al. (2014). Diabetes and stroke: Liraglutide is associated with a decreased risk of stroke in type 2 diabetes mellitus. A nested case-control study. Journal of Neurology.
Scheen AJ, Tan MH, Betteridge DJ, et al. (2009). Long-term glycaemic effects of pioglitazone compared with placebo as add-on treatment to metformin or sulphonylurea monotherapy in PROactive (PROactive 18). Diabet Med.
Scheen AJ, Van Gaal LF. (2011). Rev Med Liege.
Scheen AJ, Van Gaal LF. (2010). Rev Med Liege.
Schernthaner G, Forst T, Gulba D, et al. (2009). Challenge in diabetes therapy: Effects of thiazolidinediones beyond blood glucose control. Deutsche Medizinische Wochenschrift.
Schernthaner G, Gross JL, Rosenstock J, et al. (2013). Erratum: Canagliflozin compared with sitagliptin for patients with type 2 diabetes who do not have adequate glycemic control with metformin plus sulfonylurea: A 52-week randomized trial. Diabetes Care.
Schernthaner G, Khunti K, Patel S, et al. (2014). Safety of linagliptin in 8,778 patients with type 2 diabetes mellitus: Pooled analysis of 23 placebo-controlled, randomized clinical trials. Diabetes.
Schernthaner G, Khunti K, Patel S, et al. (2014). Safety of linagliptin in 8778 patients with type 2 diabetes mellitus: Pooled analysis of 23 placebo-controlled randomised clinical trials. Diabetologia.
Schernthaner G, Von Eynatten M, Emser A, et al. (2011). Safety and tolerability of linagliptin: A pooled analysis of data from 3572 patients with type 2 diabetes. Diabetes.
Schloot N, Haupt A, Schutt M, et al. (2014). Severe hypoglycemia during therapy with sulfonylurea in patients with type 2 diabetes (T2D) in Germany/Austria: Event rate and identification of patients at risk. Diabetologia.
Schlosser A, Owens D, Taskinen MR, et al. (2011). Long-term safety and efficacy of the DPP-4 inhibitor linagliptin: Data from a large 2-year study in subjects with type 2 diabetes mellitus. Diabetologia.
Schmidt WE, Christiansen JS, Hammer M, et al. (2009). Patient reported outcomes are superior in patients with type 2 diabetes (T2D treated with Liraglutide as compared to exenatide, when added to metformin, sulfonylurea or both. Diabetes.
Schmidt WE, Christiansen JS, Hammer M, et al. (2009). Patient reported outcomes are superior in patients with type 2 diabetes treated with liraglutide as compared to exenatide,when added to metformin,sulfonylurea or both. Value in Health.
Schmidt WE, Christiansen JS, Hammer M, et al. (2011). Patient-reported outcomes are superior in patients with Type 2 diabetes treated with liraglutide as compared with exenatide, when added to metformin, sulphonylurea or both: results from a randomized, open-label study. Diabet Med.
Schnell O. (2014). Dtsch Med Wochenschr.
Schoenauer M, Karagiannis E, Lundershausen R, et al. (2009). Weight effects of combination treatment with insulin and pioglitazone. Diabetes.
Schramm TK, Gislason GH, Rasmussen JN, et al. (2010). Differences in risk of all-cause death according to metformin in different dual combinations in patients with diabetes: A nationwide study. European Heart Journal.
Schutt M, Kern W, Zimmermann A, et al. (2010). Association of antidiabetic therapies to glycemic control and to body weight in type 2 diabetes: a German multicenter analysis on 9294 patients. Exp Clin Endocrinol Diabetes.
Scirica BM, Bhatt DL, Braunwald E, et al. (2013). Saxagliptin and cardiovascular outcomes in patients with type 2 diabetes mellitus. N Engl J Med.
Scirica BM, Bhatt DL, Braunwald E, et al. (2013). Saxagliptin and cardiovascular outcomes in patients with type 2 diabetes mellitus. N Engl J Med.
Scirica BM, Braunwald E, Raz I, et al. (2014). Heart failure, saxagliptin, and diabetes mellitus: observations from the SAVOR-TIMI 53 randomized trial. Circulation.
Scirica BM, Raz I, Cavender MA, et al. (2013). Outcomes of patients with type 2 diabetes and known congestive heart failure treated with saxagliptin: Analyses of the savor-TIMI 53 study. Circulation.
Scorsone A, Ferrara L, Spano L, et al. (2013). Influence of exenatide therapy on diabetes management in type 2 diabetes subjects ketosis prone at the onset. Italian Journal of Medicine. Scott D. (2013). Treatment of type 2 diabetes in chronic kidney disease: a case for linagliptin in the treatment of diabetes in severe renal impairment. Diabetes Metab Syndr Obes.
Scott LJ. (2011). Linagliptin: in type 2 diabetes mellitus. Drugs.
Seck T, Engel SS, Chen Y, et al. (2011). Sitagliptin (SITA) provides similar glycemic control with weight loss and less hypoglycemia compared to sulfonylurea (SU) in older patients with type 2 diabetes (T2DM). Diabetes.
Seck T, Williams-Herman DE, Chen Y, et al. (2010). Sitagliptin compared with the sulfonylurea glimepiride provides similar efficacy with less hypoglycemia and no weight gain when added to ongoing metformin therapy in patients with type 2 diabetes mellitus (T2DM). Diabetologie und Stoffwechsel.
Seck TL, Engel SS, Williams-Herman DE, et al. (2011). Sitagliptin more effectively achieves a composite endpoint for A1C reduction, lack of hypoglycemia and no body weight gain compared with glipizide. Diabetes Res Clin Pract.
Seino Y, Fujita T, Hiroi S, et al. (2011). Efficacy and safety of alogliptin in Japanese patients with type 2 diabetes mellitus: a randomized, double-blind, dose-ranging comparison with placebo, followed by a long-term extension study. Curr Med Res Opin.
Seino Y, Inagaki N, Miyahara H, et al. (2014). A randomized dose-finding study demonstrating the efficacy and tolerability of albiglutide in Japanese patients with type 2 diabetes mellitus. Curr Med Res Opin.
Seino Y, Inagaki N, Miyahara H, et al. (2012). Albiglutide significantly lowers glycemia in japanese patients with type 2 diabetes (T2D). Diabetes.
Seino Y, Nakajima H, Miyahara H, et al. (2009). Safety, tolerability, pharmacokinetics and pharmacodynamics of albiglutide, a long-acting GLP-1-receptor agonist, in Japanese subjects with type 2 diabetes mellitus. Curr Med Res Opin.
Seino Y, Rasmussen MF, Clauson P, et al. (2012). The once-daily human glucagon-like peptide-1 analog, liraglutide, improves beta-cell function in Japanese patients with type 2 diabetes. J Diabetes Investig.
Seino Y, Rasmussen MF, Nishida T, et al. (2011). Glucagon-like peptide-1 analog liraglutide in combination with sulfonylurea safely improves blood glucose measures vs sulfonylurea monotherapy in Japanese patients with type 2 diabetes: Results of a 52-week, randomized, multicenter trial. J Diabetes Investig.
Seman L, Rosenstock J, Jelaska A, et al. (2011). ENCORE: Efficacy and safety of BI 10773, a new sodium glucose cotransporter- 2 (SGLT-2) inhibitor, in type 2 diabetes patients inadequately controlled on metformin. Diabetologia.
Seong J, Choi N, Kim J, et al. (2013). Dipeptidyl peptidase-4 inhibitor use and risk of acute pancreatitis in patients with type 2 diabetes. Drug Safety.
Seong JM, Choi NK, Jung SY, et al. (2009). A comparison of pioglitazone vs rosiglitazone for heart failure in elderly type 2 patients. Pharmacoepidemiology and Drug Safety (PDS).
Seong JM, Choi NK, Shin JY, et al. (2012). Comparative effectiveness of dipeptidyl peptidase-4 inhibitor for the risk of cardiovascular and cerebrovascular disease in patients with type 2 diabetes. Pharmacoepidemiology and Drug Safety.
Sethi B, Comlekci A, Gomez-Peralta F, et al. (2013). Relationship between glycaemic control and hypoglycaemia using insulin glargine versus premixed insulin in type 2 diabetes: A subanalysis of GALAPAGOS. Diabetologia.
Seufert J, Bailey TS, Svendsen CB, et al. (2013). The effect of liraglutide on A1c and body weight is largely dependent on diabetes duration. Diabetes.
Seufert J. (2014). Dtsch Med Wochenschr.
Sha S, Polidori D, Heise T, et al. (2014). Effect of the Sodium Glucose Co-transporter 2 Inhibitor, Canagliflozin, on Plasma Volume in Patients With Type 2 Diabetes Mellitus. Diabetes Obes Metab.
Shah DD, Fonarow GC, Horwich TB. (2010). Metformin therapy and outcomes in patients with advanced systolic heart failure and diabetes. J Card Fail.
Shah N, Amanullah Afridi MH, et al. (2012). Prevelance, risk factors and outcomes of hypoglycemia in elderly diabetic patients. JPMI - Journal of Postgraduate Medical Institute.
Shani M, Feldman L, Kaiserman I, et al. (2011). Is rosiglitazone use associated with an increase in intensive eye treatment in diabetic patients? A community based study. Eur J Gen Pract.
Shankar R, Engel SS, Xu L, et al. (2012). Sitagliptin provides similar glycaemic improvement with less hypoglycaemia in the elderly with type 2 diabetes mellitus compared to sulphonylurea. Diabetologia.
Shankar R, Engel SS, Xu L, et al. (2012). Sitagliptin provides similar glycemic improvement with less hypoglycemia in the elderly with type 2 diabetes mellitus compared to sulfonylurea. Diabetes.
Shankar RR, Xu L, Golm GT, et al. (2015). A comparison of glycaemic effects of sitagliptin and sulfonylureas in elderly patients with type 2 diabetes mellitus. Int J Clin Pract.
Shaqdan W, Abdulwahid NA. (2009). Addition of pioglitazone to type 2 diabetic patients with uncontrolled diabetes regardless of their medication status. Diabetes.
Shaya FT, Lu Z, Sohn K, et al. (2009). Thiazolidinediones and cardiovascular events in high-risk patients with type-2 diabetes mellitus: a comparison with other oral antidiabetic agents. P T.
Sheehan J, Moorthy V, Colilla S, et al. (2014). Charges and health care resource use in patients with type 2 diabetes melitus after treatment initiation with saxagliptin or sitagliptin. Value in Health.
Shi L, Zhao Y, Szymanski K, et al. (2011). Impact of thiazolidinedione safety warnings on medication use patterns and glycemic control among veterans with diabetes mellitus. J Diabetes Complications.
Shimoda S, Iwashita S, Sekigami T, et al. (2014). Comparison of the efficacy of sitagliptin and glimepiride dose-up in Japanese patients with type 2 diabetes poorly controlled by sitagliptin and glimepiride in combination. J Diabetes Investig.
Shin MS, Yu JH, Jung CH, et al. (2012). The duration of sulfonylurea treatment is associated with beta-cell dysfunction in patients with type 2 diabetes mellitus. Diabetes Technol Ther.
Sicras Mainar A, Roldan Suarez C, Font Ramos B, et al. (2013). Clinical and economical consequences of the combination of metformin with dipeptidyl peptidase inhibitors in type 2 diabetes patients. Rev Clin Esp.
Sicras-Mainar A, Navarro-Artieda R. (2014). Rev Peru Med Exp Salud Publica.
Sicras-Mainar A, Navarro-Artieda R. (2014). Metformin in combination with dipeptidyl peptidase-4 inhibitors or sulfonylureas in the treatment of type 2 diabetes: Clinical and economic impact. Value in Health.
Sicras-Mainar A, Navarro-Artieda R. (2014). Use of metformin and vildagliptin for treatment of type 2 diabetes in the elderly. Drug Des Devel Ther.
Siddiqi AI, Nambi S. (2013). Head to head comparison of glucagon-like peptide 1 (GLP-1) agonists and insulin in patients with Type 2 diabetes. Diabetic Medicine. Sideleva O, Tharp WG, Ferro AJ, et al. (2011). Pioglitazone increases glucose dependent insulinotropic receptor (GIPR) expression in adipocytes in patients with type 2 diabetes. Diabetes.
Signorovitch J, Macaulay D, Diener M, et al. (2012). Hypoglycaemia and accident risk in people with Type 2 diabetes treated with antidiabetes drugs without insulin. Diabetic Medicine.
Simeone JC, Quilliam BJ. (2012). Predictors of emergency department and outpatient visits for hypoglycemia in type 2 diabetes: an analysis of a large US administrative claims database. Ann Pharmacother.
Simeone JC, Quilliam BJ. (2011). Predictors of outpatient visits for hypoglycemia in type 2 diabetes patients on oral antidiabetic agents. Diabetes.
Simo R, Guerci B, Schernthaner G, et al. (2012). Long-term administration of exenatide and changes in body weight and markers of cardiovascular risk: A comparative study with glimepiride. Diabetologia.
Simo R, Plana-Ripoll O, Puente D, et al. (2013). Impact of glucose-lowering agents on the risk of cancer in type 2 diabetic patients. The barcelona case-control study. PLoS One.
Simon ACR, GW TJ, Valkhoff VE, et al. (2013). Use of glucose lowering drugs and the risk of adenocarcinoma among patients with type 2 diabetes: A case-control study in the Netherlands. Diabetologia.
Simon D, Bradley C, Gonder-Frederick L, et al. (2010). The panorama pan-European survey: Hypoglycaemia associated with different pharmacological treatments for type 2 diabetes. Value in Health.
Sin HY, Kim JY, Jung KH. (2011). Total cholesterol, high density lipoprotein and triglyceride for cardiovascular disease in elderly patients treated with metformin. Arch Pharm Res.
Sinagra E, Mocciaro F, Messina M, et al. (2013). Colorectal cancer in patients with type 2 diabetes mellitus: Preliminary results froma retrospective analysis of 741 cases. Digestive and Liver Disease.
Sinagra E, Raimondo D, Messina M, et al. (2014). Colorectal cancer in patients with type 2 diabetes mellitus: Preliminary results from an ongoing case-control study. Digestive and Liver Disease.
Sinclair A, Bode B, Harris S, et al. (2013). Efficacy and safety of canagliflozin in older subjects with type 2 diabetes mellitus. Diabetologia.
Singh S, Chang HY, Richards TM, et al. (2013). Glucagonlike peptide 1-based therapies and risk of hospitalization for acute pancreatitis in type 2 diabetes mellitus: a population-based matched case-control study. JAMA Intern Med.
Singh S, Chang HY, Richards TM, et al. (2013). Glucagon-like peptide-1-based therapies and risk of hospitalization for acute pancreatitis in type 2 diabetes: Population based matched case-control study. Journal of General Internal Medicine.
Singh S, Chang HY, Richards TM, et al. (2013). Glucagon-like peptide-1-based therapies and risk of hospitalization for acute pancreatitis in type 2 diabetes: Population based matched case-control study. Pharmacoepidemiology and Drug Safety.
Singh S, Chang HY, Richards TM, et al. (2013). Thiazolidinedione use and risk of hospitalization for pneumonia in type 2 diabetes: Population based matched case-control study. Pharmacoepidemiology and Drug Safety.
Singh-Franco D, McLaughlin-Middlekauff J, Elrod S, et al. (2012). The effect of linagliptin on glycaemic control and tolerability in patients with type 2 diabetes mellitus: a systematic review and meta-analysis. Diabetes Obes Metab.
Sjostrom CD, Hashemi M, Sugg J, et al. (2013). Dapagliflozin-induced weight loss impacts 24 week HbA1c and blood pressure levels. Diabetologia.
Sjostrom CD, Sugg J, Tjoen C, et al. (2012). Pilot analysis of the effect of the SGLT2 inhibitor dapagliflozin on blood pressure in patients with type 2 diabetes mellitus: A pooled analysis of placebo controlled trials. European Heart Journal.
Sjostrom D, Johansson P, Ptaszynska A, et al. (2014). Dapagliflozin lowers blood pressure in hypertensive and nonhypertensive patients with type 2 diabetes. Diabetologia.
Sjostrom D, Ptaszynska A, List JF, et al. (2014). Dapagliflozin lowers blood pressure in patients with type 2 diabetes. Diabetes.
Skrivanek Z, Chien JY, Gaydos B, et al. (2013). Dose-finding results in an adaptive trial of dulaglutide combined with metformin in type 2 diabetes (AWARD-5). Diabetes.
Sloan L, Newman J, Sauce C, et al. (2011). Safety and efficacy of linagliptin in type 2 diabetes patients with severe renal impairment. Diabetes.
Smiechowski B, Azoulay L, Yin H, et al. (2013). The use of metformin and colorectal cancer incidence in patients with type II diabetes mellitus. Cancer Epidemiol Biomarkers Prev.
Smiechowski BB, Azoulay L, Yin H, et al. (2013). The use of metformin and the incidence of lung cancer in patients with type 2 diabetes. Diabetes Care.
Smiechowski BS, Suissa S, Azoulay L, et al. (2012). Metformin use and the incidence of colorectal cancer in patients with type 2 diabetes mellitus. Journal of Population Therapeutics and Clinical Pharmacology.
Smirnov II, Zhuravlyova LV, Ilchenko IA. (2011). The minimal blood glucose variability is observed in type 2 diabetic patients on metformin plus DPP-IV inhibitors. Diabetologia.
Smith CJ, Drummond RS. (2011). An observational analysis of the effect of incretin therapies in type 2 diabetes upon cardiovascular risk profiles. Diabetes, Stoffwechsel und Herz.
Smith CJ, Drummond RS. (2012). An observational study of the effect of incretin therapies upon cardiovascular risk in Type 2 diabetes. Diabetic Medicine.
Soda S, Suzuki T, Matsubayashi Y. (2013). Alogliptin can be the first treatment choice in patients with untreated severe type 2 diabetes mellitus who require inpatient treatment. Diabetes.
Soffer D, Shi J, Chung J, et al. (2012). Does metformin use among women with type II diabetes reduce the risk of gynecologic cancers?. International Journal of Gynecological Cancer.
Sohna Chandra Packiavathy A, Ramalingam M, Anchana Devi C. (2010). Role of pioglitazone on glycemic control and its effect on lipid profile in type 2 diabetics. Biomedical and Pharmacology Journal.
Song KH, Kim JM, Noh JH, et al. (2013). Efficacy and Safety of Biphasic Insulin Aspart 30/70 in Type 2 Diabetes Suboptimally Controlled on Oral Antidiabetic Therapy in Korea: A Multicenter, Open-Label, Single-Arm Study (Diabetes Metab J 2013;37:117-24). Diabetes and Metabolism Journal.
Song XX, Jiang T, Kang K, et al. (2014). Efficacy of sitagliptin combined with metformin in the initial treatment of type 2 diabetes with non-alcoholic fatty liver. Chinese Journal of New Drugs.
Spanheimer R, Erdmann E, Song E, et al. (2012). Pioglitazone and bladder malignancy during observational follow-up of PROactive: 6-year update. Diabetologia.
Spanheimer R, Zhao Z, Perez A. (2009). Effect of pioglitazone and metformin fixed-dose combination on glycemic control. Diabetes.
Spanheimer R, Zhao Z, Perez A. (2009). Evaluating effect of insulin resistance and beta cell function in a pioglitazone and metformin fixed-dose combination study. Diabetologia.
Spanheimer R, Zhao Z, Perez A. (2009). Evaluating effect of insulin resistance and ss-cell function in a pioglitazone and metformin fixed-dose combination study. Diabetes.
Spanheimer R, Zhao Z, Perez A. (2009). Improvement of glycaemic control via reducing insulin resistance with pioglitazone and metformin fixed-dose combination therapy. Canadian Journal of Diabetes.
Spinar J, Smahelova A. (2013). Vnitr Lek.
Stafford S, Elahi D, Meneilly GS. (2011). Effect of the dipeptidyl peptidase-4 inhibitor sitagliptin in older adults with type 2 diabetes mellitus. Journal of the American Geriatrics Society.
Steinberg H, Engel SS, Golm GT, et al. (2011). Initial treatment with sitagliptin as monotherapy or combination therapy improves markers of (beta)-cell function in patients with type 2 diabetes. Diabetes.
Steinberg WM, Nauck MA, Zinman B, et al. (2014). LEADER 3-lipase and amylase activity in subjects with type 2 diabetes baseline data from over 9000 subjects in the LEADER trial. Pancreas.
Stenlof K, Bode B, Harris S, et al. (2014). Long-term efficacy and safety of canagliflozin in older patients with type 2 diabetes mellitus over 104 weeks. Diabetologia.
Stenlof K, Cefalu WT, Kim KA, et al. (2013). Efficacy and safety of canagliflozin (CANA) monotherapy in subjects with type 2 diabetes mellitus (T2DM) over 52 weeks. Diabetes.
Stenlof K, Cefalu WT, Kim KA, et al. (2013). Efficacy and safety of canagliflozin monotherapy in subjects with type 2 diabetes mellitus inadequately controlled with diet and exercise over 52 weeks. Diabetologia.
Stenlof K, Cefalu WT, Kim KA, et al. (2013). Efficacy and safety of canagliflozin monotherapy in subjects with type 2 diabetes mellitus inadequately controlled with diet and exercise. Diabetes Obes Metab.
Stenlof K, Cefalu WT, Tong C, et al. (2012). Canagliflozin, a sodium glucose co-transporter 2 inhibitor, improves glycaemic control in subjects with type 2 diabetes inadequately controlled with diet and exercise. Diabetologia.
Stephens JW, Fulcher G, Matthews DR, et al. (2014). Liraglutide add-on to metformin improves postprandial glucose control compared with metformin monotherapy in patients with Type 2 diabetes: Posthoc analysis of the Liraglutide Effect and Action in Diabetes (LEAD)2 study. Diabetic Medicine.
Sterner G, Elmstahl S, Frid A. (2012). Renal function in a large cohort of metformin treated patients with type 2 diabetes mellitus. British Journal of Diabetes and Vascular Disease.
Stewart MW, Reusch JEB, Bush MA, et al. (2009). Albiglutide, a long-acting GLP-1-receptor agonist, for the treatment of type 2 diabetes: An analysis of gastrointestinal adverse events over time. Diabetologia.
Stewart MW, Reusch JEB, Bush MA, et al. (2009). The gastrointestinal adverse event profile of albiglutide, a long-acting GLP-1 receptor agonist, in type 2 diabetes. Diabetes.
Stolar MW, Grimm M, Chen S. (2013). Comparison of extended release GLP-1 receptor agonist therapy versus sitagliptin in the management of type 2 diabetes. Diabetes Metab Syndr Obes.
Stringer F, DeJongh J, Enya K, et al. (2015). Evaluation of the long-term durability and glycemic control of fasting plasma glucose and glycosylated hemoglobin for pioglitazone in Japanese patients with type 2 diabetes. Diabetes Technol Ther.
Strojek K, Hruba V, Elze M, et al. (2010). Efficacy and safety of dapagliflozin in patients with type 2 diabetes mellitus and inadequate glycaemic control on glimepiride monotherapy. Diabetologia.
Strojek K, Yoon KH, Hruba V, et al. (2014). Dapagliflozin added to glimepiride in patients with type 2 diabetes mellitus sustains glycemic control and weight loss over 48 weeks: a randomized, double-blind, parallel-group, placebo-controlled trial. Diabetes Ther.
Strongman H, D'Oca K, Langerman H, et al. (2015). A comparison of diabetes-associated secondary healthcare utilisation between alternative oral anti-hyperglycaemic dual therapy combinations with metformin in patients with type 2 diabetes: an observational cohort study. Diabetes Obes Metab.
Strongman H, D'Oca K, Langerman H, et al. (2015). Comparison of diabetes-associated secondary healthcare utilization between alternative oral antihyperglycaemic dual therapy combinations with metformin in patients with type 2 diabetes: an observational cohort study. Diabetes Obes Metab.
Stull DE, Houghton K, Traina SB. (2013). Growth mixture modeling (GMM) to determine treatment effects of canagliflozin versus sitag liptin on weight-related quality of life (WRQoL) in subjects with type 2 diabetes mellitus (T2DM). Value in Health.
Subrahmanyam BS, Bhava BSS, Venkateshwarlu E, et al. (2013). Efficacy of oral anti-diabetic agents for glycaemic control in type-2 diabetic patients with obesity. Global Journal of Pharmacology.
Succurro E, Ruffo M, Cutruzzola A, et al. (2014). Weight reduction and cardiometabolic control in diabetic patients treated with liraglutide or sitagliptin, both in association with metformin. Eating and Weight Disorders.
Succurro E, Ruffo MF, Lugara M, et al. (2013). Weight reduction and cardiometabolic control in diabetic patients treated with liraglutide or sitagliptin, both in association with metformin. High Blood Pressure and Cardiovascular Prevention.
Sudhakaran C, Fathima M, Anjana RM, et al. (2010). Effectiveness of exenatide in Asian Indians in a clinical care setting. Diabetes Technol Ther.
Sudhakaran C, Kishore U, Anjana RM, et al. (2011). Effectiveness of sitagliptin in asian Indian patients with type 2 diabetes-an Indian tertiary diabetes care center experience. Diabetes Technol Ther.
Suh DC, Lee DH, McGuire M, et al. (2011). Impact of rosiglitazone therapy on the lipid profile, glycemic control, and medication costs among type 2 diabetes patients. Curr Med Res Opin.
Sultana SS, Amin F, Rahman A, et al. (2012). A comparative study with metformin and pioglitazone versus metformin alone in nonalcoholic fatty liver disease in newly detected glucose intolerant patients. Diabetologia.
Sun GE, Wells BJ, Yip K, et al. (2014). Gender-specific effects of oral hypoglycaemic agents on cancer risk in type 2 diabetes mellitus. Diabetes Obes Metab.
Sun SX, Vallarino C, Xu Y, et al. (2009). Risk of stroke or myocardial infarction of t2dm patients treated with pioglitazone or non-thiazolidinedione in a managed care setting in the United States. Value in Health.
Suraj B, Tripathi CD, Biswas K, et al. (2015). A Comparative Evaluation of Safety, Efficacy and Cost Effectiveness of Three Add on Treatment Regimens in Type 2 Diabetics; Not Controlled by Metformin Alone. Research Journal of Pharmacy and Technology.
Suzuki K. (2015). Quantifying the effect of metformin 1000 mg/day in japanese patients with type 2 diabetes mellitus. Therapeutic Research.
Svacina S, Vesela V. (2013). Vnitr Lek.
Swinnen SGH, Dain MP, Aronson R, et al. (2009). Once-daily insulin glargine requires a significantly lower dose than insulin detemir twice daily to achieve good glycaemic control in patients with type 2 diabetes failing oral therapy. Diabetologia.
Swislocki ALM, Meier JL, Najera SM, et al. (2011). Long-Term maintenance of glucose control in veterans with type 2 diabetes mellitus using oral agents. Metabolic Syndrome and Related Disorders.
T MJ, Saha K, Steinberg W. (2012). Assessment of acute pancreatitis in liraglutide type 2 diabetes trials. Pancreas.
Tahbaz A, Jones R, Sapin H, et al. (2011). Exenatide twice daily versus insulin glargine in the HEELA (Helping Evaluate Exenatide Compared with Long-acting Insulin) study in Type 2 diabetes: Evaluation of treatment-emergent nausea and changes in body weight. Diabetic Medicine.
Tahrani AA. (2014). SGLT-2 inhibitors as second-line therapy in type 2 diabetes. Lancet Diabetes Endocrinol.
Tajiri Y, Tsuruta M, Ohki T, et al. (2012). Long-term efficacy of sitagliptin for the treatment of type 2 diabetic patients in Japan. Endocr J.
Takagi T, Okura H, Kobayashi Y, et al. (2009). A prospective, multicenter, randomized trial to assess efficacy of pioglitazone on in-stent neointimal suppression in type 2 diabetes: POPPS (Prevention of In-Stent Neointimal Proliferation by Pioglitazone Study). JACC Cardiovasc Interv.
Takai M, Ishikawa M, Maeda H, et al. (2014). Safety and efficacy of adding sitagliptin to insulin in patients with type 2 diabetes: the ASSIST-K study. Diabetes Res Clin Pract.
Takayuki Fujiwara T, Yoshida M, Nakamura T, et al. (2014). Administration of dipeptidyl peptidase-4 inhibitors is associated with improvement of left ventricular diastolic function after acute myocardial infarction in diabetic patients. European Journal of Heart Failure.
Takihata M, Nakamura A, Tajima K, et al. (2012). Comparative study of sitagliptin with pioglitazone for strict glycemic control: The compass study. Diabetes.
Takihata M, Nakamura A, Tajima K, et al. (2013). Comparative study of sitagliptin with pioglitazone in Japanese type 2 diabetic patients: the COMPASS randomized controlled trial. Diabetes Obes Metab.
Tamblyn R, Abrahamowicz M, Beauchamp ME, et al. (2013). International pharmacosurveillance: Modeling exposure to diabetic drugs in relationship to cardiovascular effects. Pharmacoepidemiology and Drug Safety.
Tamez-Perez HE. (2015). Rev Med Inst Mex Seguro Soc.
Tamir O, Wainstein J, Raz I, et al. (2012). Treatment modality, quality of life, and patient-perceived difficulties in the treatment of diabetes. Review of Diabetic Studies.
Tamita K, Okura H, Takagi T, et al. (2013). Impact of in-stent neointimal suppression by pioglitazone on clinical outcome in type 2 diabetes: 5-year follow-up of the prevention of neointimal proliferation by pioglitazone study. EuroIntervention.
Tarbett AK, VanRoekel RC, Howard RS, et al. (2011). The use of optical coherence tomography to determine the effect of thiazolidinediones on retinal thickness in patients with type 2 diabetes. J Diabetes Sci Technol.
Tasic D, Brixner D, Goodman M. (2010). The impact of oral antidiabetics on weight in the elderly with type 2 diabetes mellitus in the ambulatory setting. Value in Health.
Tatosian DA, Guo Y, Schaeffer AK, et al. (2013). Dipeptidyl peptidase-4 inhibition in patients with type 2 diabetes treated with saxagliptin, sitagliptin, or vildagliptin. Diabetes Ther.
Teigland C, Parente A, Mehta S, et al. (2013). Comparative effectiveness of sulfonylurea and metformin on risk of cardiac events in middle-aged adults with type II diabetes mellitus. Diabetes.
Terauchi Y, Satoi Y, Takeuchi M, et al. (2014). Monotherapy with the once weekly GLP-1 receptor agonist dulaglutide for 12 weeks in Japanese patients with type 2 diabetes: dose-dependent effects on glycaemic control in a randomised, double-blind, placebo-controlled study. Endocr J.
Tharp WG, Sideleva O, Elahi D, et al. (2011). Pioglitazone (PIO) does not enhance glucose-dependent insulinotropic peptide (GIP) stimulated insulin secretion in subjects with well-controlled t2dm. Diabetes.
Tharp WG, Sideleva O, Maple RL, et al. (2011). Independent increases in insulin sensitivity and adipocyte GIP-R expression following pioglitazone (PIO) treatment in patients with type 2 diabetes mellitus (T2DM). Obesity.
(2009). The LEAD study program - Liraglutide: Glycemic control with weight reduction. MMW-Fortschritte der Medizin.
Thomas J. (2012). Addition of linagliptin to metformin improves glycaemic control in type 2 diabetes. Australian Journal of Pharmacy.
Thong KY, Jose B, Sukumar N, et al. (2011). Safety, efficacy and tolerability of exenatide in combination with insulin in the Association of British Clinical Diabetologists nationwide exenatide audit. Diabetes, Obesity and Metabolism.
Thong KY, Gupta PS, Blann AD, et al. (2015). The influence of age and metformin treatment status on reported gastrointestinal side effects with liraglutide treatment in type 2 diabetes. Diabetes Res Clin Pract.
Thrasher J, Daniels K, Patel S, et al. (2012). Black/African American patients with type 2 diabetes mellitus: study design and baseline patient characteristics from a randomized clinical trial of linagliptin. Expert Opin Pharmacother.
Thrasher J, Daniels K, Patel S, et al. (2014). Efficacy and Safety of Linagliptin in Black/African American Patients with Type 2 Diabetes: A 6-month, Randomized, Double-blind, Placebo-controlled Study. Endocr Pract.
Tikkanen I, Narko K, Zeller C, et al. (2013). Empagliflozin improves 24-hour blood pressure profiles in patients with type 2 diabetes and hypertension. Circulation.
Tikkanen I, Narko K, Zeller C, et al. (2014). Empagliflozin improves blood pressure in patients with type 2 diabetes (T2DM) and hypertension. Giornale Italiano di Cardiologia.
Tikkanen I, Narko K, Zeller C, et al. (2015). Empagliflozin reduces blood pressure in patients with type 2 diabetes and hypertension. Diabetes Care.
Tikkanen I, Narko K, Zeller C, et al. (2014). Empagliflozin reduces blood pressure in patients with Type 2 diabetes and hypertension: A phase III, randomised, double-blind, placebo-controlled trial (EMPA-REG BP(trademark)). Diabetic Medicine.
Tikkanen I, Narko K, Zeller C, et al. (2014). Empagliflozin reduces blood pressure in patients with Type 2 diabetes and hypertension: A phase III, randomised, double-blind, placebo-controlled trial (EMPA-REG BP). Diabetic Medicine.
Timofte L, Stratmann B, Quester W, et al. (2013). Exenatide and liraglutide - Side effects. Comparative clinical study. Farmacia.
Timofte L, Stratmann B, Bojita MT, et al. (2015). Global view on safety and efficacy of GLP-1 receptor agonists and DPP-4 inhibitors: The study shows data from clinical routine use in a cohort of patients with type 2 diabetes mellitus. Diabetes, Stoffwechsel und Herz.
Tinahones FJ, Gomez-Huelgas R, Garciaalegria J, et al. (2011). The effect of insulin detemir on fat distribution and weight parameters in overweight and obese subjects with type 2 diabetes. Diabetes.
Tofe Povedano S, Dungan KM, Forst T, et al. (2014). Efficacy and safety of once weekly dulaglutide versus once daily liraglutide in type 2 diabetes (AWARD6). Diabetologia.
Tofe Povedano S, Umpierrez G, Perez Manghi F, et al. (2013). Efficacy and safety of dulaglutide vs metformin in type 2 diabetes (AWARD-3). Diabetologia.
Tomasetti PE, Lubbers HT, Lanzer M, et al. (2014). Metformin and oral squamous cell carcinoma?. Head and Neck Oncology.
Toubro S, Cefalu WT, Xie J, et al. (2012). Canagliflozin, a sodium glucose co-transporter 2 inhibitor, reduces body weight mainly through loss of fat mass in subjects with type 2 diabetes. Diabetologia.
Traina S, Guthrie R, Slee A. (2014). The impact of weight loss on weight-related quality of life and health satisfaction: results from a trial comparing canagliflozin with sitagliptin in triple therapy among people with type 2 diabetes. Postgrad Med.
Traina S, Slee A, Neslusan C. (2014). Impact of weight loss on weight-related quality of life (WRQL) and health satisfaction (HS): Evidence from a head-to-head study of canagliflozin (CANA) vs sitagliptin (SITA). Diabetologia.
Traina SB, Ho KF. (2013). Weight- and health-related quality of life (WRQoL and HRQoL) with canagliflozin (CANA) versus sitagliptin (SITA) in subjects with type 2 diabetes mellitus (T2DM) on background metformin. Value in Health.
Traina SB, Neslusan C, Slee A. (2014). The association of health-related quality of life (HRQOL) and achievement of disease management goals in the treatment of type 2 diabetes mellitus (T2DM). Value in Health.
Trautmann M, Giaconia J, Choi S. (2011). Impact of exenatide twice daily on body weight in different patient groups. Diabetic Medicine.
Trautmann ME, Malloy J, Han J. (2014). Sustained glycaemic control with exenatide once weekly versus insulin glargine: Associations with baseline factors and early treatment response. Diabetologia.
Tremblay AJ, Lamarche B, Deacon CF, et al. (2011). Effect of sitagliptin therapy on postprandial lipoprotein levels in patients with type 2 diabetes. Diabetes Obes Metab.
Tschope D, Bramlage P, Binz C, et al. (2011). Antidiabetic pharmacotherapy and anamnestic hypoglycemia in a large cohort of type 2 diabetic patients--an analysis of the DiaRegis registry. Cardiovasc Diabetol.
Tschope D, Bramlage P, Binz C, et al. (2012). DPP-4 inhibitors versus sulfonylureas on top of metformin in a real world setting-Results of 1 year follow-up of the prospective diaregis registry. Diabetes.
Tschope D, Bramlage P, Binz C, et al. (2014). Incidence, characteristics, and impact of hypoglycemia in type 2 diabetic patients with intensified glycaemic control in clinical practice-2-year prospective follow-up of the diaregis cohort study. Diabetes.
Tschope D, Bramlage P, Binz C, et al. (2012). Predictors of hypoglycemia in patients with type-2 diabetes-An analysis of the prospective diaregis registry. Diabetes.
Tseng CH. (2012). Diabetes, metformin use, and colon cancer: a population-based cohort study in Taiwan. Eur J Endocrinol.
Tseng CH. (2014). Metformin may reduce bladder cancer risk in Taiwanese patients with type 2 diabetes. Acta Diabetol.
Tseng CH. (2014). Metformin may reduce breast cancer risk in Taiwanese women with type 2 diabetes. Breast Cancer Res Treat.
Tseng CH. (2014). Metformin significantly reduces incident prostate cancer risk in Taiwanese men with type 2 diabetes mellitus. Eur J Cancer.
Tseng CH. (2012). Pioglitazone and bladder cancer: a population-based study of Taiwanese. Diabetes Care.
Tseng CH. (2014). Pioglitazone and thyroid cancer risk in taiwanese patients with type 2 diabetes. Journal of Diabetes.
Tseng CH. (2014). Pioglitazone does not affect the risk of kidney cancer in patients with type 2 diabetes. Metabolism.
Tseng CH. (2013). Pioglitazone does not affect the risk of ovarian cancer: analysis of a nationwide reimbursement database in Taiwan. Gynecol Oncol.
Tseng CH. (2015). Rosiglitazone may reduce non-melanoma skin cancer risk in Taiwanese. BMC Cancer.
Tseng CH. (2013). Rosiglitazone may reduce thyroid cancer risk in patients with type 2 diabetes. Ann Med.
Tsilidis KK, Capothanassi D, Allen N, et al. (2014). Metformin and cancer risk: A cohort study in the UK Clinical Practice Research Datalink analyzed like a randomized trial. Cancer Research.
Tsilidis KK, Capothanassi D, Allen NE, et al. (2014). Metformin Does Not Affect Cancer Risk: A Cohort Study in the U.K. Clinical Practice Research Datalink Analyzed Like an Intention-to-Treat Trial. Diabetes Care.
Tsuchiya M, Nishio Y, Maegawa H. (2012). Long-term effect of DPP4 inhibition on dyslipidemia and the size of LDL particles in patients with IGT or type 2 diabetes. Diabetes.
Tziomalos K, Bouziana S, Pavlidis A, et al. (2013). Prior treatment with dipeptidyl-peptidase IV inhibitors is associated with favorable outcome in patients with acute ischemic stroke. Diabetes.
Tzoulaki I, Molokhia M, Curcin V, et al. (2009). Risk of cardiovascular disease and all cause mortality among patients with type 2 diabetes prescribed oral antidiabetes drugs: retrospective cohort study using UK general practice research database. BMJ.
Udell JA, Scirica B, Cavender MA, et al. (2014). Baseline renal function and cardiovascular risk in patients treated with saxagliptin: Observations from the savor-TIMI 53 trial. Journal of the American College of Cardiology.
Uhl D. (2010). Type 2 diabetes: Vitamin B12 level drops with the use of metformin. Deutsche Apotheker Zeitung.
Uhlig-Laske B, Ring A, Graefe-Mody U, et al. (2009). Linagliptin, a potent and selective DPP-4 inhibitor, is safe and efficacious in patients with inadequately controlled type 2 diabetes despite metformin therapy. Diabetes.
Umetsu R, Nishibata Y, Abe J, et al. (2014). Yakugaku Zasshi.
Umpierrez G, Atkin S, Bain S, et al. (2014). Efficacy and safety of liraglutide versus placebo in subjects with type 2 diabetes and moderate renal impairment (LIRA-RENAL): A randomised trial. Diabetologia.
Umpierrez G, Blevins T, Rosenstock J, et al. (2009). Effect of LY2189265, a long-acting glucagon-like peptide 1 analog, on metabolic outcomes and GI events in obese patients with uncontrolled type 2 diabetes mellitus (T2DM): The EGO study. Canadian Journal of Diabetes.
Umpierrez G, Blevins T, Rosenstock J, et al. (2009). Titration effect of LY2189265 (GLP-1 Analog) once weekly on metabolic outcomes and gi events in uncontrolled type 2 diabetes Mellitus (T2DM): The ego study. Diabetes.
Umpierrez GE, Blevins T, Rosenstock J, et al. (2011). The effects of LY2189265, a long-acting glucagon-like peptide-1 analogue, in a randomized, placebo-controlled, double-blind study of overweight/obese patients with type 2 diabetes: The EGO study. Diabetes, Obesity and Metabolism.
Umpierrez GE, Manghi FP, Povedano ST, et al. (2013). Efficacy and safety of dulaglutide vs. Metformin in type 2 diabetes (AWARD-3). Diabetes.
Umpierrez GE, Zhang Q, Rosenstock J. (2009). One-year rate of hospitalization following initiation of insulin glargine or exenatide in patients with type 2 diabetes. Diabetes.
Upahyay RY, Cortes GA, Tun H, et al. (2012). Effect of diabetes mellitus treatment type in patients undergoing percutaneous coronary intervention. Circulation. ur Rahman I, Idrees M, Salman M, et al. (2012). A comparison of the effect of glitazones on serum sialic acid in patients with type 2 diabetes. Diab Vasc Dis Res.
Urquhart BS. (2010). Comparing incretin-based therapies. Evaluating GLP-1 agonists and DPP-4 inhibitors for type 2 diabetes mellitus. Adv NPs PAs.
Usiskin K, Kline I, Fung A, et al. (2014). Safety and tolerability of canagliflozin in patients with type 2 diabetes mellitus: pooled Analysis of Phase 3 Study Results. Postgrad Med.
Usiskin K, Leiter LA, Forst T, et al. (2014). Effect of canagliflozin (CANA) on liver function tests (LFTS) in patients with type 2 diabetes mellitus (T2DM). Diabetes.
Valensi P, De Pouvourville G, Benard N, et al. (2014). Duration of maintenance of dual therapy with metformin and sitagliptin in type 2 diabetes: The Odyssee observational study. Diabetologia.
Valentine WJ, Palmer AJ, Lammert M, et al. (2011). Evaluating the long-term cost-effectiveness of liraglutide versus exenatide BID in patients with type 2 diabetes who fail to improve with oral antidiabetic agents. Clin Ther.
Van Brunt K, Reaney M, Yu M, et al. (2013). Patient-reported outcomes with dulaglutide, exenatide, or placebo (AWARD-1). Diabetologia.
van Dieren S, Czernichow S, Chalmers J, et al. (2012). Weight changes and their predictors amongst 11 140 patients with type 2 diabetes in the ADVANCE trial. Diabetes Obes Metab.
Van Dieren S, Kengne AP, Chalmers J, et al. (2012). Weight changes and their predictors among 11,140 patients with type 2 diabetes in the advance trial. Circulation.
Varewijck AJ, Janssen JA, Vahatalo M, et al. (2012). Addition of insulin glargine or NPH insulin to metformin monotherapy in poorly controlled type 2 diabetic patients decreases IGF-I bioactivity similarly. Diabetologia.
Varewijck AJ, Janssen JAMJL, Vahatalo M, et al. (2011). IGF-I bioactivity decreases during insulin therapy in type 2 diabetic patients: Comparison of high doses of insulin glargine and nph insulin in the lanmet study. Endocrine Reviews.
Vel S, Frid A, Hermansen K, et al. (2009). Evaluation of patient-reported outcomes in subjects with Type 2 diabetes treated with the once-daily human GLP-1 analogue liraglutide or glimepiride, both as addon to metformin. Diabetic Medicine.
Venskutonyte L, Brismar K, Ryden-Bergsten T, et al. (2013). Satisfaction with glucose-lowering treatment and well-being in patients with type 2 diabetes and myocardial infarction: A DIGAMI2 QoL sub-study. Diabetes and Vascular Disease Research.
Vichayanrat A, Matawaran BJ, Wibudi A, et al. (2013). Assessment of baseline characteristics, glycemic control and oral antidiabetic treatment in Asian patients with diabetes: The Registry for Assessing OAD Usage in Diabetes Management (REASON) Asia study. J Diabetes.
Vilar L, Canadas V, Arruda MJ, et al. (2010). Comparison of metformin, gliclazide MR and rosiglitazone in monotherapy and in combination for type 2 diabetes. Arq Bras Endocrinol Metabol.
Viljoen A, Meek CL, Gadsby R, et al. (2013). Efficacy and safety of DPP-IV inhibitors for the treatment of older people with Type 2 diabetes: An observational study. Diabetic Medicine.
Viljoen A, Meek CL, Gadsby R, et al. (2013). The tolerability and safety of DPP-4 inhibitors for the treatment of older people with type 2 diabetes mellitus: An observational study. British Journal of Diabetes and Vascular Disease.
Villena JE, Yoshiyama CA, Sanchez JE, et al. (2011). Prevalence of diabetic retinopathy in Peruvian patients with type 2 diabetes: results of a hospital-based retinal telescreening program. Rev Panam Salud Publica.
Viney T, Blackmore M, Shaww N, et al. (2009). Positive experiences of starting exenatide inpatients with Type 2 diabetes in a busy diabetic clinic. Diabetic Medicine.
Vinik AI, Cincotta AH, Scranton RE, et al. (2012). Effect of bromocriptine-QR on glycemic control in subjects with uncontrolled hyperglycemia on one or two oral anti-diabetes agents. Endocr Pract.
Virdi NS, Raja P, Daskiran M, et al. (2011). Association of SMBG with medication adherence and glycemic control. Diabetes.
Von Eynatten M, Gong Y, Emser A, et al. (2012). Safety and Efficacy of Linagliptin in Type 2 Diabetes (T2D) Patients with Common Renal and Cardiovascular Risk Factors. Endocr Rev.
Vora J, Malloy J, Zhou M, et al. (2014). Daily blood glucose variability with exenatide once weekly versus basal insulin in 3 randomised controlled trials. Diabetologia.
Wahlqvist ML, Lee MS, Chuang SY, et al. (2012). Increased risk of affective disorders in type 2 diabetes is minimized by sulfonylurea and metformin combination: a population-based cohort study. BMC Med.
Wahlqvist ML, Lee MS, Hsu CC, et al. (2012). Metformin-inclusive sulfonylurea therapy reduces the risk of Parkinson's disease occurring with Type 2 diabetes in a Taiwanese population cohort. Parkinsonism Relat Disord.
Wainstein J, Katz L, Engel SS, et al. (2012). Initial therapy with the fixed-dose combination of sitagliptin and metformin results in greater improvement in glycaemic control compared with pioglitazone monotherapy in patients with type 2 diabetes. Diabetes Obes Metab.
Walton C, Ryder REJ, Cull ML, et al. (2011). Factors associated with HbA1c and weight changes at 6 months in the Association of British Clinical Diabetologists (ABCD) nationwide exenatide and liraglutide audit. Diabetologia.
Walton C, Ryder REJ, Cull ML, et al. (2012). Factors associated with HbA1c and weight changes at 6 months in the Association of British Clinical Diabetologists (ABCD) nationwide exenatide and liraglutide audit. Practical Diabetes.
Wang CC, Chen WL, Kao TW, et al. (2011). Incidence of cardiovascular events in which 2 thiazolidinediones are used as add-on treatments for type 2 diabetes mellitus in a Taiwanese population. Clin Ther.
Wang MM, Lin S, Chen YM, et al. (2015). Saxagliptin is similar in glycaemic variability more effective in metabolic control than acarbose in aged type 2 diabetes inadequately controlled with metformin. Diabetes Res Clin Pract.
Wang W, Yang J, Yang G, et al. (2013). Efficacy and safety of linagliptin in Asian patients with type 2 diabetes mellitus inadequately controlled on metformin: A 24-week, randomized, phase III clinical trial. Diabetes.
Wangnoo SK, Mithal A, Kumar S, et al. (2012). Safety and efficacy of liraglutide in type 2 diabetes: Post marketing surveillance data from India. Diabetologia.
Ways K, Nyirjesy P, Sobel JD, et al. (2013). Genital mycotic infections with canagliflozin in subjects with type 2 diabetes mellitus. Diabetologia.
Weber MA, List J, Mansfield TA, et al. (2014). Combined hba1c and systolic blood pressure reduction with dapagliflozin in patients with both inadequately controlled type 2 diabetes mellitus and hypertension. Circulation.
Weber MA, Mansfield TA, Alessi F, et al. (2013). Effects of dapagliflozin on blood pressure in diabetic patients with hypertension inadequately controlled by a renin-angiotensin system blocker. Circulation.
Weber MA, Mansfield TA, Iqbal N, et al. (2014). Dapagliflozin lowers HbA1c, systolic blood pressure and serum uric acid in patients with type 2 diabetes and hypertension, regardless of class of concomitant antihypertensive therapy. Circulation.
Weber MA, Mansfield TA, T'Joen C, et al. (2013). Dapagliflozin for reduction of blood pressure in diabetic patients inadequately controlled with combination antihypertensive regimen. Circulation.
Wei J, Tang Q, Liu L, et al. (2013). Combination of peroxisome proliferator-activated receptor alpha/gamma agonists may benefit type 2 diabetes patients with coronary artery disease through inhibition of inflammatory cytokine secretion. Exp Ther Med.
Wei L, MacDonald TM, Mackenzie IS. (2013). Pioglitazone and bladder cancer: a propensity score matched cohort study. Br J Clin Pharmacol.
Weinstock RS, Umpierrez GE, Guerci B, et al. (2013). Safety and efficacy of dulaglutide vs. sitagliptin after 104 weeks in type 2 diabetes (AWARD-5). Diabetes.
Weir DL, McAlister FA, Senthilselvan A, et al. (2014). Sitagliptin Use in Patients With Diabetes and Heart Failure: A Population-Based Retrospective Cohort Study. JACC Heart Fail.
Weir DL, McAlister FA, Senthilselvan A, et al. (2013). The comparative safety and effectiveness of sitagliptin in patients with type 2 diabetes and heart failure. Diabetologia.
Weir DL, McAlister FA, Senthilselvan S, et al. (2013). The comparative safety and effectiveness of sitagliptin in patients with type 2 diabetes and heart failure. Pharmacoepidemiology and Drug Safety.
Weir DL, Senthilselva A, Dyck JR, et al. (2013). Comparative safety and effectiveness of sitagliptin in patients with type 2 diabetes and heart failure. Diabetes.
Weir M, Januszewicz A, Gilbert R, et al. (2013). Effects of canagliflozin on blood pressure and adverse events related to osmotic diuresis and reduced intravascular volume in subjects with type 2 diabetes mellitus. Diabetologia.
Weir MR, Januszewicz A, Gilbert R, et al. (2013). Lower blood pressure (BP) with canagliflozin (CANA) in subjects with type 2 diabetes mellitus (T2DM). Diabetes.
Weir MR, Kline I, Xie J, et al. (2014). Effect of canagliflozin on serum electrolytes in patients with type 2 diabetes in relation to estimated glomerular filtration rate (eGFR). Curr Med Res Opin.
Weissman PN, Carr MC, Ye J, et al. (2014). HARMONY 4: randomised clinical trial comparing once-weekly albiglutide and insulin glargine in patients with type 2 diabetes inadequately controlled with metformin with or without sulfonylurea. Diabetologia.
Weissman PN, Stewart MW, Cirkel DT, et al. (2014). Harmony 4: 3 year efficacy of albiglutide (ALBI) vs insulin glargine (GLAR) in patients with type 2 diabetes mellitus. Diabetologia.
Wendel CS, Fotieo GG, Shah JH, et al. (2014). Incidence of non-severe hypoglycaemia and intensity of treatment among veterans with Type 2 diabetes in the USA: a prospective observational study. Diabet Med.
Wenten M, Gaebler JA, Hussein M, et al. (2012). Relative risk of acute pancreatitis in initiators of exenatide twice daily compared with other anti-diabetic medication: a follow-up study. Diabet Med.
Wenying Y, Chen L, Ji Q, et al. (2010). Efficacy and safety of liraglutide compared with glimepiride, both combined with metformin, in an Asian population. Diabetologia.
Wertz DA, Chang CL, Sarawate CA, et al. (2010). Risk of cardiovascular events and all-cause mortality in patients treated with thiazolidinediones in a managed-care population. Circulation: Cardiovascular Quality and Outcomes.
White JR, Bastien A, Parikh S, et al. (2011). Dapagliflozin monotherapy and combination therapy reduces hyperglycemia in patients with type 2 diabetes. Pharmacotherapy.
White WB, Cannon CP, Heller SR, et al. (2013). Alogliptin after acute coronary syndrome in patients with type 2 diabetes. N Engl J Med.
White WB, Kupfer S, Nissen S, et al. (2014). Cardiovascular mortality in patients with type 2 diabetes and recent acute coronary syndromes from the examine trial. Journal of the American College of Cardiology.
Wilding J, Blonde L, Chiasson JL, et al. (2013). Canagliflozin lowers HbA1c and blood pressure through weight lossindependent and weight loss-associated mechanisms. Diabetologia.
Wilding JP, Blonde L, Leiter LA, et al. (2014). Efficacy and safety of canagliflozin by baseline HbA and known duration of type 2 diabetes mellitus. J Diabetes Complications.
Wilding JP, Charpentier G, Hollander P, et al. (2013). Efficacy and safety of canagliflozin in patients with type 2 diabetes mellitus inadequately controlled with metformin and sulphonylurea: a randomised trial. Int J Clin Pract.
Wilding JP, Woo V, Soler NG, et al. (2012). Long-term efficacy of dapagliflozin in patients with type 2 diabetes mellitus receiving high doses of insulin: a randomized trial. Ann Intern Med.
Wilding JPH, Blonde L, Leiter LA, et al. (2015). Efficacy and safety of canagliflozin by baseline HbA1c and known duration of type 2 diabetes mellitus. Journal of Diabetes and its Complications.
Wilding JPH, Woo V, Pahor A, et al. (2010). Effect of dapagliflozin, a novel insulin-independent treatment, over 48 weeks in patients with type 2 diabetes poorly controlled with insulin. Diabetologia.
Wile DJ, Toth C. (2010). Association of metformin, elevated homocysteine, and methylmalonic acid levels and clinically worsened diabetic peripheral neuropathy. Diabetes Care.
Wilke T, Mueller S, Groth A, et al. (2015). Treatment-dependent and treatment-independent risk factors associated with the risk of diabetes-related events: A retrospective analysis based on 229,042 patients with type 2 diabetes mellitus. Cardiovascular Diabetology.
Willemen MJ, Mantel-Teeuwisse AK, Straus SM, et al. (2011). Use of dipeptidyl peptidase-4 inhibitors and the reporting of infections: a disproportionality analysis in the World Health Organization VigiBase. Diabetes Care.
Williams-Herman D, Engel SS, Round E, et al. (2010). Safety and tolerability of sitagliptin in clinical studies: a pooled analysis of data from 10,246 patients with type 2 diabetes. BMC Endocr Disord.
Williams-Herman D, Seck T, Golm G, et al. (2009). Improvement in glycaemic control and ss-cell function over 2 years with sitagliptin as monotherapy or add-on therapy to metformin in patients with type 2 diabetes. Canadian Journal of Diabetes.
Williams-Herman D, Xu L, Teng R, et al. (2012). Effect of initial combination therapy with sitagliptin and metformin on beta-cell function in patients with type 2 diabetes. Diabetes Obes Metab.
Williams-Herman DE, Seck TL, Golm G, et al. (2009). Long-term efficacy with sitagliptin as monotherapy or add-on therapy to metformin: Improvement in glycemic control over 2 years in patients with type 2 diabetes. Diabetes.
Wilson C, Fleck P. (2012). Effect of alogliptin in combination with pioglitazone on glycaemic control by baseline HbA1c. Diabetologia.
Wintle M, Bruce S, MacConell L, et al. (2009). Safety and tolerability of exenatide BID in patients with type 2 diabetes: Integrated analysis of 3854 patients from 11 comparator controlled clinical trials. Diabetologia.
Woerle HJ, Kadowaki T, Haneda M, et al. (2013). Safety and efficacy of empagliflozin monotherapy in a 52-week study in Japanese patients with type 2 diabetes mellitus. Diabetologia.
Woerle HJ, Neubacher D, Patel S, et al. (2013). Safety and efficacy of linagliptin and basal insulin combination therapy in elderly patients (age (greater-than or equal to)70 years) with type 2 diabetes (T2D). J Am Geriatr Soc.
Wolffenbuttel BHR, Klaff LJ, Bhushan R, et al. (2009). Initiating insulin therapy in elderly patients with Type 2 diabetes: Efficacy and safety of lispro mix 25 vs. basal insulin combined with oral glucose-lowering agents. Diabetic Medicine.
Woo V, Davies M, De Zeeuw D, et al. (2013). Canagliflozin is effective and generally well tolerated in subjects with type 2 diabetes mellitus and Stage 3 chronic kidney disease. Diabetologia.
Woo V, Langkilde AM, Sugg J, et al. (2011). Dapagliflozin, a novel antihyperglycemic agent that promotes urinary glucose excretion, reduces systolic blood pressure in patients with type 2 diabetes mellitus. Circulation.
Woo V, Leiter LA, Cefalu WT, et al. (2013). Blood pressure reduction with dapagliflozin in patients with type 2 diabetes and cardiovascular disease. Circulation.
Woo V, Wysham C, Mathieu C, et al. (2013). Canagliflozin (CANA) added on to dipeptidyl peptidase-4 inhibitors (DPP-4I) or glucagon-like peptide-1 (GLP-1) agonists with or without other antihyperglycemic agents (AHAS) in type 2 diabetes mellitus (T2DM). Canadian Journal of Diabetes.
Wright A, Kempegowda P, Abernethy G, et al. (2014). GLP-1 analogues treatment was not associated with additional weight loss over intensive lifestyle intervention in severely obese patients with type 2 diabetes. Diabetes.
Wright JL, Stanford JL. (2009). Metformin use and prostate cancer in Caucasian men: results from a population-based case-control study. Cancer Causes Control.
Wu JD, Xu XH, Zhu J, et al. (2011). Effect of exenatide on inflammatory and oxidative stress markers in patients with type 2 diabetes mellitus. Diabetes Technol Ther.
Wu LC, Chang CH, Chunag LM, et al. (2011). Anti-diabetic therapies and cancer risk among type 2 diabetes patients in Taiwan-a nationwide nested case-control study. Pharmacoepidemiology and Drug Safety.
Wu S, Li X, Zhang H. (2014). Effects of metformin on endothelial function in type 2 diabetes. Exp Ther Med.
Wu T, Ma J, Bound MJ, et al. (2014). Effects of sitagliptin on glycemia, incretin hormones, and antropyloroduodenal motility in response to intraduodenal glucose infusion in healthy lean and obese humans, and patients with type 2 diabetes treated with or without metformin. Diabetes.
Wu YT, Gau CS. (2009). The cardiovascular risk of sulfonylureas on newly diagnosed type ii diabetes mellitus patients. Drug Safety.
Wygant GD, Chalamandaris AG, Iloeje UH, et al. (2012). Dapagliflozin is more effective than glipizide in achieving the composite outcome of glycemic control, weight reduction, and lack of hypoglycemia. Diabetes.
Wysham C, Bergenstal R, Yan P, et al. (2009). DURATION-2: Exenatide once weekly demonstrated superior glycaemic control and weight reduction compared to sitagliptin or pioglitazone after 26 weeks of treatment. Diabetologia.
Wysham C, Blevins T, Arakaki R, et al. (2013). Efficacy and safety of dulaglutide versus placebo and exenatide in type 2 diabetes (award-1). Diabetes.
Wysham CH, Woo VC, Mathieu C, et al. (2013). Canagliflozin (CANA) added on to dipeptidyl peptidase-4 inhibitors (DPP-4i) or glucagon-like peptide-1 (GLP-1) agonists with or without other antihyperglycemic agents (AHAs) in type 2 diabetes mellitus (T2DM). Diabetes.
Xing Y, Ye S, Hu Y, et al. (2012). Podocyte as a potential target of inflammation: role of pioglitazone hydrochloride in patients with type 2 diabetes. Endocr Pract.
Xu W, Bi Y, Sun Z, et al. (2014). Comparison of glycemic control and beta-cell function in newly diagnosed type 2 diabetes patients treated with exenatide, insulin or pioglitazone: A multicentre, randomized, parallel-group trial (confidence). Diabetes.
Yale JF, Bakris G, Cariou B, et al. (2013). Efficacy and safety of canagliflozin (CANA) in subjects with type 2 diabetes mellitus (T2DM) and chronic kidney disease (CKD) over 52 weeks. Diabetes.
Yale JF, Bakris G, Cariou B, et al. (2013). Efficacy and safety of canagliflozin in subjects with type 2 diabetes and chronic kidney disease. Diabetes Obes Metab.
Yale JF, Bakris G, Cariou B, et al. (2014). Efficacy and safety of canagliflozin over 52 weeks in patients with type 2 diabetes mellitus and chronic kidney disease. Diabetes Obes Metab.
Yale JF, Bakris G, Wajs E, et al. (2012). Canagliflozin, a sodium glucose co-transporter 2 inhibitor, improves glycaemic control and is well tolerated in type 2 diabetes subjects with moderate renal impairment. Diabetologia.
Yale JF, Damci T, Kaiser M, et al. (2013). Initiation of once daily insulin detemir is not associated with weight gain in patients with type 2 diabetes mellitus: Results from an observational study. Diabetology and Metabolic Syndrome.
Yamasaki Y, Katakami N, Furukado S, et al. (2010). Long-term effects of pioglitazone on carotid atherosclerosis in Japanese patients with type 2 diabetes without a recent history of macrovascular morbidity. J Atheroscler Thromb.
Yang F, Reusch JEB, Rosenstock J, et al. (2009). The long-acting GLP-1-receptor agonist albiglutide improves glycaemic control in type 2 diabetes: Time-course analysis. Diabetologia.
Yang F, Rosenstock J, Reusch J, et al. (2009). The long-acting GLP-1-receptor agonist albiglutide for the treatment of type 2 diabetes: A time course analysis of gastrointestinal adverse events in patients receiving concomitant background metformin. Canadian Journal of Diabetes.
Yang H, Marynchenko M, Bron M, et al. (2011). Comparison of hypoglycaemia risk and cost between oral antidiabetic monotherapies in elderly patients with type 2 diabetes mellitus in a U.S. population. Diabetologia.
Yang J, Vallarino C, Bron M, et al. (2014). A comparison of all-cause mortality with pioglitazone and insulin in type 2 diabetes: an expanded analysis from a retrospective cohort study. Curr Med Res Opin.
Yang L, Lu JC, Ding CH, et al. (2013). Glycemic control in 374 outpatients with type 2 diabetes mellitus. Academic Journal of Second Military Medical University.
Yang L, Song MQ, Zhang QL, et al. (2014). Effect of piglitazone and metformin on retinol-binding protein-4 and adiponectin in patients with type 2 diabetes mellitus complicated with non-alcohol fatty acid liver diseases. Zhongguo Yi Xue Ke Xue Yuan Xue Bao.
Yang W, Guan Y, Shentu Y, et al. (2011). Sitagliptin added to ongoing metformin therapy in chinese patients with type 2 diabetes significantly enhances glycemic control. Diabetes.
Yang X, So WY, Ma RC, et al. (2011). Low HDL cholesterol, metformin use, and cancer risk in type 2 diabetes: the Hong Kong Diabetes Registry. Diabetes Care.
Yasunari E, Takeno K, Funayama H, et al. (2011). Efficacy of pioglitazone on glycemic control and carotid intima-media thickness in type 2 diabetes patients with inadequate insulin therapy. J Diabetes Investig.
Ye S, Zheng M, Hu Y, et al. (2010). Hydrochloride pioglitazone decreases urinary monocyte chemoattractant protein-1 excretion in type 2 diabetics. Diabetes Res Clin Pract.
Yee MS, Pavitt DV, Dhanjil S, et al. (2009). The effects of rosiglitazone on carotid ultrasound indices and glycaemia in subjects with a high cardiovascular risk and Type 2 diabetes. Diabetic Medicine.
Yeh HT, Hsieh CF, Tsai YW, et al. (2012). Effects of thiazolidinediones on cardiovascular events in patients with type 2 diabetes mellitus after drug-eluting stent implantation: a retrospective cohort study using the national health insurance database in Taiwan. Clin Ther.
Yokoe H, Yuasa F, Sugiura T, et al. (2009). The effect of pioglitazone on arterial baroreflex sensitivity and sympathetic nerve activity in patients with type 2 diabetes mellitus after myocardial infarction. European Heart Journal.
Yokoe H, Yuasa F, Yo M, et al. (2009). The effect of pioglitazone on sympathetic and baroreflex function in type two diabetes mellitus after myocardial infarction. Journal of the American College of Cardiology.
Yokoe H, Yuasa F, Yuyama R, et al. (2012). Effect of pioglitazone on arterial baroreflex sensitivity and sympathetic nerve activity in patients with acute myocardial infarction and type 2 diabetes mellitus. J Cardiovasc Pharmacol.
Yokoi H, Nakamura M, Muramatsu T, et al. (2013). Impact of pioglitazone on cardiovascular events in patients with type-2 diabetes mellitus after drug-eluting stent implantation. Journal of the American College of Cardiology.
Yoon K, Shockey G, Teng R, et al. (2009). Initial combination therapy with sitagliptin and pioglitazone improves glycaemic control and measures of beta cell function compared with pioglitazone alone in patients with type 2 diabetes. Diabetologia.
Yoshida M, Yamamoto N, Saeki A, et al. (2012). Exenatide therapy reduced intina-media thickness of carotid artery in patients with type 2 diabetes. Diabetologia.
Yoshii H, Onuma T, Yamazaki T, et al. (2014). Effects of Pioglitazone on Macrovascular Events in Patients with Type 2 Diabetes Mellitus at High Risk of Stroke: The PROFIT-J Study. J Atheroscler Thromb.
You SH, Kim BS, Hong SJ, et al. (2010). The effects of pioglitazone in reducing atherosclerosis progression and neointima volume in type 2 diabetic patients: prospective randomized study with volumetric intravascular ultrasonography analysis. Korean Circ J.
Young MA, Wald JA, Matthews JE, et al. (2014). Effect of renal impairment on the pharmacokinetics, efficacy, and safety of albiglutide. Postgrad Med.
Yu OHY, Filion KB, Azoulay L, et al. (2015). Incretin-based drugs and the risk of congestive heart failure. Diabetes Care.
Yu S, Yang J, Bron M, et al. (2012). An assessment of all-cause mortality for pioglitazone compared with insulin in patients with type 2 diabetes mellitus. Diabetologia.
Zannad F, Cannon C, Cushman W, et al. (2014). Alogliptin in patients with type 2 diabetes after acute coronary syndromes: Heart failure outcomes and cardiovascular safety in heart failure patients. Journal of the American College of Cardiology.
Zavattaro M, Caputo M, Sama MT, et al. (2015). One-year treatment with liraglutide improved renal function in patients with type 2 diabetes: a pilot prospective study. Endocrine.
Zeng Z, Choi DS, Mohan V, et al. (2015). Efficacy and safety of linagliptin as monotherapy or add-on treatment in Asian patients with suboptimal glycemic control: a pooled analysis. Curr Med Res Opin.
Zeng Z, Choi DS, Mohan V, et al. (2012). Linagliptin is efficacious and well tolerated in asian patients with inadequately controlled type 2 diabetes. Diabetes.
Zeng Z, Yang JK, Tong N, et al. (2013). Efficacy and safety of linagliptin added to metformin and sulphonylurea in Chinese patients with type 2 diabetes: A sub-analysis of data from a randomised clinical trial. Curr Med Res Opin.
Zhang DD, Liu F, Jia W. (2013). Metformin reduces serum CA199 levels in type 2 diabetic patients with time-effect and gender difference. Diabetologia.
Zhang L, Feng Y, List J, et al. (2010). Dapagliflozin treatment in patients with different stages of type 2 diabetes mellitus: effects on glycaemic control and body weight. Diabetes Obes Metab.
Zhang SL, Chen ZC, Yan L, et al. (2011). Determinants for inadequate glycaemic control in Chinese patients with mild-to-moderate type 2 diabetes on oral antidiabetic drugs alone. Chinese Medical Journal.
Zhang X, Mettler T, Harmsen WS, et al. (2013). Continuation of metformin use after a diagnosis of cirrhosis significantly improved survival of patients with type II diabetes (DM). Hepatology.
Zhang XQ, Zhu S, Chen LC, et al. (2013). Risk of cardiovascular diaseases associated with antidiabetic monotherapy intervals in type-2 diabetic patients-a preliminiary study on taiwan pay-for-performance diabetes registry. Value in Health.
Zhang XY, Du JL, Jia YJ, et al. (2009). Zhonghua Yi Xue Za Zhi.
Zhao M, Shao JQ, Du H. (2010). Effects of three antidiabetics on insulin and leptin in Chinese type 2 diabetes. Diabetes and Metabolic Syndrome: Clinical Research and Reviews.
Zhao Z, Spanheimer R, Perez A. (2009). Effect of pioglitazone and metformin fixed-dose combination on glycaemic control in untreated patients. Diabetologia.
Zheng JY, Tang YH, Zou JJ. (2009). Extended-release metformin in treatment of patients with type 2 diabetes: Efficacy and safety. Academic Journal of Second Military Medical University.
Zilov A, Naggar NE, Shah S, et al. (2013). Insulin detemir in the management of type 2 diabetes in non-Western countries: Safety and effectiveness data from the A1chieve observational study. Diabetes Research and Clinical Practice.
Zinman B, Gough S, Pratley R, et al. (2011). Achieving glycaemic control and weight loss with incretin-based therapies: A comparison of liraglutide, exenatide, and sitagliptin. Diabetologia.
Zinman B, Haffner SM, Herman WH, et al. (2010). Effect of rosiglitazone, metformin, and glyburide on bone biomarkers in patients with type 2 diabetes. J Clin Endocrinol Metab.
Zinman B, Harris SB, Neuman J, et al. (2010). Low-dose combination therapy with rosiglitazone and metformin to prevent type 2 diabetes mellitus (CANOE Trial): A double-blind randomized controlled study. Obstetrical and Gynecological Survey.
Zinman B, Inzucchi SE, Lachin J, et al. (2013). Design of the empagliflozin cardiovascular (CV) outcome event trial in type 2 diabetes (T2D). Canadian Journal of Diabetes.
Zinman B, Inzucchi SE, Lachin JM, et al. (2014). Rationale, design, and baseline characteristics of a randomized, placebo-controlled cardiovascular outcome trial of empagliflozin (EMPA-REG OUTCOME). Cardiovasc Diabetol.
Zinman B, Schmidt WE, Moses A, et al. (2012). Achieving a clinically relevant composite outcome of an HbA1c of <7% without weight gain or hypoglycaemia in type 2 diabetes: a meta-analysis of the liraglutide clinical trial programme. Diabetes Obes Metab.
Ziyadeh N, McAfee AT, Koro C, et al. (2009). The thiazolidinediones rosiglitazone and pioglitazone and the risk of coronary heart disease: a retrospective cohort study using a US health insurance database. Clin Ther.