# Appendix B Forms

Title Review

Title Review

Abstract Review

Abstract Review

Article Review

Article Review

Study Design

Study Design

Intervention Form

Intervention Form

Population Characteristics

Population Characteristics

Outcomes Form, KQ1–KQ3

Outcomes Form KQ1-KQ3

Study Quality Form for Randomized Controlled Trials

Study Quality Form for Nonrandomized Study

Study Quality Form for Nonrandomized Study