# Appendix A Detailed Electronic Database Search Strategies

## PubMed Strategy

Search | String
#1 | (“diabetes mellitus, type 2”[mh] or (diabet*[tiab] and (“non-insulin dependent”[tiab] or type-2[tiab] or “type II”[tiab] or “type 2”[tiab]))) AND (“metformin”[mh] or “thiazolidinediones”[mh] or “glipizide”[mh] or “glyburide”[mh] or “Dipeptidyl-Peptidase IV Inhibitors”[mh] or “Glucagon-Like Peptide 1”[mh] or biguanide*[tiab] or metformin[tiab] or thiazolidinedione*[tiab] or pioglitazone[tiab] or rosiglitazone[tiab] or sulfonylurea*[tiab] or sulphonylurea*[tiab] or glipizide[tiab] or glyburide[tiab] or glimepiride[tiab] or glibenclamide[tiab] or “insulin secretagogues”[tiab] or sitagliptin*[tiab] or saxagliptin*[tiab] or dpp-4[tiab] or dpp-iv[tiab] or liraglutide[tiab] or exenatide[tiab]) NOT (animal[mh] NOT human[mh]) NOT (letter[pt] or comment[pt] or editorial[pt]) AND ((“2009/04/01”[edat] : “2014/07/11”[edat]))
#2 | (“diabetes mellitus, type 2”[mh] or (diabet*[tiab] and (“non-insulin dependent”[tiab] or type-2[tiab] or “type II”[tiab] or “type 2”[tiab]))) AND (linagliptin*[tiab] or alogliptin*[tiab] or albiglutide*[tiab] or dulaglutide*[tiab] or “sodium-glucose co-transporter 2 inhibitors”[tiab] or “sodium-glucose co-transporter 2 inhibitor” [tiab] or “SGLT-2” [tiab] or “canagliflozin”[tiab] or “dapagliflozin”[tiab]) NOT (animal[mh] NOT human[mh]) NOT (letter[pt] or comment[pt] or editorial[pt])
#3 | (“diabetes mellitus, type 2”[mh] or (diabet*[tiab] and (“non-insulin dependent”[tiab] or type-2[tiab] or “type II”[tiab] or “type 2”[tiab]))) AND (empagliflozin*[tiab]) NOT (animal[mh] NOT human[mh]) NOT (letter[pt] or comment[pt] or editorial[pt])

## EMBASE Strategy

Search | String
#1 | (‘non insulin dependent diabetes mellitus’/exp OR ‘non insulin dependent diabetes mellitus’ or (diabet*:ti,ab and (‘non-insulin dependent’:ti,ab or type-2:ti,ab or ‘type II’:ti,ab or ‘type 2’:ti,ab))) AND (‘thiazolidinedione’/exp or ‘rosiglitazone’/exp or ‘pioglitazone’/exp or ‘glipizide’/exp or ‘glyburide’/exp or ‘glimepiride’/exp or ‘metformin’/exp or ‘sitagliptin’/exp or thiazolidinedione*:ti,ab or pioglitazone:ti,ab or rosiglitazone:ti,ab or sulfonylurea*:ti,ab or sulphonylurea*:ti,ab or glipizide:ti,ab or glyburide:ti,ab or glimepiride:ti,ab or glibenclamide:ti,ab or biguanide*:ti,ab or metformin:ti,ab or ‘insulin secretagogues’:ti,ab or ‘Dipeptidyl-Peptidase IV Inhibitor’/de or saxagliptin/exp or saxagliptin*:ti,ab or sitagliptin/exp or sitagliptin*:ti,ab or dpp-4:ti,ab or dpp-iv:ti,ab or exenatide/exp or exenatide:ti,ab or liraglutide/exp or liraglutide:ti,ab) NOT ([animals]/lim NOT [humans]/lim) NOT (letter:it or comment:it or editorial:it) AND [2009-2014]/py
#2 | (‘non insulin dependent diabetes mellitus’/exp OR ‘non insulin dependent diabetes mellitus’ or (diabet*:ti,ab and (‘non-insulin dependent’:ti,ab or type-2:ti,ab or ‘type II’:ti,ab or ‘type 2’:ti,ab))) AND (linagliptin/exp or linagliptin*:ti,ab or alogliptin/exp or alogliptin*:ti,ab or albiglutide/exp or albiglutide*:ti,ab or dulaglutide/exp or dulaglutide*:ti,ab or ‘sodium glucose cotransporter 2 inhibitor’/de or ‘sodium-glucose co-transporter 2 inhibitors’:ti,ab or ‘sodium-glucose co-transporter 2 inhibitor’:ti,ab or ‘sodium glucose cotransporter 2 inhibitors’:ti,ab or ‘sodium glucose cotransporter 2 inhibitor’:ti,ab or ‘SGLT-2”:ti,ab or canagliflozin/exp or canagliflozin:ti,ab or dapagliflozin/exp or dapagliflozin:ti,ab) NOT ([animals]/lim NOT [humans]/lim) NOT (letter:it or comment:it or editorial:it)
#3 | (‘non insulin dependent diabetes mellitus’/exp OR ‘non insulin dependent diabetes mellitus’ or (diabet*:ti,ab and (‘non-insulin dependent’:ti,ab or type-2:ti,ab or ‘type II’:ti,ab or ‘type 2’:ti,ab))) AND (empagliflozin/exp or empagliflozin*:ti,ab) NOT ([animals]/lim NOT [humans]/lim) NOT (letter:it or comment:it or editorial:it)

## Cochrane Strategy

Search | String
#1 | ((diabetes near type-2):ti,ab,kw or (diabet*:ti,ab,kw and (“non-insulin dependent”:ti,ab,kw or type-2:ti,ab,kw or “type II”:ti,ab,kw or “type 2”:ti,ab,kw))) AND (thiazolidinedione*:ti,ab,kw or pioglitazone:ti,ab,kw or rosiglitazone:ti,ab,kw or sulfonylurea*:ti,ab,kw or sulphonylurea*:ti,ab,kw or glipizide:ti,ab,kw or glyburide:ti,ab,kw or glimepiride:ti,ab,kw or glibenclamide:ti,ab,kw or biguanide*:ti,ab,kw or metformin:ti,ab,kw or “insulin secretagogues”:ti,ab,kw or “Dipeptidyl-Peptidase IV Inhibitors”:ti,ab,kw or saxagliptin*:ti,ab,kw or sitagliptin*:ti,ab,kw or liraglutide:ti,ab,kw or exenatide:ti,ab,kw) Publication Year from 2009 to 2014
#2 | ((diabetes near type-2):ti,ab,kw or (diabet*:ti,ab,kw and (“non-insulin dependent”:ti,ab,kw or type-2:ti,ab,kw or “type II”:ti,ab,kw or “type 2”:ti,ab,kw))) AND (linagliptin*:ti,ab,kw or alogliptin*:ti,ab,kw or albiglutide*:ti,ab,kw or dulaglutide*:ti,ab,kw or ‘sodium-glucose co-transporter 2 inhibitors’:ti,ab,kw or ‘sodium-glucose co-transporter 2 inhibitor’:ti,ab,kw or ‘sodium glucose cotransporter 2 inhibitors’:ti,ab,kw or ‘sodium glucose cotransporter 2 inhibitor’:ti,ab,kw or ‘SGLT-2’:ti,ab,kw or canagliflozin:ti,ab,kw or dapagliflozin:ti,ab,kw)
#3 | ((diabetes near type-2):ti,ab,kw or (diabet*:ti,ab,kw and (“non-insulin dependent”:ti,ab,kw or type-2:ti,ab,kw or “type II”:ti,ab,kw or “type 2”:ti,ab,kw))) AND (empagliflozin*:ti,ab,kw)