# Abbreviations

ADOPT: A Diabetes Outcome Progression Trial
AHRQ: Agency for Healthcare Research and Quality
BMI: body mass index
CARMELINA: Cardiovascular and Renal Microvascular Outcome Study with Linagliptin in Patients with Type 2 Diabetes Mellitus
CAROLINA: Cardiovascular Outcome Study of Linagliptin Versus Glimepiride in Patients with Type 2 Diabetes
CER: comparative effectiveness reviews
CI: confidence interval
CVD: cardiovascular disease
DPP-4 inhibitors: dipeptidyl-peptidase-4 inhibitors
EHC: Effective Health Care
EXAMINE: Examination of Cardiovascular Outcomes with Alogliptin versus Standard of Care;
FDA: Food and Drug Administration
GI: gastrointestinal
GLP-1 receptor agonists: glucagon-like peptide-1 receptor agonists
HbA1c: hemoglobin A1c
HR: hazard ratio
LEAD: Liraglutide Effect and Action in Diabetes
MeSH: medical subject headings
OR: odds ratio
PROactive: PROspective pioglitAzone Clinical Trial In macroVascular Events
RCT: randomized controlled trial
RECORD: Rosiglitazone Evaluated for Cardiac Outcomes and Regulation of Glycemia in Diabetes
RR: risk ratio
SAVOR-TIMI: Saxagliptin Assessment of Vascular Outcomes Recorded in Patients with Diabetes Mellitus Thrombolysis in Myocardial Infarction
SGLT-2 inhibitors: sodium glucose co-transporter 2 inhibitors
SOE: Strength of evidence
TECOS: Trial Evaluating Cardiovascular Outcomes with Sitagliptin
TEP: technical expert panel
UKPDS: United Kingdom Prospective Diabetes Study
UTI: urinary tract infection