# References

1 Lessa FC, Mu Y, Bamberg WM, et al. Burden of Clostridium difficile infection in the united states. New England Journal of Medicine. 2015;372(9):825-34. [pmid: 25714160].
2 Campbell RJ, Giljahn L, Machesky K, et al. Clostridium difficile infection in Ohio hospitals and nursing homes during 2006. Infect Control Hosp Epidemiol. Jun. 2009;30(6):526-33. [pmid: 19419272].
3 McFarland LV. Renewed interest in a difficult disease: Clostridium difficile infections--epidemiology and current treatment strategies. Curr. Jan. 2009;25(1):24-35. [pmid: 19114771].
4 Hoyert DL, Xu J. Deaths: preliminary data for 2011. Natl Vital Stat Rep. Oct. 10. 2012;61(6):1-51. [pmid: 24984457].
5 Severe Clostridium difficile-associated disease in populations previously at low risk--four states, 2005. Mmwr. Dec. 2. 2005;54(47):1201-5. [pmid: 16319813].
6 Hubert B, Loo VG, Bourgault AM, et al. A portrait of the geographic dissemination of the Clostridium difficile North American pulsed-field type 1 strain and the epidemiology of C. difficile-associated disease in Quebec. Clin Infect Dis. Jan. 15. 2007;44(2):238-44. [pmid: 17173224].
7 Karpa KD. Probiotics for Clostridium difficile diarrhea: putting it into perspective. The Annals of pharmacotherapy. Jul. 2007;41(7):1284-7. [pmid: 17595302].
8 Bartlett JG, Gerding DN. Clinical recognition and diagnosis of Clostridium difficile infection. Clin Infect Dis. Jan. 15. Suppl 1. 2008;46:S12-8. [pmid: 18177217].
9 Cohen J, Limbago B, Dumyati G, et al. Impact of changes in clostridium difficile testing practices on stool rejection policies and C. difficile positivity rates across multiple laboratories in the United States. J Clin Microbiol. 2014;52(2):632-4. [pmid: 24478500].
10 Surawicz CM, Brandt LJ, Binion DG, et al. Guidelines for diagnosis, treatment, and prevention of Clostridium difficile infections. The American journal of gastroenterology. 2013;108:478-98. [pmid: 23439232].
11 Pepin J. Vancomycin for the treatment of Clostridium difficile Infection: for whom is this expensive bullet really magic?. Clinical Infectious Diseases. May. 15. 2008;46(10):1493-8. [pmid: 18419481].
12 Butler M, Bliss D, Drekonja D, et al. Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection. Rockville, MD. Prepared by the Minnesota Evidence-based Practice Center for the Agency for Healthcare Research and Quality under Contract No. 290-02-0009. Comparative Effectiveness Review Number 31. AHRQ Publication No. 11(12)-EHC051-EF. December. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
13 Gerding DN, Muto CA, Owens RC Jr. Treatment of Clostridium difficile infection. Clinical Infectious Diseases. Jan. 15. Suppl 1. 2008;46:S32-42. [pmid: 18177219].
14 Halsey J. Current and future treatment modalities for Clostridium difficile-associated disease. Am J Health-Syst Pharm. Apr. 15. 2008;65(8):705-15. [pmid: 18387898].
15 Jodlowski TZ, Oehler R, Kam LW, et al. Emerging therapies in the treatment of Clostridium difficile-associated disease. Ann Pharmacother. Dec. 2006;40(12):2164-9. [pmid: 17119105].
16 Stepan C, Surawicz CM. Treatment strategies for C. difficile associated diarrhea. Acta Gastroenterol Latinoam. Sep. 2007;37(3):183-91. [pmid: 17955730].
17 Starr JM, Campbell A, Renshaw E, et al. Spatio-temporal stochastic modelling of Clostridium difficile. The Journal of hospital infection. Jan. 2009;71(1):49-56. [pmid: 19013677].
18 Abou Chakra C, Pepin J, Sirard S, et al. Risk Factors for recurrence, complications and mortality in Clostridium difficile infection: a systematic review. PLoS ONE. 2014;9(6):e98400. [pmid: 24897375].
19 Garey KW, Sethi S, Yadav Y, et al. Meta-analysis to assess risk factors for recurrent Clostridium difficile infection. Journal of Hospital Infection. Dec. 2008;70(4):298-304. [pmid: 18951661].
20 Dubberke ER, Gerding DN, Classen D, et al. Strategies to prevent clostridium difficile infections in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29:S81-92. [pmid: 18840091].
21 Gordin FM, Schultz ME, Huber RA, et al. Reduction in nosocomial transmission of drug-resistant bacteria after introduction of an alcohol-based handrub. Infect Control Hosp Epidemiol. Jul. 2005;26(7):650-3. [pmid: 16092747].
22 Roberts K, Smith CF, Snelling AM, et al. Aerial dissemination of Clostridium difficile spores. BMC Infectious Diseases. 2008;8:7. [pmid: 18218089].
23 Butler M, Bliss D, Drekonja D, et al. Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection--Nomination Summary Document. Agency for Healthcare Research and Quality. Available at: http://effectivehealthcare.ahrq.gov/ehc/assets/File/c-diff-infections-nomination-140925.pdf. Nov 4, 2014.
24 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. Oct. 2009;62(10):1006-12. [pmid: 19631508].
25 White C, Ip S, McPheeters M, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2009. www.effectivehealthcare.ahrq.gov/repFiles/methodsguide/systematicreviewsreplacedenovo.pdf.
26 Whiting P, Rutjes A, Westwood M, et al. QUADAS-2: A revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
27 Viswanathan M, Ansari M, Berkman N, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. AHRQ. 2012.
28 Trikalinos TA, Balion CM. Chapter 9: options for summarizing medical test performance in the absence of a “gold standard”. J Gen Intern Med. Jun. Suppl 1. 2012;27:S67-75. [pmid: 22648677].
29 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med. Jun. Suppl 1. 2012;27:S56-66. [pmid: 22648676].
30 Sackett D. The ratinoal clinical examination. A primer on the precision and accuracy of the clinical examination. JAMA. 1992;267(19):2638-44. [pmid: 1573753].
31 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. [pmid: 21477993].
32 Berkman ND, Lohr K, Ansari M, et al. Grading the strength of a body of evidence when assessing health care interventions for the effective health care program of the Agency for Healthcare Research and Quality: An update. 290-2007-10056-I PbtR-UE-bPCuCN, trans. Methods Guide for Comparative Effectiveness Reviews. Vol AHRQ Publication 13(14)-EHC 130-EF. November ed. Rockville, MD. Agency for Healthcare Research and Quality. 2013.
33 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
34 Filice G, Drekonja D, Greer N, et al. Antimicrobial stewardship programs in inpatient settings: a systematic review. In: #09-009 V-Ep, ed. 2013.
35 Fowler S, Webber A, Cooper B, et al. Successful use of feedback to improve antibiotic prescribing and reduce Clostridium difficile infection: a controlled interrupted time series. J Antimicrob Chemother. May. 2007;59(5):990-5. [pmid: 17387117].
36 Noto MJ, Domenico HJ, Byrne DW, et al. Chlorhexidine bathing and health care-associated infections: a randomized clinical trial. JAMA. Jan. 27. 2015;313(4):369-78. [pmid: 25602496].
37 Rupp ME, Cavalieri RJ, Lyden E, et al. Effect of hospital-wide chlorhexidine patient bathing on healthcare-associated infections. Infect Control Hosp Epidemiol. Nov. 2012;33(11):1094-100. [pmid: 23041806].
38 Manian FA, Griesnauer S, Bryant A. Implementation of hospital-wide enhanced terminal cleaning of targeted patient rooms and its impact on endemic Clostridium difficile infection rates. American journal of infection control. Jun. 2013;41(6):537-41. [pmid: 23219675].
39 Passaretti CL, Otter JA, Reich NG, et al. An evaluation of environmental decontamination with hydrogen peroxide vapor for reducing the risk of patient acquisition of multidrug-resistant organisms. Clinical Infectious Diseases. Jan. 2013;56(1):27-35. [pmid: 23042972].
40 Alfa MJ, Lo E, Olson N, et al. Use of a daily disinfectant cleaner instead of a daily cleaner reduced hospital-acquired infection rates. American journal of infection control. Feb. 2015;43(2):141-6. [pmid: 25534117].
41 Levin J, Riley LS, Parrish C, et al. The effect of portable pulsed xenon ultraviolet light after terminal cleaning on hospital-associated Clostridium difficile infection in a community hospital. American journal of infection control. Aug. 2013;41(8):746-8. [pmid: 23685092].
42 Stone SP, Fuller C, Savage J, et al. Evaluation of the national Cleanyourhands campaign to reduce Staphylococcus aureus bacteraemia and Clostridium difficile infection in hospitals in England and Wales by improved hand hygiene: four year, prospective, ecological, interrupted time series study. Bmj. 2012;344:e3005. [pmid: 22556101].
43 DiDiodato G. Has improved hand hygiene compliance reduced the risk of hospital-acquired infections among hospitalized patients in Ontario? Analysis of publicly reported patient safety data from 2008 to 2011. Infect Control Hosp Epidemiol. Jun. 2013;34(6):605-10. [pmid: 23651891].
44 Bearman G, Rosato AE, Duane TM, et al. Trial of universal gloving with emollient-impregnated gloves to promote skin health and prevent the transmission of multidrug-resistant organisms in a surgical intensive care unit. Infect Control Hosp Epidemiol. May. 2010;31(5):491-7. [pmid: 20350197].
45 Bishop J, Parry MF, Hall T. Decreasing Clostridium difficile infections in surgery: impact of a practice bundle incorporating a resident rounding protocol. Conn Med. Feb. 2013;77(2):69-75. [pmid: 23513633].
46 Brakovich B, Bonham E, VanBrackle L. War on the spore: Clostridium difficile disease among patients in a long-term acute care hospital. J Healthc Qual. May-Jun. 2013;35(3):15-21. [pmid: 22304334].
47 Mermel LA, Jefferson J, Blanchard K, et al. Reducing Clostridium difficile incidence, colectomies, and mortality in the hospital setting: a successful multidisciplinary approach. Jt Comm J Qual Patient Saf. Jul. 2013;39(7):298-305. [pmid: 23888639].
48 Price J, Cheek E, Lippett S, et al. Impact of an intervention to control Clostridium difficile infection on hospital- and community-onset disease; an interrupted time series analysis. Clin Microbiol Infect. Aug. 2010;16(8):1297-302. [pmid: 19832710].
49 You E, Song H, Cho J, et al. Reduction in the incidence of hospital-acquired Clostridium difficile infection through infection control interventions other than the restriction of antimicrobial use. Int J Infect Dis. May. 2014;22:9-10. [pmid: 24583565].
50 Cornely OA, Crook DW, Esposito R, et al. Fidaxomicin versus vancomycin for infection with Clostridium difficile in Europe, Canada, and the USA: a double-blind, non-inferiority, randomised controlled trial. The Lancet infectious diseases. Apr. 2012;12(4):281-9. [pmid: 22321770].
51 Johnson S, Louie TJ, Gerding DN, et al. Vancomycin, metronidazole, or tolevamer for Clostridium difficile infection: results from two multinational, randomized, controlled trials. Clinical Infectious Diseases. 2014;59(3):345-54. [pmid: 24799326].
52 Wenisch JM, Schmid D, Kuo HW, et al. Prospective observational study comparing three different treatment regimes in patients with Clostridium difficile infection. Antimicrob Agents Chemother. Apr. 2012;56(4):1974-8. [pmid: 22252830].
53 van Nood E, Vrieze A, Nieuwdorp M, et al. Duodenal infusion of donor feces for recurrent Clostridium difficile. New England Journal of Medicine. Jan. 31. 2013;368(5):407-15. [pmid: 23323867].
54 Cammarota G, Masucci L, Ianiro G, et al. Randomised clinical trial: faecal microbiota transplantation by colonoscopy vs. vancomycin for the treatment of recurrent Clostridium difficile infection. Aliment Pharmacol Ther. May. 2015;41(9):835-43. [pmid: 25728808].
55 Youngster I, Sauk J, Pindar C, et al. Fecal microbiota transplant for relapsing Clostridium difficle infection using a frozen inoculum from unrelated donors: a randomized, open-label, controlled pilot study. Clin Infect Dis. 2014;58(11):1515-22. [pmid: 24762631].
56 Mellow MH, Kanatzar A. Colonoscopic fecal bacteriotherapy in the treatment of recurrent Clostridium difficile infection--results and follow-up. J Okla State Med Assoc. Mar. 2011;104(3):89-91. [pmid: 21608450].
57 Youngster I, Russell GH, Pindar C, et al. Oral, capsulized, frozen fecal microbiota transplantation for relapsing Clostridium difficile infection. JAMA. 2014;312(17):1772-8. [pmid: 25322359].
58 Zainah H, Hassan M, Shiekh-Sroujieh L, et al. Intestinal microbiota transplantation, a simple and effective treatment for severe and refractory Clostridium difficile infection. Dig Dis Sci. Jan. 2015;60(1):181-5. [pmid: 25052150].
59 Lee CH, Belanger JE, Kassam Z, et al. The outcome and long-term follow-up of 94 patients with recurrent and refractory Clostridium difficile infection using single to multiple fecal microbiota transplantation via retention enema. Eur J Clin Microbiol Infect Dis. Aug. 2014;33(8):1425-8. [pmid: 24627239].
60 Garey KW, Ghantoji SS, Shah DN, et al. A randomized, double-blind, placebo-controlled pilot study to assess the ability of rifaximin to prevent recurrent diarrhoea in patients with Clostridium difficile infection. J Antimicrob Chemother. Dec. 2011;66(12):2850-5. [pmid: 21948965].
61 Laffan AM, McKenzie R, Forti J, et al. Lactoferrin for the prevention of post-antibiotic diarrhoea. J Health Popul Nutr. Dec. 2011;29(6):547-51. [pmid: 22283027].
62 Puri BK, Hakkarainen-Smith JS, Monro JA. The potential use of cholestyramine to reduce the risk of developing Clostridium difficile-associated diarrhoea in patients receiving long-term intravenous ceftriaxone. Med Hypotheses. Jan. 2015;84(1):78-80. [pmid: 25497389].
63 MacConnachie AA, Fox R, Kennedy DR, et al. Faecal transplant for recurrent Clostridium difficile-associated diarrhoea: a UK case series. Qjm. Nov. 2009;102(11):781-4. [pmid: 19726581].
64 Patel NC, Griesbach CL, DiBaise JK, et al. Fecal microbiota transplant for recurrent Clostridium difficile infection: Mayo Clinic in Arizona experience. Mayo Clin Proc. Aug. 2013;88(8):799-805. [pmid: 23910407].
65 Yoon S, Brandt L. Treatment of refractory/recurrent C. difficile-associated disease by donated stool transplanted via colonoscopy: a case series of 12 patients. Journal of Clinical Gastroenterology. 2010;44(8):562-6. [pmid: 20463588].
66 Munoz P, Bouza E, Cuenca-Estrella M, et al. Saccharomyces cerevisiae fungemia: an emerging infectious disease. Clin Infect Dis. Jun. 1. 2005;40(11):1625-34. [pmid: 15889360].
67 Barbut F, Surgers L, Eckert C, et al. Does a rapid diagnosis of Clostridium difficile infection impact on quality of patient management?. Clin Microbiol Infect. Feb. 2014;20(2):136-44. [pmid: 23565919].
68 Cohen SH, Gerding DN, Johnson S, et al. Clinical practice guidelines for Clostridium difficile infection in adults: 2010 update by the society for healthcare epidemiology of America (SHEA) and the infectious diseases society of America (IDSA). Infect Control Hosp Epidemiol. May. 2010;31(5):431-55. [pmid: 20307191].
69 Bartsch SM, Umscheid CA, Fishman N, et al. Is fidaxomicin worth the cost? An economic analysis. Clinical Infectious Diseases. 2013;57(4):555-61. [pmid: 23704121].
70 Drekonja D, Reich J, Gezahegn S, et al. Fecal microbiota transplantation for clostridium difficile infection: a systematic review. Ann Intern Med. May. 5. 2015;162(9):630-8. [pmid: 25938992].
71 Johnston BC, Ma SS, Goldenberg JZ, et al. Probiotics for the prevention of Clostridium difficile-associated diarrhea: a systematic review and meta-analysis. Ann Intern Med. Dec. 18. 2012;157(12):878-88. [pmid: 23362517].
72 Bakken JS. Staggered and tapered antibiotic withdrawal with administration of kefir for recurrent clostridium difficile infection. Clinical Infectious Diseases. 2014;59(6):858-61. [pmid: 24917658].