# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Dorothy Borton, R.N., B.S.N., CIC
  Einstein Healthcare Network
  Philadelphia, PA
- Sarah Doernberg, M.D., M.A.S.
  UCSF School of Medicine
  San Francisco, CA
- Belinda Ostrowsky, M.D., M.P.H., FSHEA, FIDSA
  Director, Antimicrobial Stewardship Program and Associate Professor
  Montefiore Medical Center/Albert Einstein College of Medicine
  Bronx, NY
- Gary Roselle, M.D.
  Department of Veterans Affairs, VA Central Office, and University of Cincinnati College of Medicine
  Cincinnati, OH
- David Rosenberg, M.D., M.P.H., FACP, SFHM
  NorthShore LIJ
  Manhasset, NY
- Vincent Young, M.D., Ph.D.
  Associate Professor
  Department of Internal Medicine/Infectious Disease Division
  University of Michigan Medical School
  Ann Arbor, MI