# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Erik Dubberke, M.D., M.S.P.H.^*^
  * Provided input on Draft Report.
  Washington University School of Medicine
  St. Louis, MO
- Clifford McDonald, M.D.^*^
  Centers for Disease Control and Prevention
  Atlanta, GA
- Rick Nolte, Ph.D.
  Medical University of South Carolina
  Charleston, SC
- Marcel Salive, M.D., M.P.H.^*^
  National Institute on Aging
  Bethesda, MD
- Christine Surawicz, M.D.^*^
  University of Washington School of Medicine
  Seattle, WA
- Michael Wilson, M.D.
  Denver Health Medical Center
  Denver, CO