# Acknowledgments

We thank Jeannine Ouellette and Marilyn Eells for their editorial help bringing the report to completion. We also thank Kim Wittenberg and Tim Carey for their helpful editorial comments.