# Ongoing Studies

Appendix Table I1 Ongoing phase 3 or phase 4 studies

NCT Number | Title | Population | Interventions | Study Designs
Vaccines
NCT01887912 Recruiting | Study of a Candidate Clostridium Difficile Toxoid Vaccine in Subjects at Risk for C. Difficile Infection | Subjects >50 age at risk for CDI and substantial unmet medical need | Vaccine | Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Single Blind (Outcomes Assessor) Primary Purpose: Prevention
Antibiotics
NCT02200328 Recruiting | Efficacy of Metronidazole Prophylaxis Against Clostridium Difficile-Associated Diarrhea in High Risk Adult Patients | Inpatients 55 years and older at risk for CDI | Metronidazole vs. placebo | Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Single Blind (Caregiver) Primary Purpose: Prevention
NCT02237859 Recruiting | Vancomycin Prophylaxis in Recurrent Clostridium Difficile Infection | Adult inpatients with history of CDI within 16 weeks and treated with Flagyl or Vancomycin, or at risk | Vancomycin vs. fruit juice/placebo | Endpoint Classification: Efficacy Study Intervention Model: Single Group Assignment Masking: Double Blind (Subject, Caregiver, Investigator) Primary Purpose: Prevention
NCT01597505 Recruiting | Study of CB-183,315 in Patients with Clostridium Difficile Associated Diarrhea | Adults with CDI | Surotomycin vs. oral vancomycin | Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor) Primary Purpose: Treatment
NCT02179658 Recruiting | A Study to Compare Safety and Efficacy of Fidaxomicin with Vancomycin in Subjects with Clostridium Difficile-associated Diarrhea (CDAD) | Japanese adult inpatients with CDI | Fidaxomycin vs. vancomycin | Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor) Primary Purpose: Treatment
NCT02254967 Recruiting | Study to Compare The Efficacy of Vancomycin Therapy to Extended Duration of Fidaxomicin Therapy in the Clinical Cure of CDI in and Older Population (EXTEND) | Adults >60 with CDI | Fidaxomicin vs. vancomycin | Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Open Label Primary Purpose: Treatment
NCT01987895 Recruiting | Phase 3 Study with Cadazolid in CDAD | Adults with CDI | Cadazolid vs. vancomycin | Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Double Blind (Subject, Investigator) Primary Purpose: Treatment
FMT
NCT02326636 Recruiting | Fecal Microbiota Transplant for Recurrent Clostridium Difficile Infection | Adult patients referred for recurrent CDI | Fecal Microbiota Transplant | Observational Model: Cohort Time Perspective: Prospective
NCT01958463 Recruiting | Transplantation of Fecal Microbiota for Clostridium Difficile Infection | Adult patients with recurrence within 6 months, or not responding to treatment | Fecal microbiota transplant | Endpoint Classification: Efficacy Study Intervention Model: Single Group Assignment Masking: Open Label Primary Purpose: Treatment
NCT02301000 Recruiting | IMT for Primary Clostridium Difficile Infection | Adults with primary CDI | Intestinal microbiota therapy vs. metronidazole | Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Single Blind (Outcomes Assessor) Primary Purpose: Treatment
Probiotics
NCT01687543 Recruiting | Probiotics for Reduction of Infections with Clostridium Difficile in Critically Ill Patients (ProbiEnt) | Adult inpatient ICU | Dietary Supplement: L. plantarym 229 and L. plantarum 229v (+maltodextrin) vs. matodextrin | Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Double Blind (Subject, Caregiver, Investigator) Primary Purpose: Prevention
NCT01873872 Recruiting | Evaluation of Probiotics and the Development of Clostridium Difficile Associated Diarrhea in Patients Receiving Antibiotics | Adult inpatients at risk for CDI due to antibiotic use | Theralac probiotic vs. culturelle probiotic vs. placebo | Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor) Primary Purpose: Prevention
NCT02076438 Recruiting | Probiotics for Prevention of Antibiotic Associated Diarrhea and Clostridium Difficile Associated Disease | Adult inpatients with CDI | Probiotics: Culturelle (Lactobacillus Rhamnosus GG) vs. placebo | Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Double Blind (Subject, Caregiver, Investigator) Primary Purpose: Prevention