# Strength of Evidence

The Strength of Evidence approach relies on a technique called structured implicit judgment. This technique has reviewers rate the quality of individual components and then use their judgment to produce an overall rating that takes all the components into account. For Strength of Evidence, the domains are reported out as categorical, but in fact represent concepts that should be viewed as a continuum. The final overall assessment should be consistent with domains but convey a final, global assessment. Thus, two outcomes can have two different overall assessments (that is, either insufficient or low, or low or moderate, or moderate or high) when the domains are coded identically.

Appendix Table H1 Strength of evidence assessments

Comparison | Outcomes | Finding | Study Limitations | Directness | Precision | Consistency | Evidence Rating
Diagnostics
LAMP (1 test, 12 arms) | Sensitivity Specificity | 0.95, 95% CI .090-0.97 0.98, 95% CI 0.96-0.99 | Low | Direct | Precise | Consistent | High (unable to detect reporting bias)
PCR (10 tests, 31 arms) | Sensitivity Specificity | 0.95, 95% CI 0.93-0.96 0.97, 95% CI 0.96-0.98 | Low | Direct | Precise | Consistent | High (unable to detect reporting bias)
Toxin A/B (8 tests, 58 arms) | Sensitivity Specificity | 0.70, 95% CI 0.66-0.74 0.98, 95% CI 0.97-0.98 | Low | Direct | Imprecise | Consistent | Moderate (unable to detect reporting bias)
GDH (4 tests, 10 arms) | Sensitivity Specificity | 0.90, 95% CI 0.78-0.96 0.94, 95% CI 0.89-0.97 | Moderate | Direct | Precise | Consistent | Moderate (unable to detect reporting bias)
Test Algorithms (11 tests, 11 arms) | Sensitivity Specificity | 0.73, 95% CI 0.62-0.82 1.00, 95% CI 0.99-1.00 | Moderate | Direct | Imprecise | Consistent | Low
Prevention
Antibiotic stewardship (1 systematic review, 6 studies) | CDI Incidence | Appropriate prescribing practices associated with decreased CDI | | | | | Low, per systematic review
Bathing (2 studies) | CDI Incidence | | Moderate | Direct | Imprecise | Inconsistent | Insufficient
Daily cleaning with hydrogen peroxide disposable wipes (1 study) | CDI Incidence | | High | Direct | Imprecise | Single Study | Insufficient
Hydrogen peroxide vapor (3 studies) | CDI Incidence | | High | Direct | Imprecise | Consistent | Insufficient
Pulsed ultraviolet light (1 study) | CDI Incidence | | High | Direct | Imprecise | Single Study | Insufficient
Handwashing campaigns (1 moderate risk of bias study as best evidence) | CDI Incidence | Reduced CDI (rates fell from 16.75 to 9.49 cases per 10,000 bed days) | Moderate | Direct | Imprecise | Single Study | Low
Multicomponent prevention interventions (4 studies) | CDI Incidence | Sustainable over several years | Moderate | Direct | Imprecise | Consistent | Low
Treatment
Vancomycin vs. Metronidazole 4 RCT N=872 initial N=705 recur | Initial cure | 83.9% vs. 75.7%; RR 1.08, 95% CI 1.02 – 1.15 | Moderate (update studies – low, with larger N; original review - high) | Direct | Precise | Consistent | High (reporting bias undetected) (Weighted by newer, lower risk of bias studies with larger N)
Vancomycin vs. Metronidazole 4 RCT N=872 initial N=705 recur | Recurrent CDI | 16.5% vs. 18.7%; RR 0.89, 95% CI 0.65 – 1.23 | Moderate (update studies – low, with larger N; original review - high) | Direct | Imprecise | Consistent | Moderate (reporting bias undetected) (Weighted by newer, lower risk of bias studies with larger N)
Fidaxomicin vs. Vancomycin 2 RCT N=1,111 initial N=962 recur | Initial cure | RR 1.02, 95% CI 0.98-1.07 | Low (low both update and original) | Direct | Imprecise | Consistent | Moderate (reporting bias undetected)
Fidaxomicin vs. Vancomycin 2 RCT N=1,111 initial N=962 recur | Recurrent CDI | RR 0.55, 95% CI 0.42-0.71 | Low (low both update and original) | Direct | Precise | Consistent | High (reporting bias undetected)
Effect by Disease Severity – any antibiotic 2 RCT, 1 observational | Initial cure | NS | High (update studies – moderate; original review - high | Direct | Imprecise | Consistent | Low
FMT 3 RCT, 23 case series N=751 | | Resolves diarrhea and prevents relapse in patients with recurrent CDI | High (case series except 2 high risk of bias trials) | Direct | Imprecise, but numerous case series | Consistent | Low (unable to detect reporting bias) (Weighted by relatively large N, consistency of large number of case series)
FMT 3 RCT, 23 case series N=751 | | Mixed finding regarding resolving diarrhea in patients with refractory CDI (n=19) | High (all case series) | Direct | Imprecise, only 2 trials | Unknown | Insufficient
Multi-organism Probiotics vs placebo 5 RCT N=3960 | Primary prevention | RR 0.48, 95%, CI 0.28-0.88 | High (dominated by Allen) | Direct | Imprecise (small number of events possible for small samples) | Consistent | Low (unable to detect reporting bias) (Weighted by large N)
S. boulardii vs placebo 6 RCT N=1244 | Primary prevention | RR 0.77, 05% CI 0.38-1.54 | High (not dominated) | Direct | Imprecise (small number of events possible for small samples) | Consistent | Low (unable to detect reporting bias) (Weighted by relatively large N)
Single strain lactobacillus 6 RCT N=1251 | Primary prevention | RR 0.27, 95% CI 0.15-0.49 | High (dominated by Gao) | Direct | Imprecise (small number of events possible for small samples) | Inconsistent | Low (unable to detect reporting bias) (Weighted by relatively large N)

RR = relative risk [95 percent confidence intervals]; NS = No statistically significant difference.