# Detailed Analyses

## KQ1 Diagnostics

Appendix Figure G1 LAMP negative likelihood ratio

Appendix Figure G1 displays the negative likelihood ratios for loop mediated isothermal amplification diagnostic tests by individual study arm and by pooled arms. When endpoint data from 12 arms were pooled, the negative likelihood ratio was 0.041.

Appendix Figure G2 LAMP positive likelihood ratio

Appendix Figure G2 displays the positive likelihood ratios for loop mediated isothermal amplification diagnostic tests by individual study arm and by pooled arms. When endpoint data from 12 arms were pooled, the positive likelihood ratio was 50.789.

Appendix Figure G3 LAMP SROC

Appendix Figure G3 displays the summary receiver operating characteristic curve for the loop mediated isothermal amplification diagnostic tests. The area under the curve is high, since the curve is pushed into the far upper-left corner of the plot. The lower bound of the curve ends above 0.8 sensitivity and the upper bound of the curve ends just about 0.2 for 1-specificity.

Appendix Figure G4 PCR negative likelihood tatio

Appendix Figure G4 displays the negative likelihood ratios for polymerase chain reaction diagnostic tests by individual study arm and by pooled arms. When endpoint data from 31 arms were pooled, the negative likelihood ratio was 0.035.

Appendix Figure G5 PCR positive likelihood ratio

Appendix Figure G5 displays the positive likelihood ratios for polymerase chain reaction diagnostic tests by individual study arm and by pooled arms. When endpoint data from 31 arms were pooled, the positive likelihood ratio was 29.810.

Appendix Figure G6 PCR SROC

Appendix Figure G6 displays the summary receiver operating characteristic curve for the polymerase chain reaction diagnostic tests. The curve is pushed into the far upper-left corner of the plot. The lower bound of the curve ends below 0.8 sensitivity and the upper bound of the curve ends before 0.2 for 1-specificity.

Appendix Figure G7 Toxin A/B negative likelihood ratio

Appendix Figure G7 displays the negative likelihood ratios for immunoassys for toxin A or B disagnostic tests by individual study arm and by pooled arms. When endpoint data from 58 arms were pooled, the negative likelihood ratio was 0.220.

Appendix Figure G8 Toxin A/B positive likelihood ratio

Appendix Figure G8 displays the positive likelihood ratios for immunoassys for toxin A or B disagnostic tests by individual study arm and by pooled arms. When endpoint data from 58 arms were pooled, the positive likelihood ratio was 32.411.

Appendix Figure G9 Toxin A/B SROC

Appendix Figure G9 displays the summary receiver operating characteristic curve for immunoassys for toxin A or B diagnostic tests. The curve is pushed to the far left side of the plot. The lower bound of the curve ends above 0.2 sensitivity and the upper bound of the curve ends just before 0.2 for 1-specificity.

Appendix Figure G10 GDH negative likelihood ratio

Appendix Figure G10 displays the negative likelihood ratios for glutamate dehydrogenase diagnostic tests by individual study arm and by pooled arms. When endpoint data from 10 arms were pooled, the negative likelihood ratio was 0.076 .

Appendix Figure G11 GDH positive likelihood ratio

Appendix Figure G11 displays the positive likelihood ratios for glutamate dehydrogenase diagnostic tests by individual study arm and by pooled arms. When endpoint data from 10 arms were pooled, the positive likelihood ratio was 17.651.

Appendix Figure G12 GDH SROC

Appendix Figure G12 displays the summary receiver operating characteristic curve for glutamate dehydrogenase diagnostic tests. The curve is pushed to the far left side of the plot. The lower bound of the curve ends at about 0.6 sensitivity and the upper bound of the curve ends just past 0.2 for 1-specificity.

Appendix Figure G13 All test algorithms negative likelihood ratio

Appendix Figure G13 displays the negative likelihood ratios for test algorithms for diagnostic tests by individual study arm and by pooled arms. When endpoint data from 11 arms were pooled, the negative likelihood ratio was 0.220.

Appendix Figure G14 All test algorithms positive likelihood ratio

Appendix Figure G14 displays the positive likelihood ratios for test algorithms for diagnostic tests by individual study arm and by pooled arms. When endpoint data from 11 arms were pooled, the positive likelihood ratio was 130.828.

Appendix Figure G15 All test algorithms SROC

Appendix Figure G15 displays the summary receiver operating characteristic curve for test algorithms for diagnostic tests. The curve is pushed to the far left side of the plot. The lower bound of the curve ends just above 0.4 sensitivity and the upper bound of the curve ends about 0.1 for 1-specificity.

## KQ2 Prevention

Appendix Table G1 Prevention interventions, all with CDI incidence as outcome

Author, Year Country | Study Design | Population Setting | CDI Definition Timing Testing | Intervention | Study Findings
Antibiotic Stewardship
Filice, 2013^92^ United States | Systematic review 37 included studies 1 RCT, 5 interrupted time series (one of which overlapped with the original report) relevant to CDI incidence | Patients at risk for CDI Inpatient settings, not pediatric | Defined: based on individual study Timing: NA Testing: NA | Inpatient antimicrobial stewardship programs | Low strength evidence from 3 moderate and 3 high risk of bias studies that broad range of antimicrobial stewardship programs reduce CDI incidence (qualitative synthesis)
Transmission Interruption
Rupp, 2012^93^ United States | Quasi-experimental staged introduction trial in 3 cohorts, 19 months followed by 4 month wash-out | Patients at risk for CDI 689-bed academic medical center (not pediatric). Nebraska. Not outbreak setting. | Defined: CDC NHSN criteria Timing: Not reported Testing: Not reported | Chlorhexidine gluconate (CHG) bathing 3 days per week or daily | CDI RR 0.41 (95% CI, 0.29 to 0.59) for daily bathing, 0.71 (95%, CI 0.57 to 0.89) for 3 times per week, and 1.85 (95% CI, 1.38 to 2.53) for CDI in washout period compared with daily bathing. Daily more effective than 3 times per week Adverse Events: no events reported
Noto, 2015^94^ United States | Pragmatic cluster randomized cross-over trial, 1 year | Patients at risk for CDI 5 adult intensive care units, tertiary medical center, Nashville Tennessee. Not outbreak setting | Defined: CDC NHSN criteria Timing: Not reported Testing: Not reported | Chlorhexidine gluconate bathing daily for 10-week period followed by 2-week wash-out. Daily bathing assigned 3 times over the study | CDI rate not different between groups by both intention-to-treat and as-treated analyses.
Alfa, 2015^95^ Canada | Prospective interrupted time series, 3 years historical, 1 year intervention | Patients at risk for CDI 538-bed tertiary care hostpital (medicine, cardiac, surgery, women and child wards), Manitoba. Not outbreak setting. | Defined: Not reported Timing: Not reported Testing: 4 step algorithm | Daily disinfectant cleaning with hydrogen peroxide disposable wipes on high-touch surfaces in patient care rooms | When compliance was >80%, CDI dropped from 54 to 39 cases/10,000 patients (p=.0005)
Manian, 2013^97^.1.^90^ United States | Retrospective Pre/post single site. 1 year followup. | Patients at risk for CDI (not pediatric or rehabilitation) 900-bed teaching hospital, St. Louis, MO. Not outbreak setting | Defined: diarrhea with positive test for toxin A/B Timing:3 days after admission or 7 days after discharge Test: EIA (Meridian) | Hydrogen peroxide vapor in sealed room | CDI incidence rate dropped from 0.88/1000 patient days to 0.55/1000 patient days (0.63. 95% CI, 0.50 to 0.79) Adverse Events: Reported no events related to cleaning
Passaretti, 2013^98^ United States | Prospective cohort intervention in 3 cohorts. 1 year, 6 month followup | Patients at risk for CDI 994-bed tertiary hospital. Maryland. Not outbreak setting. | Defined: Not reported Timing: 48 hours after admission Test: Not reported | Hydrogen peroxide vapor in sealed room | Trend in reduced rate but no statistical difference in CDI incidence rate. Adverse Events: Reported no events related to cleaning
Levin, 2013^96^ United States | Pre/post single site. 1 year followup | Patients at risk for CDI 140-bed community hospital, Western MA. Not outbreak setting. | Defined: CDC NHSN criteria Timing: not reported Test: PCR and Immunocard Toxins A and B | Portable pulsed xenon ultraviolet light used in 3 7-minute sessions per patient room. Device operated remotely by cleaning personel. Safety feature turns off light if door opens. | CDI rates declined from 9.46 per 10,000 in 2010 to 4.45 per 10,000 in 2011, a 53% reduction. Declines also in deaths, from 6 to 1, and coloctomies, from 3 to 0.
Stone, 2012^99^ United Kingdom | Prospective, ecological, interrupted time series. 3 year followup after roll-out | Patients 65+ years at risk for CDI 187 hospital trusts in England . Not outbreak setting. | Defined: Not reported Timing: 48 hours after admission Test: Not reported | Clean your hands campaign: alcohol rub at bedside, reminder posters, compliance audit and feedback, materials to patients empowering them to remind healthcare workers to clean their hands | CDI fell from peak of 16.75 to 9.49 cases per 10,000 bed days. Soap use independently associated with reduced CDI. CDI was not associated with alcohol gel in multivariate analysis.
DiDiodato, 2013^100^ Canada | Prospective, ecological, interrupted time series. 3 years | Patients at risk for CDI 166 acute care hospitals, Ontario. Not outbreak setting. | Defined: Not reported Timing: 72 hours after admission Test: Not reported | Ontario Just Clean Your Hands patient safety initiative. Education and training program. Mandated hand hygiene audits and public reporting | No statistical differences found
Bearman, 2010^101^ United States | Prospective Pre/post single site. 6 month followup | Patients at risk for CDI 18 bed surgical intensive care unit (820-bed academic medical center) Virginia. Not outbreak setting. | Defined: Not reported Timing: Not reported Test: Not reported | Universal gloving with emollient-impregnated gloves | No significant differences in CDI incidence
Multicomponent
Brakovich, 2013^102^ United States | Prospective Pre/post single site design. 2 year followup | Patients at risk for CDI 50-bed long-term acute care hospital, southeastern United States. Not outbreak setting. | Defined: unclear Timing: first event at least 3 days after admission Test: for antigen marker, C. diff glutamate dehydrogenase, toxins A and B | Tiered approach: Cleaning education plan developed based on empiric test of site terminal cleaning Microfiber mops Hydrogen peroxide vapor equipment/services Bleach Contact isolation Hand hygiene Antimicrobial stewardship plan Quarterly feedback | CDI incidence rate: 44.25% decrease in cumulative rate, sustained over 2 years. (Cumulative rate drop from 56.52 to 31.51)
Bishop, 2013^103^ United States | Prospective pre/post single site design. 3 year followup | Surgical patients at risk for CDI Connecticut community hospital (Stamford Hospital). Not outbreak setting | Defined: CDC NHSN criteria Timing: within 30 days of hospital exposure Test: EIA (2007-2008) PCR (2009-2010) | Resident rounding protocol Antibiotic stewardship Restriction of gastric acid suppression Contact isolation Hand hygiene (Terminal cleaning previously introduced) | CDI incidence rate: 41% decrease in annual rate, sustained over 3 year 64% decrease in patient days. (2.8/1000 vs 1.8/1000
Mermel, 2013^104^ United States | Time series single site design. 6 year, 9 month followup. Prospective monitoring | Patients at risk for CDI 719-bed Rhode Island tertiary care hospital (Rhode Island Hospital). Post-outbreak setting. | Defined: CDC NHSN criteria Timing: includes patients with 30 day readmit with diarrhea and confirmed toxin present. Test: PCR | Progressive roll-out of elements of CDI control plan based on risk assessment Monitor CDI morbidity/mortality Improve testing using PCR Enhance environmental cleaning CDI treatment plans Other interventions | CDI incidence rate: drop from 12.2/1000 to 3.6/1000. Annual mortality drop from 52 to 19
Price, 2010^105^ United Kingdom | Interrupted time series single site design; 12 months pre, 15 months post. Retrospective | Patients at risk for CDI 820-bed teaching hospital and tertiary services (Brighton and Sussex University Hospital NHS Trust). Not outbreak setting | Defined: Liquid stool and positive test for Toxins A or B Timing: More than 3 days after admission or before 3 days after discharge Test: Not reported | Restrictive antibiotic use and isolation or cohorting active cases | Increase in the CDI reduction rate from 3% to 8% per month.
You, 2014^106^ Korea | Retrospective Pre/post single site design, 9 month followup | Patients at risk for CDI Medical intensive care unit (Korea). Not outbreak setting. | Defined:symptoms and positive test Timing: Not reported Test: PCR | Education, isolation, hand hygiene, contact precautions, and environmental disinfection. Did not include restricting antimicrobial agents | CDI incidence rate: decrease from 4.7/1000 to 1.53/1000 patient days. Overall hospital rate increased over same period.

CDI=C. difficile infection; CDC NHSF-Centers for Disease Control and Prevention National Healthcare Safety Network; SHEA=Society for Healthcare Epidemiology of America

## KQ3 Standard Treatment

### Initial Cure

A single new RCT comparing metronidazole, vancomycin, and tolevamer was published in 2014.^37^ Tolevamer was inferior to both metronidazole and vancomycin, and is not discussed further since it is not licensed by the U.S. Food and Drug Administration. The results of the metronidazole and vancomycin arms (n = 537) showed that vancomycin led to a significant increase in subjects achieving initial cure (81.1 percent versus 72.7 percent; P = .02). When combined with the three previous RCTs comparing metronidazole to vancomycin,41-43 the percentage of subjects achieving initial cure was significantly higher among those receiving vancomycin (83.9 percent versus 75.7 percent; RR 1.08, 95% CI 1.02 – 1.15).

The second RCT identified in our update is a trial of fidaxomicin versus vancomycin (n = 509).38 This study is the second of two studies that led to the approval of fidaxomicin for the treatment of CDI in the United States. Consistent with the first study, which was included in our original review, fidaxomicin performed similarly to vancomycin for the outcome of initial cure. Specifically, the percentage of subjects meeting initial cure did not differ significantly by treatment received (87.7 percent for fidaxomicin versus 86.8 percent for vancomycin; P = .79). Combining these results with those from the first study of fidaxomicin versus vancomycin40 led to a similar finding of no significant difference in initial cure when stratified by treatment received (87.6 percent versus 85.6 percent; RR 1.02, 95% CI 0.98 – 1.07).

### Recurrent CDI

The newly identified trial of metronidazole versus vancomycin37 demonstrated no difference between the two agents for the outcome of recurrent CDI (20.6 percent versus 23.0 percent; P = .64). Similarly, when data from this study were pooled with the three previous RCTs comparing metronidazole versus vancomycin, no significant differences were observed (16.5 percent versus 18.7 percent; RR 0.89, 95% CI 0.65 – 1.23).

In contrast, the trial of fidaxomicin versus vancomycin demonstrated that use of fidaxomicin led to significantly fewer subjects having recurrent CDI (12.7 percent versus 26.9 percent; P = .002). Similarly, when pooled with the data from the prior study of fidaxomicin and vancomycin,40 recurrence remained less likely after fidaxomicin treatment (14.1 percent versus 26.1 percent; RR 0.55, 95% CI 0.42 – 0.71).

Finally, the observational study noted similar recurrence rates after oral metronidazole and vancomycin (20.6 percent and 19.0 percent, respectively), but higher rates after intravenous metronidazole (50.0 percent; P = .007).

Appendix Table G2 Initial clinical cure: # subjects / # randomized (%) for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | RR [95% CI]
Johnson, 2014^37^ | 210/259 (81) | 202/278 (73) | 1.12 [1.02 to 1.22]
Zar, 2007^41^ | 69/82 (84) | 66/90 (73) | 1.15 [0.98 to 1.34]
Wenisch, 1996^42^ | 29/31 (94) | 29/31 (94) | 1.00 [0.88 to 1.14]
Teasley, 1983^43^ | 51/56 (91) | 39/45 (87) | 1.05 [0.91 to 1.21]
Totals | 359/428 (84) | 336/444 (76) | 1.08 1.01 to 1.15]]

CI = confidence interval; RR = relative risk

Appendix Figure G16 Initial clinical cure: vancomycin versus metronidazole

Appendix Figure G16 is a forrest plot displaying data presented in Appendix Table G2 about the efficacy of two standard antibiotic treatments, vancomycin versus metronidazole, for the outcome initial cure of CDI.

Appendix Table G3 Initial clinical cure: # subjects / # randomized (%) for fidaxomicin versus vancomycin

Study | Fidaxomicin | Vancomycin | RR [95% CI]
Cornely, 2012^38^ | 221/252 (88) | 223/257 (87) | 1.01 [0.95 to 1.08]
Louie, 2011^40^ | 253/289 (88) | 265/313 (85) | 1.03 [0.97 to 1.10]
Totals | 474/541 (88) | 488/570 (86) | 1.02 [0.98 to 1.07]

CI = confidence interval; RR = relative risk

Appendix Figure G17 Initial clinical cure: vancomycin versus fidaxomicin

Appendix Figure G17 is a forrest plot displaying data presented in Appendix Table G3 about the efficacy of two standard antibiotic treatments, fidaxomicin versus vancomycin, for the outcome initial cure of CDI.

Appendix Table G4 Clinical recurrence: # subjects / # initially cured (%) for vancomycin versus metronidazole

Study | Vancomycin | Metronidazole | Relative Risk [95% CI]
Johnson, 2014^37^ | 43/209 (21) | 49/213 (23) | 0.89 [0.62 to 1.28]
Zar, 2007^41^ | 5/69 (7) | 9/66 (14) | 0.53 [0.19 to 1.50]
Wenisch, 1996^42^ | 5/29 (17) | 5/29 (17) | 1.00 [0.32 to 3.09]
Teasley, 1983^43^ | 6/51 (12) | 2/39 (5) | 2.29 [0.49 to 10.76]
Totals | 59/358 (16) | 65/347 (19) | 0.89 [0.65 to 1.23]

CI = confidence interval

Appendix Figure G18 Recurrence of CDI: metronidazole versus vancomycin

Appendix Figure G18 is a forrest plot displaying data presented in Appendix Table G4 about the efficacy of two standard antibiotic treatments, vancomycin versus metronidazole, for the outcome recurrence of CDI.

Appendix Table G5 Clinical recurrence: # subjects / # initially cured (%) for fidaxomicin versus vancomycin

Study | Fidaxomicin | Vancomycin | Relative Risk [95% CI]
Cornely, 2012^38^ | 28/221 (13) | 60/223 (27) | 0.47 [0.31 to 0.71]
Louie, 2011^40^ | 39/253 (15) | 67/265 (25) | 0.61 [0.43 to 0.87]
Totals | 67/474 (14) | 127/488 (26) | 0.55 [0.42 to 0.71]

CI = confidence interval

Appendix Figure G19 Recurrence of CDI: vancomycin versus fidaxomicin

Appendix Figure G19 is a forrest plot displaying data presented in Appendix Table G5 about the efficacy of two standard antibiotic treatments, fidaxomicin versus vancomycin, for the outcome recurrence of CDI.

Appendix Table G6 Severe disease: # subjects / # (%)

Study | Fidaxomicin | Vancomycin | Metronidazole | Finding
Cornely, 2012^38^ initial cure | 48/63 (76) | 43/61 (71) | | RR 0.81 [CI 0.45-1.45]
Cornely, 2012^38^ recurrence | 4/48 (8) | 14/43 (33) | | RR 0.26 [CI 0.09-0.72] results fragile to missing or reassignment
Johnson, 2014^37^ Initial cure | | 50/64 (79) | 61/92 (66) | RR 0.65 [CI 0.38-1.12]
Zar 2007^41^ Initial cure | | 24/31 (78) | 25/38 (66) | RR 1.20 [CI 0.92-1.57]

## KQ4 Nonstandard Treatment

### FMT for Recurrent CDI

We identified 26 studies that addressed FMT for recurrent CDI of which three were small size RCTs and the remaining were observational. We identified two studies that included both recurrent and active CDI.57,68 The studies included individuals between the ages of 7 and 90 years, with children included in one study. In 18 of the 21 studies, >55 percent of the participants were women. Two studies reported race and ethnicity distribution.47,62 One of these studies enrolled 21 indivduals for FMT of which 74 percent were white, 22 percent black ,and 4 percent Asian.47 The other study enrolled 26 individuals, 100 percent of whom were white.62 Most studies were small, enrolling 12 to 94 individuals. Followup was variable, and ranged from 3 weeks to 8 years. Outcomes reported were resolution of diarrhea or symptoms, recurrence. and adverse events.

The three RCTs are noteworthy. One unblinded, three-arm RCT, conducted in the Netherlands, enrolled 43 adults with recurrent CDI with mean age of 70, 43 percent women.59 Patients were randomized to oral vancomycin, FMT, or vancomycin plus bowel lavage. Followup was 10 weeks and the endpoint was resolution of diarrhea. The study was stopped early due to a large difference in the FMT and comparator groups (81 percent versus 31 percent and 23 percent). FMT was administered via nasoduodenal tube. However, the CDI rate in the comparator groups was unusually low.

Cammarota and colleagues conducted an additional unblinded trial of FMT via colonoscopy versus a vancomycin regimen that was given for at least 3 weeks, with the latter half given in a pulsed fashion (dosed every 2-3 days).44 In patients with pseudomembranous colitis, the FMT protocol was amended after two patients to give FMT infusions every 3 days until resolution of colitis, versus the single infusion given to patients with CDI without pseudomembranous colitis. This study enrolled 39 subjects, with a mean age of 73. The primary endpoint was resolution of diarrhea associated with CDI at 10 weeks after the end of treatment. When analyzed by resolution after a single course of treatment (FMT or vancomycin), 65 percent of subjects had resolution of diarrhea with FMT, versus 26 percent with vancomycin. The authors noted that administering multiple courses of FMT increased the success rate to 90 percent in the FMT group and that multiple antibiotic courses increased the success rate to 53 percent in the vancomycin group. This study was also stopped early after an interim analysis.

Youngster and colleagues conducted an unblinded RCT that randomized 20 individuals with recurrent CDI, with mean age of 54, to colonoscopic or nasogastric administration of FMT.54 The study endpoint was resolution of diarrhea without relapse within 8 weeks. The authors found no difference between the two modalities of FMT administration.

Appendix Figure G20 Resolution of symptoms after initial FMT for recurrent CDI, all routes

Appendix Figure G20 is a forrest plot displaying data presented in Appendix Table G7 for the outcome resolution of symptoms after initial FMT for recurrent CDI.

Appendix Table G7 Resolution of symptoms after initial FMT for recurrent CDI

Study | Events / Sample Size (Event Rate) | 95% CI Lower Limit | 95% CI Upper Limit
Aas, 2003^66^ | 15/18 (83) | 0.59 | 0.95
Cammarota, 2015^44^ | 13/20 (65) | 0.43 | 0.82
Dutta, 2014^47^ | 27/27 (98)* | 0.77 | 1.0
Emanuelsson, 2013^55^ | 15/23 (65) | 0.44 | 0.82
Garborg, 2010^65^ | 29/40 (73) | 0.57 | 0.84
Hamilton, 2012^60^ | 37/43 (86) | 0.72 | 0.94
Jorup-Ronstrom, 2012^61^ | 22/32 (69) | 0.51 | 0.82
Kelly, 2012^62^ | 25/26 (96) | 0.77 | 0.99
Khan, 2014^48^ | 18/20 (90) | 0.68 | 0.97
Lee, 2014^49^ | 45/94 (48) | 0.38 | 0.58
MacConnachie, 2009^69^ | 11/15 (73) | 0.47 | 0.90
Mattila, 2012^63^ | 66/70 (94) | 0.86 | 0.98
Mellow, 2011^64^ | 12/12 (92) | 0.61 | 0.99
Patel, 2013^56^ | 22/30 (73) | 0.55 | 0.86
Pathak, 2014^57^ | 11/12 (92) | 0.59 | 0.99
Ray, 2014^50^ | 20/20 (100) | 0.71 | 1.00
Rohlke, 2010^67^ | 18/19 (95) | 0.71 | 0.99
Rubin, 2013^58^ | 58/72 (81) | 0.70 | 0.88
Satokari, 2015^45^ | 47/49 (96) | 0.85 | 0.99
Seekatz, 2014^51^ | 12/14 (86) | 0.57 | 0.96
Van Nood, 2013^59^ | 13/16 (81) | 0.55 | 0.94
Weingarden, 2014^52^ | 11/12 (92) | 0.59 | 0.99
Yoon, 2010^68^ | 12/12 (96)* | 0.60 | 1.0
Youngster, 2014a53 | 14/20 (70) | 0.47 | 0.86
Youngster, 2014b54 | 14/20 (70) | 0.47 | 0.86
Zainah, 2015^46^ | 11/14 (79) | 0.51 | 0.93
Total | 518/612 (85) | 0.76 | 0.87

CI=confidence interval

### FMT for Refractory CDI

Three studies reported outcomes for FMT in individuals with refractory CDI (defined as an episode that did not respond to antibiotic treatment). All were from case series, totaling 19 individuals.46,53,64 Overall, there was insufficient strength of evidence supporting the role of FMT in refractory CDI. Unfortunately, few FMT studies provided detailed patient information to identify whether included patients could be considered refractory.

Appendix Table G8 Resolution of symptoms after initial FMT for recurrent CDI

Study | Refractory Sample | Cleared of CDI
Mellow, 2011^64^ | 1 | 1/1
Youngster, 2014 (oral)53 | 4 | 2/4
Zainah, 2015^46^ | 14 | 11/14

### Probiotics for CDI

We identified a total of 18 studies that reported use of probiotics as adjunctive treatment for CDI: nine RCTs and one observational study were newly identified, while seven RCTs were included in the prior report. With the plethora of RCTs to provide a best evidence base, the observational study will not be discussed further.

Probiotics were administered as an adjunct to standard antibiotic treatment for CDI in all the studies. All studies included adults with mean reported age of 50 to 77 years. The studies enrolled 40 to 2981 subjects. The probiotics tested were lactobacilli species in six studies, sacchromyces species (S. boulardii) in six studies, and multiorganism in five studies: both lactobacillus and saccharomyces species in one study, lactobacillus and bifidobacterium in two studies, a four-strain preparation of L. acidophilus, L. paracasei, and bifidobacterium in one study, and VSL#3 in one study. VSL#3 contained Bifidobacterium breve, Bidfidobacterium longum, Bifidobacterium infantis, Lactobacillus acidophilus, Lactobacillus plantarum, Lactobacillus paracasei, Lactobacillus delbrueckii subsp. Bulgaricus, and Streptococcus thermophiles. The comparator was placebo in 16 studies and standard care or no treatment in one study each. In four studies the probiotic was continued for the duration of antiobiotic therapy,78-80,83 while in the others, the probiotic was continued for 3 to 21 days beyond antibiotic administration. Study endpoint was diagnosis of CDI and followup was limited, typically ranging from 7 days to 4 weeks, with two RCTs extending followup to 12 weeks.

For quantitative analysis, we categorized probiotics as single organism strains (lactobacillus species), S.boulardii, and those that contained multiple organisms. Overall, we found low-strength evidence that probiotics containing only lactobacillus organisms or multiple organisms are more effective than placebo in preventing an acute episode of CDI. We found low-strength evidence that probiotics containing S.boulardii given as adjunct to standard antimicrobial therapy, are comparable with placebo in preventing an episode of CDI.

Appendix Figure G21 Single organism probiotics for prevention of CDI-associated diarrhea

Appendix Figure G21 is a forrest plot displaying data presented in Appendix Table G9 about the efficacy of single organism probiotics for the outcome prevention of CDI-associated diarrhea.

Appendix Table G9 Single organism probiotics for prevention of CDI-associated diarrhea

Study | Treatment CDI Events (percent) | Control CDI Events (percent) | Relative Risk [95% CI]
Beausoleil, 2007^78^ | 1/44 (2) | 7/45 (16) | 0.15 [0.02 to 1.14]
Gao, 2010^74^ | 9/171 (5) | 20/84 (24) | 0.22 [0.11 to 0.46]
Lonnermark, 2010^75^ | 1/80 (1) | 0/83 (0) | 3.11 [0.13 to 75.26]
Psaradellis, 2010^76^ | 1/216 (0.5) | 4/221 (2) | 0.26 [0.03 to 2.27]
Safdar, 2008^77^ | 0/23 (0) | 1/17 (6) | 0.25 [0.01 to 5.79]
Thomas, 2001^85^ | 2/133 (2) | 3/134 (2) | 0.67 [0.11 to 3.96]
Totals | 14/667 (2) | 35/584 (6) | 0.27 [0.15 to 0.49]

CI = confidence interval

Appendix Figure G22 S boulardii for prevention of CDI-associated diarrhea

Appendix Figure G22 is a forrest plot displaying data presented in Appendix Table G10 about the efficacy of s. boulardii probiotics for the outcome prevention of CDI-associated diarrhea.

Appendix Table G10 S. boulardii probiotics for prevention of CDI-associated diarrhea

Study | Treatment CDI Events (percent) | Control CDI Events (percent) | Relative Risk [95% CI]
Pozzoni, 2012^73^ | 3/141 (2) | 2/134 (1) | 1.43 [0.24 to 8.40]
Lewis, 1998^86^ | 5/33 (15) | 3/36 (8) | 1.82 [0.47 to 7.02]
Can, 2006^83^ | 0/73 (0) | 2/78 (3) | 0.21 [0.01 to 4.37]
Duman, 2005^79^ | 0/196 (0) | 1/180 (0.5) | 0.31 [0.01 to 7.47]
McFarland, 1995^87^ | 3/97 (3) | 4/96 (4) | 0.74 [0.17 to 3.23]
Surawicz, 1989^88^ | 3/116 (3) | 5/64 (8) | 0.33 [0.08 to 1.34]
Totals | 14/656 (2) | 17/588 (3) | 0.77 [0.38 to 1.54]

CI = confidence interval

Appendix Figure G23 Multi-organism probiotics for prevention of CDI-associated diarrhea

Appendix Figure G23 is a forrest plot displaying data presented in Appendix Table G11 about the efficacy of multi-organism probiotics for the outcome prevention of CDI-associated diarrhea.

Appendix Table G11 Multi-organism probiotics for prevention of CDI-associated diarrhea

Study | Treatment CDI Events (percent) | Control CDI Events (percent) | Relative Risk [95% CI]
Ouwehand, 2014^70^ | 6/336 (1.8) | 8/167 (4.8) | 0.37 [0.13 to 1.06]
Allen, 2013^71^ | 12/1493 (0.8) | 17/1488 (1) | 0.70 [0.34 to 1.47]
Hickson, 2007^82^ | 0/56 (0) | 9/53 (17) | 0.05 [0.00 to 0.84]
Plummer, 2004^84^ | 2/69 (3) | 5/69 (7) | 0.40 [0.08 to 1.99]
Selinger, 2013^72^ | 0.5/117 (0.4)^*^ | 0.5/112 (0.4)^*^ | 0.96 [0.02 to 47.84]
Totals | 20/2071 (1.0) | 39/1889 (2) | 0.50 [0.28 to 0.88]

CI = confidence interval

* Adjusted from 0 to 0.5 to facilitate analysis.