# Risk of Bias and Study Quality

## KQ1 Diagnostics

We used an updated rubric for assessing the quality of included studies (QUADAS-2). Overall, 12 of 37 studies were “low risk of bias” in all 4 QUADAS-2 domains (patient selection, index test, reference standard, and flow and timing). In keeping with the previous report, most studies that were included in this report that were not included in the original report enrolled samples from patients at risk for or with symptoms consistent with CDI. However, some studies included enrolled unformed specimens only irrespective of whether testing for CDI was requested by the patient's clinician. The clinical characteristics of the patients from whom fecal samples were obtained for inclusion in the included studies were generally not described, making determination of applicability of findings problematic. While the characteristics of patients from whom fecal specimens were obtained for inclusion in the study were often not described, most studies (26) included only unformed stools samples while two studies contained both formed and unformed specimens and nine studies did not specify whether samples were formed or unformed. Nineteen studies did not include repeat samples from a single patient, but 18 studies included more samples than patients or did not specify the number of patients.

In contrast to the previous report, we included studies that prospectively enrolled samples from a patient population with a “baseline” pre-test probability of CDI without modification of the probability of disease by a screening test. The prevalence of CDI in the studies varied widely, between 6 percent and 48 percent. While this variability may not have an impact on sensitivity and specificity, the positive and negative predictive values of included tests are not applicable to a population with different prevalence than the prevalence of CDI in an included study. Seventeen studies enrolled a random or consecutive sample of samples, 20 studies did not specify if a consecutive or random sample of patients was included, and three studies did not include a random or consecutive sample of specimens. The impact of enrolling nonconsecutive samples on the measured operating characteristics of a certain diagnostic test is unclear. We cannot exclude the possibility that a study that had a nonconsecutive sample of patients could systematically entrain bias if there were characteristics of that led to samples being included and others excluded, such as volume of stool, variability of testing practices in certain wards, or other characteristics.

Similar to the previous report, we found that there were few concerns in the conduct and interpretation of index tests with respect to risk of bias. However, there was significant heterogeneity in the studies and the source of this heterogeneity in observed operating characteristics for the included studies is not completely clear. Many studies did not apply different tests to the exact same number of patients and the reasons for these differences were not often specified. There was some variability in how invalid or inconclusive index test(s) were interpreted and if the index test(s) were repeated on invalid or inconclusive specimens. The previous report included studies with a combination of reference standards including cell cytotoxicity test, cell cytotoxicity test in conjunction with toxigenic culture, one used a toxin immunoassay in conjunction with toxigenic culture, multiple immunoassays for toxins A and B in conjunction with toxigenic culture, and in-house gene detection tests. In the current update report, we used a more stringent reference standard of the cell cytotoxicity assay, toxigenic culture, or a combination thereof. A few studies used enriched toxigenic culture as the reference standard which is likely a more sensitive reference standard that typical toxigenic culture or cytoxicity assay; the logical consequence is that index tests may appear less sensitive when compared against a more sensitive reference standard. Thirty studies used toxigenic culture as the reference standard, five studies used a composite reference standard of cell cytotoxicity assay and/or toxigenic culture, and two studies used cell cytotoxicity assays as the reference standard. Although regarded as an acceptable reference standard, toxigenic culture, cell cytotoxicity assay or a combination thereof are not perfectly accurate. In the majority of included studies the diagnostic tests were performed independently although it was usually not explicitly stated whether or not the tests were evaluated without knowledge of the other tests. However, it was inferred that most index tests (which are more rapid than the reference standards that take 24-48 hours) were interpreted prior to the results of the reference test being available.

Nineteen studies were “high risk of bias” with respect to flow and timing, mostly due to not all samples being included in the analysis. While the number of indeterminate results was generally small, small changes in a 2×2 table for a certain study can have marked changes in the calculated operating characteristics. As in the previous report, the handling of indeterminate or inconclusive results is problematic. One approach many investigators used was to exclude the inconclusive tests from the calculation of the operating characteristics of a certain test, while others repeated the index test and used the second result (if positive or negative) as the result used in the calculation of operating characteristics. The former approach may lead to an overestimation or underestimation of the sensitivity and specificity of a test depending on whether the reference standard result of the excluded samples is positive or negative. Further, this approach also may lead to the body of samples included being no longer consecutive or random. The latter approach may also lead a misestimation of the operating characteristics as the approach to inconclusive results likely varies significantly between laboratories.

Appendix Table F1 Diagnostic study quality

Author | Year | Patient Selection | Index Test | Reference Standard | Flow and Timing | Test Class Examined
Alcala, 2014^1^ | 2014 | Low | Low | Low | High | GDH, PCR
Barkin, 2012^2^ | 2012 | Low | Low | Low | High | A/B, GDH, LAMP
Bruins, 2012^3^ | 2012 | Low | Unclear | Low | Unclear | PCR, A/B, GDH, LAMP
Buchan, 2012^4^ | 2012 | Unclear | Low | Low | High | LAMP
Calderaro, 2012^5^ | 2012 | Low | Low | Low | Low | GDH, LAMP
Carroll, 2013^6^ | 2013 | Unclear | Low | Low | High | PCR
Dalpke, 2013^7^ | 2013 | Unclear | Low | Low | Low | PCR
de Boer, 2010^8^ | 2010 | Low | Low | Low | Low | PCR
de Jong, 2012^9^ | 2012 | Low | Low | Low | Low | A/B
Eckert, 2014^10^ | 2014 | Low | Low | Low | High | GDH, LAMP
Eigner, 2014^11^ | 2014 | Unclear | Low | Low | High | A/B, PCR
Herrera, 2010^12^ | 2010 | Low | Unclear | Low | Unclear | A/B
Hirvonen, 2013^13^ | 2013 | Low | Low | Low | Low | PCR
Hoegh, 2012^14^ | 2012 | Low | Low | Low | High | A/B
Humphries, 2013^15^ | 2013 | High | Unclear | High | Unclear | A/B, LAMP
Jensen, 2015^16^ | 2015 | Low | Low | Low | High | LAMP, PCR
Kim, 2012^17^ | 2012 | Low | Low | Low | High | PCR, A/B
Knetsch, 2011^18^ | 2011 | Low | Low | Low | High | PCR
Lalande, 2011^19^ | 2011 | Low | Low | Low | Low | LAMP
Landry, 2014^20^ | 2014 | Unclear | Low | Low | Low | PCR
Le Guern, 2012^21^ | 2012 | Low | Low | Low | Low | PCR
Leitner, 2013^22^ | 2013 | Low | Low | Low | Low | PCR, A/B
Mattner, 2012^23^ | 2012 | Low | Low | Low | Low | A/B
Noren, 2011^24^ | 2011 | Low | Low | Low | Low | LAMP
Noren, 2014^25^ | 2013 | Low | Low | Low | High | A/B, LAMP
Planche, 2013^26^ | 2013 | Low | High | Low | High | A/B, GDH, TA
Putsathit, 2014^27^ | 2014 | Unclear | Low | Low | High | GDH, PCR
Qutub, 2011^28^ | 2011 | Low | Low | Low | Low | GDH
Reller, 2010^29^ | 2010 | Unclear | Low | Low | Low | A/B, GDH
Rene, 2011^30^ | 2012 | Low | Low | Low | High | A/B
Shin, 2012^31^ | 2012 | Low | Low | Low | Low | PCR, A/B
Shin, 2012^32^ | 2012 | Low | Low | Low | High | PCR
Strachan, 2013^33^ | 2013 | Low | Low | Low | Low | A/B
Viala, 2012^34^ | 2012 | Low | Low | Low | High | PCR, LAMP
Walkty, 2013^35^ | 2013 | Low | Low | Low | High | A/B, GDH, LAMP, TA
Ylisiurua, 2013^35^ | 2013 | Low | Low | Low | High | PCR, A/B, LAMP
Zidaric, 2011^36^ | 2011 | Low | Low | Low | High | PCR

A/B=toxin A/B test; GDH=glutamate dehydrogenase; LAMP=loop mediated isothermal amplification; PCR-polymerase chain reaction; TA=test algorithm

## KQ2 Prevention

Appendix Table F2 Prevention study risk of bias

Author, Year Country | Study Design | Overall Summary Score | Comments
Transmission Interruption
Filice, 2013^92^ United States | Systematic review | Low | Publication bias not assessed – fewer than 10 relevant studies for CDI outcome. English language only, but focused on interventions in systems similar to the U.S.
Rupp, 2012^93^ United States | Quasi-experimental staged introduction trial, 19 months followed by 4 month wash-out | Moderate | Cohorts, not matched concurrent control. Tested for effect of compliance on change in CDI rates. Change in diagnostic testing would conservatively increase CDI rate. Limited information on regression models.
Noto, 2015^94^ United States | Pragmatic cluster randomized cross-over trial, 1 year | Moderate | Blinding not possible – outcome assessor blinded. CDI not primary outcome; unlikely powered to capture CDI rate changes.
Alfa, 2015^95^ Canada | Interrupted time series single site, 3 years prior, 1 year intervention. prospective | High | Comparator arm (separate location) not used for analysis. Did not control for increase cleaning monitoring.
Levin, 2013^96^ United States | Pre/post single site. 1 year followup | High | No concurrent control. Change in antibiotic formulary during study period.
Manian, 2013^97^ United States | Retrospective Pre/post single site. 1 year followup | High | No concurrent control
Passaretti 2013^98^ United States | Prospective cohort intervention in 3 cohorts. 1 year, 6 month followup | High | No concurrent control. No information on CDI definition.
Stone, 2012^99^ United Kingdom | Prospective, ecological, interrupted time series, 3 year followup after roll-out | Moderate | CDI incidence estimated because mandatory reporting database does not include patient age as variable. Limited information on regression models. Analysis reported evidence of selection bias- trusts missing data for soap had lower rates of CDI.
Didiodato, 2013^100^ Canada | Prospective, ecological, interrupted time series, 3 year followup | High | Limited information on regression models, imputation for missing data, limited confounding variables captured in the patient safety indicator database.
Bearman, 2010^101^ United States | Prospective pre/post single site. 6 month followup | High | No concurrent control
Multicomponent
Brakovich, 2013^102^ United States | Prospective pre/post single site design. 2 year followup | High | No concurrent control
Bishop, 2013^103^ United States | Prospective pre/post single site design. 3 year followup | High | No concurrent control
Mermel, 2013^104^ United States | Time series single site design. 6 year, 9 month followup | High | Unclear timing for data collection, switch to PCR (more sensitive test) during intervention period confounds change in CDI, limited information on regression model
Price, 2010^105^ United Kingdom | Interrupted time series single site design; 12 months pre, 15 months post. Retrospective | High | Retrospective data, no information on C. difficile diagnostic testing methods, other than no changes except for reduced from 7 to 5 days per week, limited information on regression model.
You, 2014^106^ Korea | Retrospective pre/post single site design; 9 months | High | No concurrent control

Appendix Table F3 Quality of previous systematic reviews

Study | A priori Study Design | Dual Study Selection and Data Abstraction | Comprehensive literature search | Publication Status | Lists of Included and Excluded Studies Provided? | Scientific Quality of Included Studies Assessed and Documented? | Scientific Quality of Included Studies Used Appropriately in Formulating Conclusions? | Methods of Combining Studies Appropriate? | Likelihood of Publication Bias Assessed? | Conflict of Interest Stated? | Overall Quality
Filice, 2013^92^ | yes | yes | yes | yes | yes | yes | yes | yes | Unclear | yes | good

## KQ3 Standard Treatment

Appendix Table F4 Standard treatment study risk of bias

Study ID | Design | Funding source | Overall Summary | Comments
Johnson, 2014^37^ | RCT- 3 arms, tolevamer vs.metronidazole vs. vancomycin | Genzyme (tolevamer maker) | Low risk of bias | No reason to downgrade.
Cornely, 2012^38^ | RCT- Vancomycin vs. fidaxomicin | Optimer pharmaceutical (fidaxomicin maker) | Low risk of bias | No reason to downgrade.
Wenisch, 2012^39^ | Prospective Cohort – oral metronidazole vs. IV metronidazole vs. oral vancomycin | “No financial support was received for this study” | High risk of bias | Downgraded for: “no” answers to sequence generation, allocation concealment, blinding, and other (non-RCT). Unclear for incomplete outcome data

## KQ4 Nonstandard Treatment

Appendix Table F5 FMT adjunctive treatments study risk of bias

Study Country Funding | Type of Study | Overall Risk of Bias Assessment | Rationale
Newly identified studies
Cammarota, 2015^44^ Italy Nongovernmental | Open-label RCT | High | Unblinded, stopped early, inadequate sample size, change of FMT protocol during study (decided to give multiple infusions after first 2 patients had recurrence after 1 infusion)
Satokari, 2015^45^ Finland | Retrospective review | High | Retrospective, case series
Zainah, 2015^46^ United States Funding NR | Retrospective review | High | Retrospective, case series, inadequate sample size
Dutta, 2014^47^ United States Health organization, University | Prospective | High | Case series, inadequate sample size
Khan, 2014^48^ United States Funding NR | Retrospective review | High | Retrospective, case series, inadequate sample size, CDI assessed based on symptoms only, population inclusion criteria (“recurrent CDI”) not defined
Lee, 2014^91^ Canada University | Retrospective review | High | Retrospective, case series
Ray, 2014^50^ United States Funding NR | Retrospective review | High | Retrospective, case series, inadequate sample size, lack of systematic followup (n=10/20 with 0-1 months followup)
Seekatz, 2014^51^ United States Government, foundation | Prospective | High | Case series, inadequate sample size
Weingarden, 2014^52^ United States Government, University | Observational | High | Case series, inadequate sample size, population inclusion criteria (“recurrent CDI”) not defined, adverse events not reported
Youngster, 2014^54^ United Sates Health organization | Open-label feasibility study | High | Inadequate sample size, no comparison group
Youngster, 2014^53^ United States Government, University | Open-label RCT | High | Inadequate sample size, no non-FMT comparison group, attrition
Emanuelsson, 2013^55^ Sweden No funding | Retrospective review | High | Retrospective, case series, inadequate sample size, lack of systematic followup (n=5 patients with 0-1 months follow-up)
Patel, 2013^56^ United States Funding NR | Retrospective review | High | Retrospective, case series, inadequate sample size, attrition
Pathak, 2013^57^ United States Funding NR | Retrospective review | High | Retrospective, case series, inadequate sample size
Rubin, 2013^58^ United States Health organization | Retrospective review | High | Retrospective, case series
van Nood, 2013^59^ The Netherlands Government | Open-label randomized trial | High | Unblinded, inadequate sample size (n=43 randomized, n=13-17 per arm), stopped early
Brandt, 2012^107^ United States No funding | Survey | High | Retrospective, survey design
Hamilton, 2012^60^ United States Foundation, government | Case series | High | Case series, followup not reported
Jorup-Ronstrom, 2012^61^ Sweden Funding NR | Observational | High | Retrospective, case series, inadequate sample size, outcomes not clearly defined
Kelly, 2012^62^ United States Funding NR | Case series | High | Case series, inadequate sample size, adverse events not reported
Mattila, 2012^63^ Finland Foundation | Retrospective review | High | Retrospective, case series
Mellow, 2011^64^ United States Funding NR | Observational | High | Case series, inadequate sample size, selective CDI testing
Garborg, ^65^2010^65^ Norway Funding NR | Retrospective review | High | Retrospective, case series, heterogeneous sample (confirmed or suspected CDI), lack of systematic followup
Aas, 2003^66^ United States Health organization | Retrospective review | High | Retrospective, case series, inadequate sample size, selective CDI testing
Previously identified studies
Rohlke, 2010^67^ United States No funding | Retrospective review | High | Retrospective, case series, inadequate sample size, population inclusion criteria (“recurrent CDI”) not defined, adverse events not reported
Yoon, 2010^68^ United States No funding | Case series | High | Retrospective, case series, inadequate sample size
MacConnachie, 2009^69^ United Kingdom Funding NR | Retrospective review | High | Retrospective, case series, inadequate sample size

Appendix Table F6 Probiotic adjunctive treatments study risk of bias

Study Country Funding | Overall Risk of Bias Assessment | Rationale
Newly identified randomized trials
Ouwehand, 2014^70^ China Industry | Moderate | Outcomes not clearly reported for CDI
Allen, 2013^71^ United Kingdom Government | High | Underpowered for event rate, limited followup duration
Selinger, 2013^72^ United Kingdom Industry, government | High | Underpowered for event rate, 45% did not complete study, trial stopped early due to low incidence of CDI
Pozzoni, 2012^73^ Italy Hospital | High | Possible attrition bias, selective CDI testing, underpowered for event rate
Gao, 2010^74^ China Industry | Moderate | Selective CDI testing.
Lonnermark, 2010^75^ Sweden Funding NR | High | Possible attrition bias, selective CDI testing, limited followup duration, underpowered for event rate
Psaradellis, 2010^76^ Canada Industry | High | Unclear randomization process and allocation concealment, possible attrition bias, selective CDI testing, underpowered for event rate, outcomes not reported by recurrence (heterogeneous population)
Safdar, 2008^77^ United States Industry, NR | High | Underpowered for event rate
Beausoleil, 2007^78^ Canada Industry | High | Unclear randomization process and allocation concealment, selective CDI testing, underpowered for event rate
Duman, 2005^79^ Turkey Funding NR | High | Unclear randomization process and allocation concealment, open label, possible attrition bias, underpowered for event rate
Newly identified observational study
Bakken, 2014^81^ United States Case series None | High | No comparison group.
Maziade, 2013^80^ Canada Open prospective Hospital | High | Observational design, unclear details of treatment/comparison groups
Previously identified trials
Hickson, 2007^82^ United Kingdom Foundation | High | Possible attrition bias, selective CDI testing, underpowered for event rate
Can, 2006^83^ Turkey Funding NR | High | Unclear randomization process and allocation concealment, blinding patient or assessors; possible attrition bias, underpowered for event rate
Plummer, 2004^84^ United Kingdom Funding NR | High | Unclear randomization process and allocation concealment, selective CDI testing, underpowered for event rate, outcomes not reported by carrier status (heterogeneous population)
Thomas, 2001^85^ United States Industry | High | Possible attrition bias, selective CDI testing, CDI assessment by retrospective chart review, underpowered for event rate
Lewis, 1998^86^ United Kingdom Health organization | High | Unclear randomization process and allocation concealment, unclear followup duration, underpowered for event rate
McFarland, 1995^87^ United States | High | Unclear randomization process and allocation concealment, attrition bias, underpowered for event rate
Surawicz, 1989^88^ United States Industry | High | Unclear allocation concealment, attrition bias, underpowered for event rate, outcomes not reported by carrier status (heterogeneous population)

Appendix Table F7 Other adjunctive treatments study risk of bias

Study Country Funding | Type of Study | Overall Risk of Bias Assessment | Rationale
Newly identified studies
Puri, 2015^89^ United Kingdom None | Case Series | High | No comparator
Garey 2011^90^ United States Industry | Randomized trial | High | Trial stopped early; unusually low cure rate for established comparator.
Laffan, 2011^91^ United States Industry | Randomized trial | High | Inadequate sample size