# Description and Characteristics of Included Studies

## KQ1 Diagnostics

Appendix Table E1 Included diagnostics

Appendix Table E2 Included diagnostic studies tests

## KQ2 Prevention

See Appendix G

## KQ3 Standard Treatment

Appendix Table E3 New included studies standard antibiotic treatments

## KQ4 Nonstandard Treatment

Appendix Table E4 Included studies for FMT nonstandard treatments

Appendix Table E5 Included studies for probiotic nonstandard treatments

Appendix Table E6 Included RCTs for other nonstandard treatments