# Search Strings

Search String for Diagnostics (not filtered for study design)

1. difficile.mp.
2. limit 1 to (english language and humans)
3. (animals not (humans and animals)).sh.
4. 2 not 3
5. limit 4 to (addresses or bibliography or biography or dictionary or directory or duplicate publication or editorial or interview or introductory journal article or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or portraits)
6. 4 not 5