# Analytic Frameworks

Appendix Figure A1 Framework for diagnostic testing and treatment

Appendix Figure A1 is a flow diagram illustrating the clinical path for patients with the potential to develop CDAD, from diagnostic laboratory tests, through their impact on treatment decisions, to finally implications for prevention strategies. It also locates the key questions of the review within the context of the framework. Diagnostic testing has two parts, the technical efficacy of the tests and diagnostic accuracy. After diagnostic accuracy, and treatment, and patient outcome efficacy, is prevention, a societal level efficacy measure, as the benefits of prevention of infectious disease can extend beyond the individual patient.

Appendix Figure A2 Analytic framework for CDI prevention

Figure A2 is a flow diagram illustrating the pathway of preventive strategies and practices from the target patient population of patients at risk for CDAD due to potential exposure, through intermediate outcomes, and on to clinical health outcomes.