# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CCNA: Cell cytotoxicity neutralization assay
CDI: Clostridium difficile infection
CENTRAL: Cochrane Central Register of Controlled Trials
CER: Comparative Effectiveness Review
CI: Confidence interval
FMT: Fecal microbiota transplantation
GDH: Glutamate dehydrogenase
GI: Gastrointestinal
ICTRP: International Controlled Trials Registry Platform
IDSA: Infectious Disease Society of America
IND: Investigational New Drug
KQ: Key Question
LAMP: Loop mediated isothermal amplification
MRSA: Methicillin-resistant staphylococcus aureus
NAAT: Nucleic acid amplification tests
PCR: Polymerase chain reaction
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Settings
RCT: Randomized controlled trial
RD: Risk difference
ROC: Receiver operating characteristic
RR: Risk ratio
SIP: Scientific information packet
SMD: Standard mean difference
WMD: Weighted mean difference