# Results

## Results of Literature Searches

The results of the literature search and study selection are summarized in the flow chart (Figure 4). A total of 17,146 potentially relevant citations were identified. After dual review of abstracts and titles, 16,836 articles were excluded. The remaining 310 articles underwent dual review at the full-text level and 46 studies (in 51 publications) met the inclusion criteria and were included in this report: 14 randomized controlled trials (RCTs),75-89 15 comparative observational studies,90-107 and 17 noncomparative studies.108-125 Of those, 24 studies were designed to compare one noninvasive test to another in separate patient groups and reported our primary outcomes of interest; these studies form the primary basis for our report.

Figure 4 Flow chart showing results of literature search

KQ = Key Question; RCT = randomized controlled trial

* Some studies were included in more one than one risk strata or reported outcomes for more than one comparison or test of interest.

† Noncomparative studies reporting predictive accuracy.

This figure is a flow chart that outlines the study retrieval and selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria of the report. Briefly: “A total of 17,146 potentially relevant citations were identified from database searches and other sources. After dual review of abstracts and titles, 16,850 articles were excluded. The remaining 296 articles underwent dual review at the full text level and 45 studies (in 48 publications) met the inclusion criteria and were included in this report: 13 randomized controlled trials, 14 comparative observational studies, and 18 noncomparative studies.” Of the 248 studies excluded at full-text review, the majority were excluded for the following reasons: wrong population (174), wrong outcome (38), wrong intervention (23), wrong study type (11), results stratified by test (1), and poor quality observation study for a comparison with satisfactory RCT data (1).

A total of 15 studies compared coronary computed tomography angiography (CCTA) with either usual care (4 RCTs,75,80,81,83,89 1 prospective observational,92,94 1 retrospective observational107); various functional testing (1 RCT);76 single photon emission computed tomography (SPECT) (3 RCTs,77,78,84 1 retrospective observational90); or with exercise electrocardiography (ECG) (2 RCTs,79,82 1 retrospective observational,100,106 1 administrative database102). Three studies compared SPECT with exercise ECG (2 RCTs,85,87 1 administrative database102). A total of four studies compared stress echocardiography with either exercise ECG (1 RCT,86 1 prospective observational,96 1 administrative database102) or SPECT (1 administrative database).102 Only one prospective registry was identified that investigated positron emission tomography (PET) scanning which was compared with SPECT.93,95 No comparative studies of magnetic resonance imaging (MRI) or calcium scoring that met our inclusion criteria were found. CCTA was only anatomic test for which we found comparative data. No other relevant test comparisons were identified. A list of included studies can be found in Appendix B.

A total of 259 articles that did not meet one or more of the inclusion criteria were excluded after full-text review. Appendix C provides a list of these articles with reasons for exclusion (also see Figure 4. The primary reason for exclusion (70% of citations) was that studies did not include the population of interest (i.e., no known history of coronary artery disease [CAD]).

## Organization of Results

Given the heterogeneity in how pretest risk was measured and defined across the studies (see Appendix Tables E44-45 for details), results could not be reported as delineated by the Key Questions into distinct pretest risk groups (i.e., low-risk and intermediate-to-high risk). Therefore, the results were organized by pretest risk as defined by the study authors, which included populations with low risk, intermediate risk, low to intermediate risk, intermediate to high risk, high risk, and mixed risk (or pretest risk not reported). Studies describing high pretest risk excluded patients with acute coronary syndrome (ACS) and were interpreted as representing the higher risk end of the intermediate pretest risk range. Available data from studies conducted in emergency departments (EDs) were primarily for the index ED visit and are noted. Outcomes such as myocardial infarction (MI) at the time of the ED index visit were considered to reflect diagnosis of MI at that time. Where available, data on longer-term followup are presented. An overview of tests compared for the various pretest risk groups is found in Table 7.

Table 7 Overview of test comparisons and pretest risk groups for which the comparisons were made

Comparator | Pretest Risk Groups With Usual Care Comparisons | Pretest Risk Groups With CCTA Comparisons | Pretest Risk Groups With SPECT Comparisons | Pretest Risk Groups With Stress ECG Comparisons | Pretest Risk Groups With Functional Testing Comparisons | Pretest Risk Groups With Stress Echocardiography Comparisons | Pretest Risk Groups With Nuclear MPI Comparisons
Usual care | N/A | - Low; - Intermediate; - Low to intermediate; - Intermediate to high; - High (non-ACS); - Mixed population | No comparison | No comparison | No comparison | No comparison | No comparison
CCTA | - Low; - Intermediate; - Low to intermediate; - Intermediate to high; - High (non-ACS); - Mixed population | N/A | - Intermediate; - Low to intermediate; - Intermediate to high; - Mixed population | - Low; - Intermediate; - Low to intermediate; - Intermediate to high; - Mixed population | - Intermediate | - Mixed population | - Mixed population
SPECT | No comparison | - Intermediate; - Low to intermediate; - Intermediate to high; - Mixed population | N/A | Intermediate High (non-ACS) Mixed population | No comparison | No comparison | No comparison
Stress ECG | No comparison | - Low; - Intermediate; - Low to intermediate; - Intermediate to high; - Mixed population | - Intermediate; - High (non-ACS); - Mixed population | N/A | No comparison | - Mixed population | - Mixed population
Functional Testing | No comparison | - Intermediate | No comparison | No comparison | N/A | No comparison | No comparison
Stress Echocardiography | No comparison | - Mixed population | No comparison | - Mixed population | No comparison | N/A | - Mixed population
Nuclear MPI | No comparison | - Mixed population | No comparison | - Mixed population | No comparison | - Mixed population | N/A

ACS = acute coronary syndrome; CCTA = coronary computed tomography angiography; ECG = electrocardiography; MPI = myocardial perfusion imaging; N/A = not applicable; SPECT = single-photon emission computed tomography

For each section, within the specified pretest risk categories, key points were presented followed by detailed information from evidence synthesis for the following test comparisons, presented in this order: anatomic testing (CCTA or calcium scoring via CT) versus usual care; functional testing versus functional testing (any combination of the following: stress echocardiography, stress ECG, stress echocardiography, SPECT, PET, or MRI); and anatomic testing versus functional testing (any comparison of tests from the previously described categories). Following a brief description of the study populations, detailed results are reported in terms of clinical outcomes, clinical management outcomes, harms of index and additional testing, and differential effectiveness or safety in subgroups. Limited evidence from noncomparative studies reporting on predictive accuracy is included at the end of each risk category only for tests for which no or little comparative data were available.

## Low Pretest Risk of Coronary Artery Disease

### Key Points

Given the focus of the report on evaluation of testing based on pretest risk, results for the low pretest risk groups are presented here even though evidence from these groups was rated as insufficient.

#### CCTA Versus Usual Care

- In a small subgroup of low-risk patients presenting to the ED, there was insufficient evidence from one fair-quality trial to draw conclusions regarding differences between CCTA and usual care in all-cause mortality or hospitalization for acute coronary syndrome through 30 days. At the index ED visit, frequency of ICA referral and revascularization was similar (insufficient evidence).

#### SPECT Versus Exercise ECG

- In a small subgroup of low-risk outpatients, there was insufficient evidence from one fair-quality trial that SPECT patients had less additional noninvasive stress testing than exercise ECG patients through a mean of 22 months. SPECT patients were slightly more likely to have ICA referral through the same followup period (insufficient evidence), although the difference was not statistically significant.

### Detailed Synthesis

A total of five studies were identified in populations with a low pretest risk of CAD and two included the following comparisons: CCTA versus usual care (1 RCT)75 and SPECT versus exercise ECG (1 RCT)85 (Table 8); three additional noncomparative studies (4 publications) reported on the predictive accuracy of stress echocardiography.108,113,118,119

Table 8 Summary of findings and strength of evidence: Low pretest risk

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | CCTA vs. usual care^†^ | 1 RCT (n=99 in low-risk subgroup) | ED | No deaths through 1 month in either group. Definitive conclusions are not possible.^‡^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. usual care^†^ | 1 RCT (n=99 in low-risk subgroup) | ED | Similar frequency of referral (CCTA 6% vs. usual care 10%) at index visit (RD -4, 95% CI -15 to 7 per 100 people, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient
Invasive Coronary Angiography Referral | SPECT vs. exercise ECG | 1 RCT (n=68 in low-risk subgroup) | Outpatient | Somewhat more common following SPECT (7%) vs. exercise ECG (0%) through a mean of 22 months (RD 7 per 100 people, p=0.0690). Definitive conclusions are not possible.^‡^ | Insufficient
Revascularization | CCTA vs. usual care^†^ | 1 RCT (n=99 in low-risk subgroup) | ED | Revascularization at the index visit was similar between CCTA (6%) and usual care (2%) (RD 4, 95% CI -4 to 12 per 100 people, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient
Additional Testing | SPECT vs. exercise ECG | 1 RCT (n=68 in low-risk subgroup) | Outpatient | SPECT was associated with less subsequent stress testing with imaging than exercise ECG through a mean of 22 months (0% vs. 14%, respectively) (RD -14, 95% CI -24 to -4 per 100 people). Definitive conclusions are not possible.^‡^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. usual care^†^ | 1 RCT (n=99 in low-risk subgroup) | ED | Hospitalization for ACS was similar for CCTA and usual care groups (4% vs. 2%). Definitive conclusions are not possible.^‡^ | Insufficient

ACS = acute coronary syndrome; CCTA = coronary computed tomography angiography; CI = confidence interval; ECG = electrocardiography; ED = emergency department; NS = not statistically significant; RCT = randomized controlled trial; RD = risk difference; SPECT = single-photon emission computed tomography

* Primary outcomes not listed in this table had no evidence, and thus insufficient strength of evidence.

† Usual care consisted of a conventional diagnostic strategy using serial ECGs and cardiac biomarkers.

‡ Definitive conclusions are not possible because of lack of data from subgroup analyses in RCTs.

#### Anatomic Tests Versus Usual Care

##### CCTA Versus Usual Care

One fair-quality trial compared CCTA with usual care in low-risk patients (see Appendix E and G for details); no other studies compared anatomical testing with usual care in this population. The trial enrolled 266 patients presenting with chest pain to a single ED in South Korea.75 Study funding was not reported. Results were stratified based on pretest risk, with 99 of the 266 patients at low pretest risk. CCTA was performed with 64-slice scanning in 50 low-risk patients; usual care consisted of a conventional diagnostic strategy (e.g., serial ECGs, and cardiac biomarkers) and was used in 49 low-risk patients. Subsequent diagnostic tests were done at the discretion of the treating physician. Overall, groups were similar in age (mean 57.5 years), sex (38.7% female), and cardiac risk factors, however these characteristics were not compared for low-risk patients only. Methodological shortcomings included unclear randomization method, allocation concealment, and blinding of outcomes assessment.

###### Clinical Outcomes

No deaths occurred in either group through 1 month of followup; MI occurred at a similar rate between groups at the index visit (4% in both groups).75 The frequency of hospital admissions at the index visit was similar between groups in terms of those for acute coronary syndrome (6% in both groups) and total admissions (14% for CCTA vs. 16% for usual care). Patients in the CCTA group were less likely to have an unnecessary hospital admission at the time of the index visit (0% vs. 6%), though this result did not achieve statistical significance (risk difference [RD] -6, 95% confidence interval [CI] -13 to 0.6 per 100 people). Clinical outcomes based on test results were not reported.

###### Clinical Management

ICA referral at the index visit was similar following CCTA versus usual care (6% vs. 10%, RD -4, 95% CI -15 to 7 per 100 people), as was revascularization (6% vs. 2%, RD 4, 95% CI -4 to 12 per 100 people).75 Noninvasive stress testing was done in 80 percent of usual care patients but data on noninvasive stress testing were not reported for the CCTA group. Revascularization at the index visit was similar between CCTA and usual care groups (6% vs. 2%, RD 4, 95% CI -4 to 12 per 100 people).

###### Harms of Index Test and Consequences of Index and Additional Testing; Differential Effectiveness or Safety in Subgroups

Not reported for low-risk patients.

#### Functional Tests Versus Functional Tests

##### SPECT Versus Exercise ECG

One fair-quality trial compared SPECT with exercise ECG in low-risk patients (see Appendix E and G for details); no other studies compared different types of functional testing in this population.85 The trial included 457 patients referred for stable chest pain to a single outpatient center in the United Kingdom; funding grants were received from Bristol-Myers Squibb and Northwick Park Cardiac Research, as well as from an individual. Results were stratified based on pretest risk; 71 patients had low pretest likelihood of CAD. Patients underwent either SPECT (n=27) or exercise ECG (n=44). Treadmill exercise was employed in both groups; pharmacological stress was employed in some patients receiving SPECT. Groups were similar overall in age (mean age 59 years), sex (43.5% female), and cardiac risk factors, but these characteristics were not compared within the low-risk group. Patients were followed for a mean of 22 months; loss-to-followup was not reported. Methodological shortcomings included unclear randomization method, allocation concealment, and blinding of outcomes assessment.

###### Clinical Outcomes

Not reported for low-risk patients.

###### Clinical Management

SPECT recipients had a slightly higher frequency of ICA referral compared with exercise ECG over a mean of 22 months followup in low-risk patients (7% vs. 0%), although the difference did not achieve statistical significance (RD 7 per 100 people, p=0.07). This trial used Bayesian methods to model post-test risk and reported that 86 percent of those with low pretest risk finished with low post-test risk (SPECT 78% vs. ECG 91%) and that those with a normal or low-risk test in either arm did not receive ICA. SPECT was associated with less additional imaging than was exercise ECG (0 vs. 13.6%, RD -14 per 100 people, 95% CI -24 to -4). Medication therapy based on the initial test was statistically similar between SPECT and exercise ECG patients (92.6% vs. 86.3%, RD 6, 95% CI -8 to 20 per 100 people).

###### Harms of Index Test and Consequences of Index and Additional Testing; Differential Effectiveness or Safety in Subgroups

Not reported for low-risk patients.

#### Noncomparative Studies: Functional

No noncomparative studies of anatomical testing in patients at low risk met the inclusion criteria that reported outcomes of interest. For functional testing in this population, only studies of stress echocardiography were identified.

##### Stress Echocardiography

Three noncomparative studies of stress echocardiography in low pretest risk patients reported on predictive accuracy, two of which were conducted in an ED setting. Stressors included exercise or dobutamine in one trial118,119 and two used exercise only.108,113 Study sizes ranged from 149 to 1618 patients. In terms of test-positive patients, cardiac events occurred in no patients through 6 months in one ED study, and in 3 to 5 percent of patients through a median of 36 months (outpatient setting) or a mean of 54 months (ED setting) followup, respectively. The frequency of any cardiac event in those who tested negative was 1 per 100 people in all studies (see Appendix F for details).

## Intermediate Pretest Risk of Coronary Artery Disease

### Key Points

Evidence for all primary outcomes and comparators not listed was insufficient to draw conclusions because of study limitations and/or imprecision in the observational study or because of lack of evidence.

#### CCTA Versus Usual Care

- In intermediate-risk patients presenting to the ED, there was low-strength evidence from two fair-quality trials that patients in the CCTA and usual care groups had similar mortality, MI, any revascularization, PCI, CABG, or additional testing at the index ED visit and through 28 to 30 days. ICA referral was also similar at the index visit and after the index visit through 28 days (low strength of evidence).

#### SPECT Versus Exercise ECG

- In intermediate-risk women (setting not reported) groups were similar with respect to mortality, ICA referral, revascularization, and hospitalization through 24 months based on one fair-quality trial (low strength of evidence). However, moderate-strength evidence from this trial suggested that SPECT is associated with less additional noninvasive testing than exercise ECG.
- A second fair-quality trial on the general population reported that in a subgroup of intermediate-risk outpatients, SPECT was associated with fewer referrals to ICA (low strength of evidence) and additional stress testing (low strength of evidence) through a mean of 22 months of followup.
- Differences in patient characteristics between the two trials may partially explain differences in findings; one trial was comprised of women with a mean age of 63 years who were able to perform ≥5 METS on the Duke Activity Status Index. Findings from the other trial were based on subanalysis of intermediate-risk patients from a general population of >50 percent men with mean age of 59 years old with any activity ability.

#### CCTA Versus Functional Testing

- In intermediate-risk outpatients, moderate-strength evidence suggested that all-cause mortality, nonfatal MI, and cardiac hospitalizations were similar between groups through 12 months and a median of 25 months based on one good-quality trial. There was high-strength evidence that CCTA was associated with more ICA referrals and revascularizations (including CABG and PCI evaluated separately) through 90 days. Major procedural complications were similar between groups (moderate strength of evidence).

#### CCTA Versus SPECT

- In a fair-quality trial of 400 intermediate-risk patients admitted to a telemetry ward, low strength evidence suggested that there is no difference between CCTA and SPECT groups in all-cause mortality through a median of 24.5 months or in 12-month ICA referral, additional testing, revascularization, or PCI. However, CABG was more common following CCTA versus SPECT through 12 months and cardiac rehospitalization occurred in fewer CCTA versus SPECT patients through a median of 40.4 months, although the difference did not achieve statistical significance (low strength of evidence). No major complications were attributed to the imaging procedure; 30-day death, MI, and stroke were not reported. The composite of periprocedural chest pain, shortness of breath, or palpitations occurred in significantly fewer CCTA versus SPECT patients, while there were no differences between groups in minor adverse reactions (including headache, nausea, dizziness, or feeling of warmth) or in rash or pruritus. There were no cases of post-test renal dysfunction (low strength of evidence).

### Detailed Synthesis

A total of nine studies were identified in populations with an intermediate pretest risk of CAD and seven (9 publications) included the following comparisons: CCTA versus usual care (2 RCTs,75,80,89 1 prospective observational study92,94), CCTA versus various functional testing (1 RCT),76 CCTA versus SPECT (1 RCT),88 and SPECT versus exercise ECG (2 RCTs)85,87 (Table 9); two additional noncomparative studies reported on the predictive accuracy of coronary artery calcium scoring (CACS).123,125

Table 9 Summary of findings and strength of evidence: Intermediate pretest risk

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | CCTA vs. usual care^†^ | 2 RCTs (N=1098)^‡^ 1 observational study (N=200) | ED | There is low-strength evidence that a difference in mortality was not found. At ED visit through 28 to 30 days, there were no deaths in either group (2 RCTs). Through 3 months followup, there were no deaths in either group (observational study). | Low
Mortality (all-cause) | SPECT vs. exercise ECG | 1 RCT (N=824 women) | NR | There is low-strength evidence that a difference in mortality was not found. Through 24 months, overall mortality was similarly low in both groups (1.0% vs. 0.5%). | Low
Mortality (all-cause) | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | Mortality was similar between the CCTA and functional testing groups through 12 months (0.42% vs. 0.64%) and a median of 25 months (1.48% vs. 1.50%) followup. | Moderate
Mortality (all-cause) | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | There is low-strength evidence that a difference in mortality was not found through a median of 24.5 months (0.5% vs. 3.0%, RD -2.5, 95% -5.1 to 0.06 events per 100 people). | Low
Myocardial Infarction | CCTA vs. usual care^†^ | 2 RCTs (N=1098)^‡^ 1 observational study (N=200) | ED | Strength of evidence is low that a difference in diagnosis of MI was not found (2.3% vs. 3.6%, pooled RD -1, 95% CI -3 to 0 events per 100 patients, I^2^=0%) (2 RCTs) at the index ED visit; or after index visit through 28 days (0.2% vs. 0.8%, RD -0.6, 95% CI -1.5 to 0.3 events per 100 people) in one trial (N=987). The observational study reported no MIs in either group through 3 months followup. | Low
Myocardial Infarction | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | Nonfatal MI was similarly rare between groups through 12 months (0.36% vs. 0.54%, RD -0.18, 95% -0.44 to 0.08 per 100 people) and a median of 25 months (0.60% vs. 0.80%, RD -0.20, 95% CI -0.53 to 0.13 per 100 people). | Moderate
Heart Failure | CCTA vs. usual care^†^ | 1 observational study (N=200) | ED | Through 3 months followup, there was no development or worsening of heart failure that required hospitalization in either group. Definitive conclusions are not possible.^§^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. usual care^†^ | 2 RCTs (N=1098)^‡^ | ED | At the index visit, ICA referral was similar in the testing groups (13.8% vs. 11.2%, RD 3, 95% CI 0 to 7 per 100 patients, I^2^=0%, p=NS). Through 28 days followup (after the index visit), there was no difference between groups (1.0% vs. 0.8%) in one RCT (N=987). | Low
Invasive Coronary Angiography Referral | SPECT vs. exercise ECG | 2 RCTs (N=824 women in one trial; n=280 in intermediate-risk subgroup in other trial) | NR (trial of women) Outpatient (general population) | One trial of women only reported identical referral rates for ICA in both groups (6%) through 24 months. The other trial (general population) found that SPECT was associated with a significantly lower risk of ICA (10.6% vs. 43.1%, RD -32, 95% CI -43 to -22 per 100 people) through a mean of 22 months followup. | Low
Invasive Coronary Angiography Referral | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | ICA within 90 days was significantly more common in the CCTA group than the functional testing group (12.19% vs. 8.11%, RD 4.08, 95% CI 2.90 to 5.26 per 100 people). | High
Invasive Coronary Angiography Referral | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | ICA within 12 months was similar between the CCTA and SPECT groups (15.0% vs. 16.0%, RD 1.0, 95% CI -8.1 to 6.1 events per 100 people). | Low
Revascularization | CCTA vs. usual care^†^ | 2 RCTs (N=1098)^‡^ | ED | At the index visit, revascularization was similar between CCTA (7.2%) and usual care(5.6%) (pooled RD 2, 95% CI -1 to 5 per 100 patients, I^2^=0%) (2 RCTs). | Low
Revascularization | SPECT vs. exercise ECG | 1 RCT (N=824 women) | NR | Similar over 24 months of followup in the SPECT (2.0%) and exercise ECG groups (1.0%) in one trial of women only (RD 1.1, 95% CI -0.7 to 2.8 per 100 patients). | Low
Revascularization | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | Significantly more CCTA patients underwent revascularization within 90 days than functional testing patients (6.22% vs. 3.16%, RD 3.07, 95% CI 2.24 to 3.90 per 100 people). | High
Revascularization | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | No difference in revascularization rates through 12 months between CCTA and SPECT groups (7.5% vs. 6.0%, RD 1.5, 95% CI -3.4 to 6.4 events per 100 patients). | Low
Percutaneous Coronary Intervention | CCTA vs. usual care^†^ | 1 RCT (N=987) 1 observational study (N=200) | ED | Similar rates of PCI at the index ED visit (5% vs. 3%) (1 RCT), through 28 days (0.6% vs. 0.6%) (1 RCT), and through 3 months (9% vs. 15%) (1 observational study). | Low
Percutaneous Coronary Intervention | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | More common following CCTA vs. functional testing through 90 days (4.8% vs. 2.4%, RD 2.4, 95% CI 1.7 to 3.1 per 100 people). | High
Percutaneous Coronary Intervention | CCTA vs. SPECT | 1RCT (N=400) | Telemetry | No difference in PCI rates through 12 months between CCTA and SPECT groups (4.0% vs. 5.5%, RD -1.5, 95% CI -5.7 to 2.7 events per 100 patients). | Low
Coronary Artery Bypass Graft | CCTA vs. usual care^†^ | 1 RCT (N=987) 1 observational study (N=200) | ED | Similar between groups at the index visit (1% in both groups) (1 RCT), through 28 days (0% in both groups) (1 RCT), or through 3 months (1% vs. 2%) (1 observational study). | Low
Coronary Artery Bypass Graft | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | More common following CCTA vs. functional testing through 90 days (1.44% vs. 0.76%, RD 0.68, 95% CI 0.27 to 1.09 per 100 people). | High
Coronary Artery Bypass Graft | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | CABG was more common following CCTA vs. SPECT through 12 months (3.5% vs. 0.5%, RD 3.0, 95% CI 0.3 events to 5.7 per 100 people). | Low
Additional Testing | CCTA vs. usual care^†^ | 1 RCT (N=987) | ED | Through 28 days (and after the index visit) similar frequency of additional noninvasive testing: SPECT (1.6% vs. 1.8%); stress echocardiography (0% in both groups) or exercise treadmill testing (2% vs. 3%). | Low
Additional Testing | SPECT vs. exercise ECG | 2 RCTs (N=824 women in one trial; n=280 in intermediate-risk subgroup in other trial) | NR (trial of women) Outpatient (general population) | SPECT was associated with a significantly lower risk of additional noninvasive testing in both trials; this included stress testing with or without imaging in one RCT of women only (9.4% vs. 18.6%; RD -9, 95% CI -14 to -4 per 100 people). The other trial reported additional stress testing in no SPECT patients and 38% of exercise ECG patients (RD -38, 95% CI -48 to -29 per 100 people). | Moderate (trial of women) Low (subgroup of general population)
Additional Testing | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | Additional noninvasive testing was performed in 22.5% of patients in both the CCTA and SPECT groups (RD 0, 95% CI -8.2 to 8.2 events per 100 patients), and included myocardial perfusion imaging (15.0% vs. 13.0%), stress echocardiography (6.5% vs. 7.0%), and CCTA (1.0% vs. 2.5%). | Low
Hospitalization (Cardiac related) | CCTA vs. usual care^†^ | 1 RCT (N=987) 1 observational study (N=200) | ED | Strength of evidence is low that hospitalizations were similar at the time of ED index visit (pooled RD -22, 95% CI -47 to 2 per 100 patients, I^2^=85.1%); the larger trial (N=987) found fewer hospitalizations with CCTA vs. usual care(51.9% vs. 82.3%, RD -33, 95% CI -39 to -28 per 100 patients) but the smaller trial (N=111) found no difference between groups. The observational study found that through 3 months, hospitalization for recurrent chest pain was similar (0% vs. 3%, RD -3, 95% CI -6 to 0.3 per 100 patients, p=NS). | Low
Hospitalization (Cardiac related) | SPECT vs. exercise ECG | 1 RCT (N=824 women) | NR | Through 24 months, hospitalization for chest pain was similarly low between groups (3.9% vs. 3.1%, RD 0.8, 95% CI -1.8 to 3.4). | Low
Hospitalization (Cardiac related) | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | Through a median of 25 months, no difference was found between groups in the risk of cardiac hospitalization (1.22% vs. 0.92%, RD -0.30, 95% CI -0.10 to 0.71 per 100 people), and hospitalization for unstable angina was similar but significantly more common in CCTA patients (1.22% vs. 0.82%, RD 0.40, 95% CI 0.01 to 0.80 per 100 people). | Moderate
Hospitalization (Cardiac related) | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | Cardiac rehospitalization occurred in fewer CCTA vs. SPECT patients through a median of 40.4 months, although the difference did not achieve statistical significance (25.0% vs. 31.0%, RD -5.5, 95% CI -14.3 to 0.03 events per 100 people) | Low
Harms of the Index Test | CCTA vs. functional testing | 1 RCT (N=10,003) | Outpatient | For major procedural complications, there were no differences between groups (procedural stroke (0.02% vs. 0.04%); major bleeding (0.1% in both groups); no cases of anaphylaxis or renal failure requiring dialysis). Overall, minor side effects (e.g., stress-induced symptoms, mild contrast reactions) occurred at a similar rate between groups although the difference was statistically significant (0.74% vs. 0.42%, RR 1.77, 95% CI 1.05 to 3.01). | Moderate
Harms of the Index Test | CCTA vs. SPECT | 1 RCT (N=400) | Telemetry | No major complications were attributed to the imaging procedure; 30-day death, MI, and stroke were not reported. The composite of periprocedural chest pain, shortness of breath, or palpitations occurred in significantly fewer CCTA vs. SPECT patients (0.5% vs. 15.9%, RD -15.4, 95% CI -20.8 to -10.1 per 100 people), while there were no differences between groups in minor adverse reactions (including headache, nausea, dizziness, or feeling of warmth) (24.2% vs. 24.5%) or in rash or pruritus (1.6% vs. 0%, p=0.25). There were no cases of post-test renal dysfunction | Low

CABG = coronary artery bypass graft; CCTA = coronary computed tomography angiography; CI = confidence interval; ECG = electrocardiography; ED = emergency department; ICA = invasive coronary angiography; MI = myocardial infarction; NS = not statistically significant; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; RD = risk difference; RR = relative risk; SPECT = single photon emission computed tomography

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Usual care varied by study and included consisted of the standard evaluation strategy used at each ED (1 RCT), a conventional diagnostic strategy using serial ECGs and cardiac biomarkers (1 RCT), and repeated biomarker measurements, stress testing (e.g., exercise ECG, stress echocardiography, SPECT), and clinical observation (observational study).

‡ Number of patients includes the 987 patients in the Hoffman trial and the subset of 111 patients who were at intermediate pretest risk in the Chang trial.75,80

§ Definitive conclusions are not possible because of study limitations and/or imprecision in observational studies.

#### Anatomic Tests Versus Usual Care

##### CCTA Versus Usual Care

Two fair-quality trials compared CCTA with usual care in patients with intermediate pretest risk (see Appendix E and G for details);75,80 an additional publication from one of these trials evaluated possible modification by sex.89 One large trial (ROMICAT-II) enrolled 1,000 intermediate-risk patients with chest pain across nine EDs in the United States.80 The trial was funded by grants from the National Institutes of Health and from the National Heart, Lung, and Blood Institute. Patients underwent testing with 64-slice (or higher) CCTA (n=501) or usual care (n=499) which employed the standard evaluation strategy used at each ED. One trial of chest pain patients presenting to a single ED in South Korea stratified results according to pretest risk; 111 (of 266 total) patients were categorized as having intermediate pretest probability of ACS.75 Study funding was not reported. Patients were tested with 64-slice CCTA (n=55) or usual care (n=56) which consisted of a conventional diagnostic strategy using serial ECGs and cardiac biomarkers. Subsequent diagnostic tests were done at the discretion of the treating physician. Within each trial, the CCTA and usual care groups were similar in age, sex, and cardiac risk factors. However, the two trials differed somewhat in overall patient characteristics. The study by Chang et al. 2008 included slightly older patients (mean age 58 vs. 54 years), more males (61% vs. 53%), and fewer people with hypertension (44% vs. 54%) or dyslipidemia (27% vs. 45%) compared with the Hoffman et al. 2012 study. Neither study provided a baseline risk score for their population. Methodological shortcomings included unclear randomization method and allocation concealment (Chang et al. 2008), lack of a prespecified definition of a positive test (Hoffmann 2012, et al.), and unclear blinding of outcomes assessment (both trials).

One poor-quality prospective observational study compared CCTA with usual care in 200 patients at intermediate pretest risk (according to the Thrombolysis in Myocardial Infarction [TIMI] risk score; scores/mean not reported), with relevant results published in two separate papers.92,94 The study was conducted in a single ED in Germany; funding was not reported. Patients received CCTA testing (n=100) or usual care (n=100) to include repeated biomarker measurements, stress testing (e.g., exercise ECG, stress echocardiography, SPECT), and clinical observation. Patients in the CCTA group were younger (mean age 58 vs. 66 years) and more likely to be female (48% vs. 39%) than those in the usual care group; cardiac risk factors were similar between groups. Methodological shortcomings included unclear blinding of outcomes assessment and lack of controlling for baseline differences between groups.

###### Clinical Outcomes

No deaths were reported in either of the two trials during the 1-month followup periods. MI diagnosis at the index visit occurred with similar frequency in CCTA and usual care patients across both trials (2.3% vs. 3.6%, pooled RD -1, 95% CI -3 to 0 events per 100 patients, I^2^=0%) (Figure 5).75,80 After the index visit and through 28 days of followup, one trial also found that MI was similar in both CCTA (0.2%) and usual care groups (0.8%) (RD -0.6, 95% CI -1.5 to 0.3 events per 100 people).80 Across both trials, diagnosis with unstable angina at the index visit was more common in the CCTA group (9.0%) compared with the usual care group (5.4%) (pooled RD 4, 95% CI 1 to 6 per 100 people, I^2^=0%) (Figure 6).75,80 Through 28 days followup (and after the index visit), one trial reported similar incidences of unstable angina requiring PCI (0.2% vs. 0.4%; RD -0.2, 95% CI -0.9 to 0.5 per 100 people).80 In the smaller trial, hospital admission for acute coronary syndrome at the time of the index ED visit was similar between the CCTA and usual care groups (36% vs. 32%, RD 4, 95% CI -13 to 22 per 100 patients).75 The larger trial found that CCTA was associated with significantly fewer hospitalizations at the index visit compared with usual care (51.9% vs. 82.3%, RD -33, 95% CI -39 to -28 per 100 patients),80 but the smaller trial found no difference between groups (RD -8, 95% CI -27 to 10 per 100 patients).75 Considerable statistical heterogeneity across the studies for the pooled estimate (RD -22, 95% CI -47 to 2 per 100 patients, I^2^=85.1%) was noted and may in part result from differences in patient characteristics between the two studies as well as available sample size in one trial (Figure 7).75,80 The smaller trial found that CCTA was associated with fewer unnecessary hospital admissions (defined as an admission for a medical condition that should not have led hospitalization) compared with usual care (4% vs. 20%, RD -16, 95% CI -28 to -4 per 100 patients).75 Admittance to the observation unit at the index visit was significantly less common in the CCTA group (31%) versus the usual care group (60%), with 30 fewer patients per 100 being admitted (95% CI -36 to -24 per 100).80

Figure 5 Meta-analysis results for risk of myocardial infarction across studies comparing CCTA with usual care in patients with intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

* Subgroup of intermediate-risk patients.

This figure is a forest plot that displays risk of myocardial infarction (MI) across studies comparing coronary computed tomography angiography with standard of care in patients with intermediate pretest risk. The risk of MI was similar in both groups at the index visit as reported by two trials (pooled risk difference [RD] -1, 95% CI -3 to 0 events per 100 patients, I2=0%), and after the index visit through 30 days as reported by one trial (RD -0.6, 95% CI -1.5 to 0.3 events per 100 patients).

Figure 6 Meta-analysis results for risk of unstable angina across studies comparing CCTA with usual care in patients with intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

* Diagnosis of unstable angina was more common following CCTA.

† Subgroup of intermediate-risk patients.

This figure is a forest plot that displays risk for unstable angina across studies comparing coronary computed tomography angiography (CCTA) with standard of care (SOC) in patients with intermediate pretest risk. The risk for unstable angina at the index visit was more common in the CCTA group compared with the SOC group as reported by two trials (pooled risk difference [RD] 4, 95% CI 1 to 6 per 100 patients, I2=0%). After the index visit through 30 days followup, no difference in unstable angina requiring percutaneous coronary intervention was found between groups as reported in one trial (RD -0.2, 95% CI -0.9 to 0.5 per 100 patients).

Figure 7 Meta-analysis results for risk of hospital admission across studies comparing CCTA with usual care in patients with intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

* The large study (Hoffmann et al. 2012) showed significantly less hospitalization following CCTA testing.

† Subgroup of intermediate-risk patients.

This figure is a forest plot that displays risk for hospital admission across studies comparing coronary computed tomography angiography (CCTA) with standard of care in patients with intermediate pretest risk. The risk for hospitalization at the index visit appeared to be greater for the CCTA group as reported by two trials; however, the risk up to 30 days followup showed no difference between the two groups as reported by one trial. The pooled risk for hospital admission was heterogenous between the two included studies (RD -22, 95% CI -47 to 2 per 100 patients, I2=85.1%), which may be due in part to differences in patient characteristics between the two trials and the differences in available sample size in one trial.

The single observational study reported no major adverse cardiovascular events in either group through 3 months followup, including death, MI, unstable angina requiring hospitalization, or development or progression of heart failure requiring hospitalization.92,94 The study reported that hospitalization for recurrent chest pain was slightly less frequent in CCTA versus usual care patients (0% vs. 3%, RD -3, 95% CI -6 to 0.3 per 100 patients) through the 3-month followup period.

###### Clinical Management

Referral to ICA at the index visit occurred with similar frequency in the CCTA group compared with the usual care group based on data from both trials (13.8% vs. 11.2%, RD 3, 95% CI 0 to 7 per 100 patients, I^2^=0%) (Figure 8),75,80 as well as during the 28-day period following the index visit in the larger trial (1.0% for CCTA vs. 0.8% for usual care).80 The latter trial reported that patients receiving CCTA testing were significantly less likely to receive any of three types of stress testing at the index ED visit compared with the usual care group: SPECT (10% vs. 25%, RD -15, 95% CI -19 to -10 per 100 patients); stress echocardiography (4% vs. 20%, RD -16, 95% CI -20 to -13 per 100 people); or exercise treadmill testing (2% vs. 29%, RD -27, 95% CI -31 to -23 per 100 patients). The protocol of that trial called for stress testing only as a second test in the CCTA group, but as the first test in the usual care group. In the 28 days after the index ED visit, percentages of patients in the CCTA and usual care groups who received these noninvasive stress tests were similar: SPECT (1.6% vs. 1.8%), stress echocardiography (0% in both groups), or exercise treadmill testing (2% vs. 3%). In the smaller trial, 50 percent of intermediate-risk usual care patients underwent additional stress testing at the time of the index ED visit, however this data was not reported for intermediate-risk CCTA patients.75 Revascularization (PCI or CABG) at the index visit was similar between the CCTA (7.2%) and usual care (5.6%) groups at the time of the index ED visit compared with the usual care group based on data from both trials (RD 2, 95% CI -1 to 5 per 100 patients, I^2^=0%) (Figure 9).75,80 One trial similarly reported comparable proportions of patients who had PCI at the index visit (5.0% vs. 2.8%, RD 2.0, 95% CI -0.3 to 4.3 per 100 patients) and through 28 days of followup after the index ED visit (0.6% in both groups); CABG was performed in 1.0 percent of patients in both groups at the index visit and no patients in either group received CABG during the followup period.80

Figure 8 Meta-analysis results for risk of invasive coronary angiography across studies comparing CCTA with usual care in patients with intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

* Subgroup of intermediate-risk patients.

This figure is a forest plot that displays risk of invasive coronary angiography (ICA) across studies comparing coronary computed tomography angiography (CCTA) with standard of care (SOC) in patients with intermediate pretest risk. The risk for ICA at index was slightly more common in the CCTA group compared with the SOC group based on two studies (RD 3, 95% CI 0 to 7 per 100 patients, I2=0%). The risk for ICA up to 30 days followup showed no difference between groups as reported in one trial (1.0% for CCTA versus 0.8% for SOC).

Figure 9 Meta-analysis results for risk of any revascularization across studies comparing CCTA with usual care in patients with intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

* Subgroup of intermediate-risk patients.

This figure is a forest plot that displays risk of revascularization (either percutaneous coronary intervention or coronary artery bypass graft) across studies comparing coronary computed tomography angiography with standard of care in patients with intermediate pretest risk. The risk for any revascularization at index was similar between the groups as reported in two studies (RD 2, 95% CI -1 to 5 per 100 patients, I2=0%). At 30 days followup after index, one trial reported no difference between groups (0.6% in both CCTA and SOC groups).

The observational study reported no statistical differences between CCTA and usual care patients in PCI (9% vs. 15%), CABG (1% vs. 2%), and intensified medical therapy (7% vs. 8%); however, the rate of referral for ICA was significantly lower following CCTA (19% vs. 87%; RR 0.22, 95% CI 0.14 to 0.33).92,94 Of those referred, a smaller proportion of CCTA patients showed no obstructive CAD on ICA compared with patients tested via usual care (10.5% [2/19] vs. 71.3% [62/87], RR 0.15, 95% CI 0.04 to 0.55).

###### Harms of Index Test and Consequences of Testing

The larger RCT reported a similarly low incidence of periprocedural complications (not defined further) in the CCTA (0.4%) and the usual care (0%) groups.80 In this same trial, CCTA was associated with significantly higher exposure to radiation at the index visit compared with usual care (mean 13.9 ± 10.4 vs. 4.7 ± 8.4 mSv, p<0.001). The observational study reported a mean radiation exposure of 8.7 mSv following CCTA but did not report exposure for the usual care group.92,94

###### Harms of Additional Testing

Cumulative radiation exposure (index visit plus additional testing during followup) was significantly greater following CCTA compared with usual care, as reported by one RCT (mean 14.3 ± 10.9 vs. 5.3 ± 9.6 mSv, p<0.001);80 however, over the followup period, the effective radiation dose was similar between groups: 0.4 versus 0.6 mSv, respectively.

###### Differential Effectiveness or Safety in Subgroups

A prespecified analysis from a fair-quality trial (ROMICAT-II) evaluated potential differences between women and men on outcomes following CCTA versus usual care;89 however, the primary clinical outcomes of interest for this review were not reported (e.g., death, MI). Of the 1,000 patients included, 468 (47%) were women and 532 (53%) were men. There were multiple differences at baseline between the sexes. Compared with men, women were slightly older (56 vs. 53 years) and a greater proportion were African American (75% vs. 66%), had diabetes (48% vs. 39%), were taking beta-blocker medication (47% vs. 39%), and were diagnosed with noncardiac chest pain (93% vs. 82%) (p<0.03 for all); conversely, fewer women were smokers (43% vs. 55%, p<0.01).

Although ACS as a final diagnosis was less common in women than men (3% vs. 12%), no difference in ACS rate by randomization strategies of CCTA versus usual care were identified for women (3% vs. 3%) or men (14% vs. 10%) and no evidence of modification by sex was seen (p=0.46). Similarly, there was no evidence of modification by sex for any of the following outcomes: direct ED discharge, downstream testing, ICA referral, PCI use, PCI or CABG use, repeat ED visit or hospitalization for chest pain, or major adverse cardiac event at 28 days. Authors report, however, that women undergoing CCTA versus usual care had fewer hospital admissions and shorter length of hospital stays compared with men (p=0.005 and 0.006, respectively). Sex also modified cumulative radiation exposure: women had lower mean cumulative radiation following initial testing with CCTA compared with men at both the index visit and at 28 days followup (p=0.003 and 0.02, respectively). CAD prevalence and severity was lower in women compared with men, which may partially explain the results.

#### Functional Tests Versus Functional Tests

##### SPECT Versus ECG

Two fair-quality trials compared SPECT with exercise ECG in intermediate-risk patients (see Appendix E and G for details); no other studies compared different types of functional testing in this population. One large RCT (N=824) enrolled women only who were at intermediate pretest risk presenting with chest pain to various outpatient cardiology practices (43 sites) across the United States and Canada.87 The trial was funded by a grant from GE Healthcare. The women received either SPECT (n=412) or exercise ECG (n=412); the Bruce exercise protocol was used in both test groups. Overall, groups were similar in age (median 62 years), presenting symptoms (60% typical angina), and cardiac risk factors. Outcomes were reported at 24 months for 93.7 percent of patients. Another RCT included 457 patients referred for stable chest pain to a single outpatient center in the United Kingdom; funding via grants was received from Bristol-Myers Squibb and Northwick Park Cardiac Research, as well as from an individual.85 Results were stratified based on pretest risk; 280 patients had intermediate pretest likelihood of CAD. Patients underwent either SPECT (n=178) or exercise ECG (n=102). Treadmill exercise was employed in both groups; pharmacological stress was used in some patients receiving SPECT. Groups were similar overall in age (mean age 59 years), sex (43.5% female), and cardiac risk factors but were not compared within the intermediate-risk group. Neither study reported a baseline risk score for their population. Patients were followed for a mean of 22 months; loss to followup was not reported for this subgroup of patients but attrition was 3 percent in the overall population. Methodological shortcomings included lack of concealed allocation in both studies and lack of blinded assessment of outcomes in one.85

###### Clinical Outcomes

All clinical outcomes were reported through 24 months of followup in the trial of women. Overall mortality was similarly low in both SPECT and exercise ECG groups (1.0% vs. 0.5%),87 as was the frequency of major adverse major adverse cardiac events (including cardiac death, nonfatal MI, or hospitalization for acute coronary syndrome or heart failure) (2.3% SPECT vs. 1.7% exercise ECG, RD 0.54, 95% CI -1.5 to 2.6 per 100 people). Hospitalizations for chest pain (3.9% vs. 3.1%) and worsening angina frequency or stability (5% of patients in both groups) were also similar. By 12 months, 49 percent of patients in both groups were angina-free, and by 24 months a similar proportion of patients in both groups remained free from angina (64.9% SPECT vs. 60.4% ECG; RD 4.5, 95% CI -2.3 to 11.4 per 100 patients).

###### Clinical Management

While referral to ICA was similar between the SPECT and exercise ECG arms (5.7% vs. 6.4%, RD -0.7, 95% CI -4 to 3 per 100 people) through 24 months in the trial of women,87 the other trial reported that a significantly smaller percentage of subjects undergoing SPECT had ICA when compared with ECG testing (10.7% vs. 43.1%, RD -32.5, 95% CI -43 to -22 per 100 people) through a mean of 22 months.85 This latter trial used Bayesian methods to model post-test risk and reported that only 21 percent of those with intermediate pretest risk finished with intermediate post-test risk (2% SPECT vs. 53% ECG) and that those with a normal or low-risk test in either arm did not receive ICA. Based on results from the Shaw trial of women, additional testing with SPECT was done less frequently in the SPECT group than in the exercise ECG group (9.1% vs. 18.6%, RD -8.9, 95% CI -13.7 to -4.1 per 100 people); of those randomized to SPECT, this test was repeated in 9, 8, and 15 percent of women with normal, mildly abnormal, and moderately to severely abnormal results, while among those randomized to exercise ECG, the frequency of crossover to SPECT (counts as use of additional test) was 8, 25, and 43 percent respectively for women who had normal, indeterminate, and abnormal ECG results.87 Additional testing with exercise ECG was performed in 0.3 percent of patients in both groups. In the other trial, SPECT patients had significantly less additional testing when compared with ECG testing through a mean of 22 months (0% vs. 38%, RD -38, 95% CI -48 to -29 per 100 people).85 Revascularization was similar between SPECT and exercise ECG in the trial of women only (2.1% vs. 1.0%, RD 1.1, 95% CI -0.7 to 2.8 per 100 patients).87 The trial of the general population reported that SPECT patients were considerably more likely to receive medical therapy than those who underwent stress ECG (89.3% vs. 18.6%, RD 70.7, 95% CI 61.9 to 79.5 per 100).85

###### Harms of Index Test and Consequences of Testing

The Shaw trial reported a mean radiation exposure of 14.0 mSv following SPECT but did not report radiation exposure for the exercise ECG group.87

###### Harms and Consequences of Additional Testing; Differential Effectiveness or Safety in Subgroups

Not reported for intermediate-risk patients.

#### Anatomic Tests Versus Functional Tests

##### CCTA Versus Functional Testing (Various)

One large, good-quality trial compared CCTA with functional testing in 10,003 outpatients at intermediate pretest risk (see Appendix E and G for details);76 no other studies compared anatomical with functional testing in this population. Dubbed the PROMISE trial, this multicenter RCT was conducted in 193 outpatient clinics (cardiology, radiology, primary care, urgent care, and anesthesiology departments) across the United States and Canada. Outcomes were reported at 12 months for 93.5 percent of patients; outcomes at the last followup were also reported (median of 25 [interquartile range (IQR) 18 to 34] months). CCTA scans were obtained with a 64-detector row scanner and contrast. Those randomized to functional testing could undergo one of a number of different testing modalities which were chosen prior to randomization. Functional testing modalities used included nuclear stress imaging (63.09%), stress echocardiography (21.09%), and exercise ECG (9.53%). A similar proportion of patients randomized to both CCTA and functional testing (6.25%) did not receive the assigned test (i.e., did not undergo any test or underwent a different test). The stressors used for nuclear imaging and echocardiography were not reported.

For inclusion, patients were required to have new or worsening symptoms consistent with suspected CAD, no history of MI, and no history revascularization or testing within the past 12 months. In general, males were required to be 55 years or older and females 65 years or older, although exceptions were made for slightly younger patients with specific risk factors. The two groups were well-balanced in terms of baseline characteristics and cardiac risk factors (mean of 2.4 ± 1.1 risk factors per patient). Mean age was 60.8 ± 8.3 years and 52.7 percent of patients were female. Racial or ethnic minorities comprised 22.6 percent of the population. Pretest risk for CAD was intermediate (10%–90%) in 92.6 percent of patients (and was low [<10%] in 2.5% and high [>90%] in 4.9%). Overall, the mean pretest risk of CAD was 53.3 percent ± 21.4 percent based on a combined Diamond and Forrester and Coronary Artery Surgery Study score. Presenting symptoms included chest pain (72.7%) and shortness of breath on exertion (14.9%). Angina was atypical in the majority of patients (77.7%), with fewer presenting with typical (11.7%) or nonanginal pain (10.6%). There were no apparent methodological shortcomings.

###### Clinical Outcomes

There was no difference in the risk of all-cause death between the CCTA and functional testing groups through 12 months (0.42% vs. 0.64%) and a median of 25 months (1.48% vs. 1.50%) followup.76 Similarly, risk of nonfatal MI was similar between groups through 12 months (0.36% vs. 0.54%, RD -0.18, 95% -0.44 to 0.08 per 100 people) and a median of 25 months (0.60% vs. 0.80%, RD -0.20, 95% CI -0.53 to 0.13 per 100 people). However, the composite risk of death or nonfatal MI was significantly lower in the CCTA group through 12 months (0.78% vs. 1.14%, adjusted hazard ratio (HR) 0.66, 95% CI 0.44 to 1.00, p=0.049) although the difference was no longer significant by a median of 25 months (2.08% vs. 2.24%). The primary composite endpoint (defined as all-cause death, nonfatal MI, hospitalization for unstable angina, or a major procedural complication [e.g., stroke, major bleeding, anaphylaxis, or renal failure requiring dialysis]) and the secondary endpoint (defined as the primary endpoint or catheterization showing no obstructive CAD) occurred at a similar rate in both groups. While there was no difference in hospitalization for unstable angina between groups through 12 months (0.98% vs. 0.67%), it was more common in the CCTA group through a median of 25 months (1.22% vs. 0.82%, RD 0.40, 95% CI 0.01 to 0.80 per 100 patients). In contrast, hospitalization for any cardiovascular reason other than unstable angina was less common in the CCTA group through a median of 25 months (0% vs. 0.10%, p=0.0255). There was no difference between groups at either time point in composite outcome of death, nonfatal MI, or hospitalization for unstable angina. While the study reported that a similar percentage of patients in each test group tested positive (abnormal) (10.68% vs. 1.16%), clinical outcomes were not stratified according to test result.

###### Clinical Management

Although more patients in the CCTA group underwent ICA within 90 days compared with the functional testing group (12.19% vs. 8.11%, RD 4.08, 95% CI 2.90 to 5.26 per 100 people), the ICA results showed no obstructive CAD (i.e., false positives) in fewer CCTA patients (27.9% vs. 52.5% of patients who underwent ICA; p<0.0001). Moreover, more CCTA patients underwent revascularization within 90 days than functional testing patients (6.22% vs. 3.16%, RD 3.07, 95% CI 2.24 to 3.90 per 100 patients); similar results were found when considering the 90-day risk of CABG alone (1.44% vs. 0.76%, RD 0.68, 95% CI 0.27 to 1.09 per 100 people) and PCI alone (4.8% vs. 2.4%, RD 2.4, 95% CI 1.7 to 3.1 per 100 people).76

###### Harms of Index Test and Consequences of Testing

Douglas et al. reported no difference between CCTA and functional imaging groups in the risk of major procedural complications, which was a component of the primary outcome and included stroke, major bleeding, anaphylaxis, or renal failure requiring dialysis (0.1% in both groups) throughout the entire followup period.76 There was similar risk of procedural stroke (0.02% vs. 0.04%) and major bleeding (0.1% in both groups) between groups, and no instances of anaphylaxis or renal failure requiring dialysis. Exercise-induced hypotension, stress-induced symptoms not resolved within 20 minutes, ventricular tachycardia, and hemodynamic instability were rare, occurring in no CCTA patients and less than 0.1 percent of functional testing patients; it was unclear whether these events occurred periprocedurally or at a later time point. There were no cases of rapid atrial fibrillation that did not slow or convert. Mild contrast reactions were significantly more common in the CCTA group than in the functional testing group (0.4% vs. 0%, RD 0.44 per 100 people, p<0.0001). The study reported a total of 37 mild safety events in the CCTA group and 21 in the functional testing group, making these events significantly more common for CCTA patients (0.74% vs. 0.42%, RD 0.32, 95% CI 0.02 to 0.62 per 100 people, p=0.0344).

###### Harms of Additional Testing

In the PROMISE trial (Douglas et al.), cumulative radiation exposure through 90 days was higher in the CCTA group compared with the functional testing group (mean 12.0 ± 8.5 vs. 10.1 ± 9.0 mSv [mean difference 3.0, 95% CI 2.7 to 3.3]).76

###### Differential Effectiveness or Safety in Subgroups

Douglas et al. reported that none of the prespecified subgroups modified the primary composite outcome (all-cause death, nonfatal MI, hospitalization for unstable angina, or a major procedural complication [e.g., stroke, major bleeding, anaphylaxis, renal failure requiring dialysis]), with results across subgroups consistent with those for the entire study population. Subgroups examined included age (<65 vs. ≥65 years), sex, race (white vs. nonwhite), pretest risk assessment (≤30% vs. 31-70% vs. >70%), CAD equivalence, and pretest probability of CAD (low [<10%] vs. intermediate [10-90%] vs. high [>90%]).76

##### CCTA Versus SPECT

One fair-quality trial (PROSPECT)88 evaluated the impact of testing with CCTA versus SPECT in 400 intermediate-risk patients admitted to a telemetry-monitored ward (see Appendix E and G for details). No other studies compared CCTA with SPECT alone in this population. PROSPECT was a single-center trial conducted at an inner-city hospital in the United States. Twelve-month (or longer) outcomes were available for 95.3 percent of patients. Two-hundred patients were randomized to each testing group. In the CCTA group, 93.5 percent underwent testing as randomized; 64-row scanning with contrast was used. In the SPECT group, 94.5 percent received testing as randomized. The preferred stressor was exercise, while those unable to exercise received pharmacological stress with or without low-level exercise. The percentage of patients who received each type of stress was not reported.

Inclusion criteria were admittance to a telemetry screening ward for chest pain, absence of known CAD or acute MI, one or more intermediate-risk criteria for short-term death, or MI and no cardiac testing or catheterization within the previous 6 months. The groups were well-balanced in terms of baseline characteristics. Mean age was 56.6 ± 11.2 years and 62.8 percent of patients were female. Racial or ethnic minorities comprised the majority of the population (94.8%). Pretest risk was intermediate (37%) based the Diamond and Forrester prediction rule; the mean TIMI score was 1.3 ± 1.0. Symptoms at presentation included retrosternal pain in 69.5 percent, exertional pain in 40.0 percent, pain for longer than 20 minutes in 62.0 percent, and new pain on exertion within the past 2 weeks in 37.8 percent. Methodological limitations were lack of blinding for all outcomes except revascularization and absence of a prespecified definition of a positive test. The authors recognized both limitations and noted that the trial was designed to mimic real-life practice wherein treatment decisions are made based on factors besides imaging results alone.

###### Clinical Outcomes

Through a median of 24.5 months, all-cause mortality occurred in slightly fewer CCTA than SPECT patients, though the difference did not reach statistical significance (0.5% vs. 3.0%, RD -2.5, 95% CI -5.1 to 0.06 per 100 people). The percentage of patients who had a nonfatal MI or stroke was not clearly reported for both treatment groups. One patient in the CCTA group had a nonfatal MI and died at a later time. Whether the death was MI- or cardiac-related was not reported. The composite risk of nonfatal MI, cardiac arrest, and stroke was the same in both groups (4.5% vs. 4.5%). No details were reported for events in the CCTA group and in the SPECT group, two patients had two strokes each, and no details were reported for the remaining patients. Chest pain was described as “same” or “worse” in a similar percentage of patients in the CCTA versus SPECT groups at 6 to 12 months (15.8% vs. 12.7%, RD 3.0, 95% CI -4.2 to 10.3 per 100 people) and 36 percent of patients in both groups continued to have chest pain during this time period. Cardiovascular rehospitalization through a median of 40.4 months was needed in fewer CCTA versus SPECT patients, although the difference did not achieve statistical significance (25.0% vs. 31.0%, RD -5.5, 95% CI -14.3 to 0.03 per 100 people). Cardio-related ED visits (21.0% vs. 20.0%) were similar between groups through a median of 40.4 months.

###### Clinical Management

Test results were not reported. There was no difference between CCTA and SPECT groups in the percentage of patients who underwent ICA within 12 months (15.0% vs. 16.0%, RD 1.0, 95% CI -8.1 to 6.1 per 100 people). A similar percentage of CCTA and SPECT patients who underwent ICA did not undergo revascularization (7.5% vs. 10.0%, RD 2.5, 95% CI -2.2 to 7.2 per 100 patients). Although there was no difference between groups in revascularization through 12 months (7.5% vs. 6.0%, RD 1.5, 95% CI -3.4 to 6.4 per 100 patients) or in PCI through 12 months (4.0% vs. 5.5%, RD -1.5, 95% CI -5.7 to 2.7 per 100 patients), significantly more CCTA patients underwent CABG compared with SPECT patients through 12 months (3.5% vs. 0.5%, RD 3.0, 95% CI 0.3 to 5.7 per 100 people). Additional noninvasive testing was performed in 22.5 percent of patients in both the CCTA and SPECT groups, including myocardial perfusion imaging (MPI) (15.0% vs. 13.0%), stress echocardiography (6.5% vs. 7.0%), and CCTA (1.0% vs. 2.5%). There were no differences between the CCTA and SPECT groups in new prescriptions for aspirin (39.5% vs. 34.0%), statins (25.0% vs. 18.0%), or in prescriptions for increased statin dosages (3.0% in both groups).

###### Harms of Index Test and Consequences of Testing

No major complications were attributed to the imaging procedure. Thirty-day death, MI, and stroke were not reported. Periprocedural chest pain, shortness of breath, or palpitations occurred in significantly fewer CCTA versus SPECT patients (0.5% vs. 15.9%, RD -15.4, 95% CI -20.8 to -10.1 per 100 people), while there were no differences between groups in “general” adverse reactions (including headache, nausea, dizziness, or feeling of warmth) (24.2% vs. 24.5%) or in rash or pruritus (1.6% vs. 0%, p=0.25). There were no cases of post-test renal dysfunction. Radiation exposure from the initial test was lower in the CCTA group compared with the functional testing group (9.6 [IQR, 6.2 to 23] vs. 27 [IQR, 19 to 27] mSv, mean difference -17.4, 95% CI NR, p<0.001).

###### Harms of Additional Testing

Cumulative cardiac radiation exposure through 12 months was lower in the CCTA group compared with the functional testing group (12 [IQR 6.4 to 26] vs. 27 [IQR 19 to 27] mSv, mean difference -15, 95% CI NR, p<0.001); similar results were found through the entire followup period (median of 40.4 months) (13 [IQR, 6.9 to 27] vs. 27 [IQR 19 to 27] mSv, mean difference -14, 95% CI NR, p<0.001).

###### Differential Effectiveness or Safety in Subgroups

Not reported.

##### Noncomparative Studies: Anatomical

No noncomparative studies of functional testing in patients at intermediate risk met the inclusion criteria that reported outcomes of interest. For anatomic testing in this population, only studies of coronary artery calcium scoring were identified.

###### Calcium Scoring

Two noncomparative studies of calcium scoring during CCTA in patients at intermediate pretest risk reported on predictive accuracy.123,125 One study was conducted in a single center outpatient setting (N=341) and the other included data from an international, multicenter registry (N=10,037). The study populations differed, respectively, in terms of mean age (62 vs. 57 years) and sex (33% vs. 43% female), as well as several cardiac risk factors. The followup period was 24 months in both studies. In terms of test-positive patients, the frequency of any cardiac event was substantially higher in both studies (5 and 8 per 100 people) compared with those who tested negative (0 and 1 per 100 people). The registry study also reported a higher risk of both mortality (1.8% vs. 0.4%) and MI (1.1% vs. 0.2%) in those who tested positive (see Appendix F for details).

## Low to Intermediate Pretest Risk of Coronary Artery Disease

### Key Points

Evidence for all primary outcomes and comparators not listed was insufficient to draw conclusions because of study limitations and/or imprecision in the observational study or because of lack of evidence.

#### CCTA Versus Usual Care

- In low- to intermediate-risk patients presenting to the ED, there is low-strength evidence showing no difference between groups in mortality or MI diagnosis at the index visit or through 1 month based on one fair-quality trial. Moderate-strength evidence from the same trial suggests that CCTA patients were less likely to be hospitalized at the index ED visit but cardiac-related hospitalizations through 1 month were similar. The CCTA groups were less likely to undergo additional testing at the index and 1-month followup visits (1 fair-quality trial) and through 3-months followup (1 poor-quality trial) (moderate [1 month] and low [3 months] strength of evidence). While ICA referrals were similar for the groups at the index ED visit and through 1- to 3-month followup, there were slightly more revascularization procedures in the CCTA group at the index visit in one large fair-quality trial but no difference through the followup period across two trials (low strength of evidence).

#### CCTA Versus Exercise ECG

- In low- to intermediate-risk patients, there was low-strength evidence of no differences in mortality or MI between groups through 12 months based on one trial of ED patients and one observational study of outpatients (both fair quality). The 12-month rate of referral to ICA and revascularization was significantly greater following CCTA than exercise ECG based on data from the trial of ED patients (low strength of evidence).

#### CCTA Versus SPECT

- In low- to intermediate-risk patients presenting to the ED, there was low-strength evidence from two trials (1 good- and 1 fair-quality) that no difference was found between groups in mortality through 6 months. There was moderate-strength evidence that there was no difference in MI (both RCTs) or cardiac-related hospitalizations (1 good-quality RCT) through 6 months; one fair-quality observational study of outpatients also reported no difference in mortality or cardiac-related hospitalizations between groups through a mean of 30 months. Together, the trials of ED patients reported that ICA referrals were similar between groups at both the index ED test and through 6 months (low strength of evidence). Additional noninvasive testing was more common following CCTA at the index visit (high strength of evidence from two trials); additional noninvasive testing through 6 months was similar (low strength of evidence from 1 trial). Moderate-strength evidence from both trials of ED patients suggested similar referral for revascularization, including PCI and CABG evaluated separately, at the index visit and through 6 months.

### Detailed Synthesis

A total of 15 studies were identified in populations with low to intermediate pretest risk of CAD and eight (9 publications) compared CCTA with usual care (2 RCTs,81,83 1 retrospective observational107), SPECT (2 RCTs,77,78 1 retrospective observational90), and exercise ECG (1 RCT,79 1 retrospective observational100,106) (Table 10); seven additional noncomparative studies (2 of which contained data for 2 different tests) reported on the predictive accuracy of stress echocardiography (2 studies),110,114 exercise ECG (4 studies),109-111,116 and calcium scoring (3 studies).111,120,122

Table 10 Summary of findings and strength of evidence: Low to intermediate pretest risk

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | CCTA vs. usual care^†^ | 1 RCT (N=1,392) 1 observational study (N=1,788) | ED | There is low-strength evidence that a difference in mortality was not found. In both studies, no deaths occurred in either group through 1 month. | Low
Mortality (all-cause) | CCTA vs. exercise ECG | 1 RCT (N=562) 1 observational study (N=498) | ED (RCT) Outpatient (observational) | There is low-strength evidence that a difference in mortality was not found. No deaths through 1 month. Through 12 months, no difference between groups in mortality (0.6% vs. 0.4%, RD 0.2, 95% CI -1.0 to 1.4 per 100 people) were reported; the observational study reported no deaths. | Low
Mortality (all-cause) | CCTA vs. SPECT | 2 RCTs (N=952) 1 observational study (N=252) | ED (RCTs) Inpatient or outpatient (observational) | There is low-strength evidence that a difference in mortality was not found. No deaths through 6 months (2 RCTs) or through a mean of 30 months (observational study). | Low
Myocardial Infarction | CCTA vs. usual care^†^ | 1 RCT (N=1,392) 1 observational study (N=1,788) | ED | A difference in diagnosis of MI was not found at the ED index visit (1.0% vs. 0.9%) in the RCT or through 1 month in both the RCT (1.1% in both groups) and the observational study (0.3% vs. 0.6%). | Low
Myocardial Infarction | CCTA vs. exercise ECG | 1 RCT (N=562) 1 observational study (N=498) | ED (RCT) Outpatient (observational) | A difference in diagnosis of MI was not found at index visit (1.9% vs. 1.7%, RD 0.2, 95% CI -2.0 to 2.4 per 100 people) and there were no additional MIs through 1 month. Through 12 months, MI occurred at a similar rate between groups (0% vs. 1.2%, p=0.08) based on the observational study. | Low
Myocardial Infarction | CCTA vs. SPECT | 2 RCTs (N=952) | ED | No difference in MI diagnosis was found between groups at the index visit (0.3% vs. 1.5%, RD -1.2%, 95% CI -2.6%–0.19%) (1 RCT, N=749) or through 6 months (0% in both groups) (both RCTs). | Low
Invasive Coronary Angiography referral | CCTA vs. usual care^†^ | 2 RCTs (N=1452) 1 observational study (N=1,788) | ED | Referral for ICA was similar between groups at the time of index ED visit (1 RCT, N=1392) (4.1% vs. 3.9%) and through 1- to 3-months (2 RCTs) (pooled 5.2% vs. 4.7%, RD 1, 95% CI -1 to 3 per 100 people). In the observational study, up to 1 month post ED visit, ICA referral was less common with CCTA (1% vs. 3%); although authors report statistical significance (p<0.001), clinical significance is unclear. | Low
Invasive Coronary Angiography referral | CCTA vs. exercise ECG | 1 RCT (N=562) | ED | CCTA associated with more ICA referrals through 12 months (9.0% vs. 2.3%, RD 4.8, 95% CI 0.8 to 8.9 per 100 people). | Low
Invasive Coronary Angiography referral | CCTA vs. exercise ECG | 1 observational study (N=498) | Outpatient | There were fewer ICA referrals in the CCTA group through 12 months (17.5% vs. 22.7%; unadjusted RR 0.7, 95% CI 0.54 to 1.1, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient
Invasive Coronary Angiography referral | CCTA vs. SPECT | 2 RCTs (N=952) | ED | ICA referral rates were similar at the index ED visit (7.6% vs. 5.5%, pooled RD 4, 95% CI -4 to 11 per 100 people, I^2^=71.7%) and through 6 months (0.7% vs. 1.3%, pooled RD -1, 95% CI -5 to 3 per 100 people, I^2^=71.1%). | Low
Invasive Coronary Angiography referral | CCTA vs. SPECT | 1 observational study (N=252) | Inpatient or outpatient | CCTA patients were less likely than SPECT patients to undergo ICA (3.3% vs. 8.1%, RR 0.4, 95% CI 0.2 to 0.9) through a mean of 30 months. Definitive conclusions are not possible.^‡^ | Insufficient
Revascularization | CCTA vs. usual care^†^ | 2 RCTs (N=1452) 1 observational study (N=1,788) | ED | At the index visit, CCTA was associated with slightly more revascularization procedures (2.5% vs. 0.9%, RD 1.7, 95% CI 0.3 to 3.0 per 100 people) in one trial (N=1392). Through 1- to 3-month followup, revascularization was similar between CCTA and usual care groups (pooled, 2.7% vs. 1.2%, RD 1, 95% CI 0 to 3 per 100 people) based on both trials and the observational study (3% vs. 2%). | Low
Revascularization | CCTA vs. exercise ECG | 1 RCT (N=562) | ED | Revascularization was significantly more common in CCTA vs. exercise ECG through 12 months (4.3% vs. 1.3%, RD 3.1, 95% CI 0.5 to 5.7 per 100 people). | Low
Revascularization | CCTA vs. exercise ECG | 1 observational study (n=96 subset of test-positive patients) | Outpatient | Revascularization was more common following positive CCTA than positive exercise ECG through 12 months (45% vs. 17%, unadjusted RR 2.7, 95% CI 1.4 to 5.2). Definitive conclusions are not possible.^‡^ | Insufficient
Revascularization | CCTA vs. SPECT | 2 RCTs (N=952) | ED | Revascularization at the ED index visit (3.9% vs. 2.1%, pooled RD 2 per 100 people, 95% CI 0 to 4) and after this visit through 6 months (0.5% vs. 0%, pooled RD 0, 95% CI 0 to 1 per 100 people) was similar between groups. | Moderate
Percutaneous Coronary Intervention | CCTA vs. usual care^†^ | 1 RCT (N=60) | ED | Similarly low rates between groups over 3 months followup (CCTA 3% vs. usual care 0%); unclear if this estimate includes the index visit. | Low
Percutaneous Coronary Intervention | CCTA vs. exercise ECG | 1 observational study (n=96 subset of test-positive patients) | Outpatient | More patients who tested positive with CCTA underwent PCI through 12 months compared with those who tested positive with exercise ECG (29% vs. 15%, unadjusted RR 1.9, 95% CI 0.9 to 4.2, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient
Percutaneous Coronary Intervention | CCTA vs. SPECT | 2 RCTs (N=952) | ED | Across both trials, PCI use was similar at the index visit 2.5%–3% vs. 1.0%–2.4%, RD 0.13 to 2.0 per 100 people, p=NS) and through 6 months (0.3%–1.0% vs. 0%, RD 0.3 to 1.0 per 100 people, p=NS). | Moderate
Coronary Artery Bypass Graft | CCTA vs. usual care^†^ | 1 RCT (N=60) | ED | A difference in CABG use was not found. No CABG procedures reported in either group through 3 months. | Low
Coronary Artery Bypass Graft | CCTA vs. exercise ECG | 1 observational study (n=96 subset of test-positive patients) | Outpatient | Those who tested positive after CCTA were more likely to undergo CABG through 12 months than those who tested positive with exercise ECG (16% vs. 2%, unadjusted RR 11, 95% CI 1 to 86). Definitive conclusions are not possible.^‡^ | Insufficient
Coronary Artery Bypass Graft | CCTA vs. SPECT | 2 RCTs (N=952) | ED | A difference in referral for CABG was not found at the ED index visit (1.1%–2.0% vs. 0%) or after this visit through 6 months (0% in both groups). | Moderate
Additional Testing | CCTA vs. usual care^†^ | 2 RCTs (N=1452) 1 observational study (N=1,788) | ED | At the ED index visit, CCTA testing was associated with less stress testing than usual care (13.7% vs. 57.8%, RD -44.1, 95% CI -49.2 to -39.1 per 100 people) (1 RCT, N=1392). During the followup period, additional noninvasive testing was done in fewer patients in the CCTA group through 1 month (23.1% vs. 66.4%, RD -43.3, 95% CI -48.4 to -38.1 per 100 people) in one RCT (N=1392) and the observational study (4% vs. 21%, p<0.001), and through 3 months (33% vs. 60%, RD -27, 95% CI -51 to -2) in the second RCT (N=60). | Moderate (30 days) Low (90 days)
Additional Testing | CCTA vs. exercise ECG | 1 observational study (N=498) | Outpatient | Additional noninvasive testing was less common following CCTA than exercise ECG through 12 months (4.8% vs. 13.4%, unadjusted RR 0.4, 95% CI 0.2 to 0.7). Definitive conclusions are not possible.^‡^ | Insufficient
Additional Testing | CCTA vs. SPECT | 2 RCTs (N=952) | ED | At the index visit, additional noninvasive testing was more commonly done in the CCTA group, with the larger trial reporting 10.2% for CCTA and 0.9% for SPECT (RD 9.4, 95% CI 6.1 to 12.7 per 100 patients) and the smaller trial reporting 24% for CCTA and 0% for SPECT (RD 24 per 100 people, p<0.001). There were no significant differences between groups in additional testing through 6 months as reported by one trial (1% vs. 3%). | High (index visit) Low (6 months)
Additional Testing | CCTA vs. SPECT | 1 observational study (N=252) | Inpatient or outpatient | A difference was not found for additional testing at a mean of 30 months including SPECT (5.7% vs. 6.0%), exercise echocardiography (1.2% vs. 0.9%), or exercise ECG (2.5% vs. 2.1%). Definitive conclusions are not possible.^‡^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. usual care^†^ | 1 RCT (N=1392) | ED | One trial (N=1392) reported that the CCTA group was significantly less likely to be hospitalized or admitted for observation at the ED index visit (50% vs. 77%, RD -26.8, 95% CI -31.9 to -21.8 per 100 people). During followup, 1-month rates of cardiac hospitalization were similar between groups (3% vs. 2%). | Moderate
Hospitalization (Cardiac related) | CCTA vs. SPECT | 1 RCT (N=749) 1 observational study (N=252) | ED (RCT) Inpatient or outpatient (observational) | Frequency of hospitalization was similar between groups The RCT reported no cardiovascular hospitalizations through 6 months and the observational study reported similar results between groups (6.6% vs. 4.3%) through a mean of 30 months. | Moderate
Harms of Index Test | CCTA vs. usual care^†^ | 1 RCT (N=1392) | ED | A difference in bradyarrhythmia was not found; it occurred in one patient in each group (0.1% vs. 0.2%). | Low
Harms of Index Test | CCTA vs. SPECT | 1 observational study (N=252) | Inpatient or outpatient | Incidental findings requiring further investigation occurred following CCTA in 7.1% of patients. Definitive conclusions are not possible.^‡^ | Insufficient

CABG = coronary artery bypass graft; CCTA = coronary computed tomography angiography; CI = confidence interval; ED = emergency department; ICA = invasive coronary angiography; MI = myocardial infarction; NS = not statistically significant; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; RD = risk difference; RR = relative risk; SPECT = single-photon emission computed tomography

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Usual consisted of traditional “rule out” approaches at the discretion of the patients' treating physician (64% underwent diagnostic testing, primarily stress testing with imaging) in one trial (N=1392) and standard treatment (12-lead ECG, coronary biomarkers, continuous ECG monitoring, medication, cardiology consultation, and additional cardiac testing as required) in the other trial (N=60).

‡ Definitive conclusions are not possible because of study limitations and/or imprecision in observational studies.

#### Anatomic Tests Versus Standard of Care

##### CCTA Versus Usual Care

Two RCTs, one fair quality81 and one poor quality,83 compared CCTA with usual care in patients with low to intermediate pretest risk presenting with chest pain to the ED in the United States (see Appendix E and G for details).81,83 No other studies compared anatomical testing with usual care in this population. In one large multicenter trial conducted across five EDs, patients received testing with 64-slice (or higher) CCTA with contrast (n=908) or usual care (n=462) consisting of traditional “rule out” approaches at the discretion of the patients' treating physician (64% underwent diagnostic testing, primarily stress testing with imaging).81 Outcomes were reported at the index visit and at 1 month; only 84.5 percent of patients randomized to CCTA actually underwent the test. This trial was supported by the Commonwealth of Pennsylvania Department of Health and the American College of Radiology Imaging Network Foundation. A small RCT was conducted in a single ED and all patients received standard treatment (i.e., 12-lead ECG, coronary biomarkers, continuous ECG monitoring, medication, cardiology consultation, and additional cardiac testing as required) with those randomized to the intervention group also undergoing 64-slice CCTA (n=30 in both groups).83 Outcomes were reported for all patients over a 3-month followup period. This trial received grants from the National Center for Research Resources. Within each trial, the CCTA and usual care groups were similar in age and sex; cardiac risk factors were also similar between groups in one study81 but not reported in the second.83 Only one of the trials reported baseline risk scores; 51, 36, and 13 percent of the overall population had a TIMI risk score of 0, 1, and 2 or higher, respectively.81 Across trials, mean ages (49 vs. 51 years) and the proportion of females (53% vs. 50%) were similar. The trial by Litt et al. 2012 enrolled more African Americans (60% vs. 47%) compared with Miller et al. 2012 trial. Methodological shortcomings included unclear allocation concealment and unclear blinding of outcomes assessment in both studies and no reporting of or adjustment for standard cardiac risk factors in one study.83

One fair-quality retrospective observational study compared CCTA with usual care in 1,788 patients at low to intermediate risk (no details on risk scores reported)107 (see Appendix E for details). The study was conducted in a single ED in the United States and funding was not reported. Patients received CCTA or usual care at the discretion of the ED physician, depending on CCTA availability and clinical suitability. Data for the study were abstracted from hospital discharge and followup records and patients were matched for analysis by propensity scores. All patients were initially evaluated with 12-lead ECG and serum troponin I level. Patients then received CCTA (n=894) or usual care (n=894) to include cardiac monitoring in the ED with serial ECGs and serial troponin I levels and stress testing at the discretion of the clinician. Patents in the two groups were similar in mean age (49 years), proportion that was female (52%), and in all cardiac risk factors. Methodological shortcomings included unclear blinding of outcomes assessment.

###### Clinical Outcomes

In the larger trial, no deaths were reported for CCTA or usual care patients during the 30-day followup period.81 The same trial found similar percentages of patients with a MI diagnosis at the index ED visit (1.0% vs. 0.9%, RD 0.1, 95% CI -0.9 to 1.2 per 100 people) and through 30 days (1.1% in both groups). At the index visit, diagnosis with acute coronary syndrome without MI was also similar between CCTA and usual care groups (3.1% vs. 1.5%, RD 1.6, 95% CI -0.01 to 3.2 per 100 patients); CCTA was associated with significantly more positive diagnoses for CAD (9.0% vs. 3.5%, RD 5.6, 95% CI 3.1 to 8.1 per 100 patients).81 The CCTA group was less likely than the usual care group to be admitted to the hospital or observation unit at the index ED visit (50% vs. 77%, RD -26.8, 95% CI -31.9 to -21.8 per 100), with similar incidences between the groups of cardiac-related hospital admissions after the index visit (3.1% vs. 2.4%, RD 0.7, 95% CI -1.1 to 2.6).81 In the smaller trial, the CCTA group was less likely to be hospitalized (for presumably any reason) during the 90-day followup period compared with the usual care group (20% vs. 53%, RD -33, 95% CI -56 to -10 per 100 people), but it was not clear whether or not this included admissions at the time of the index visit.83 This same trial found that ED visits within 90 days were less common in the CCTA group compared with the usual care group, though the results did not reach statistical significance (17% vs. 33%, RD -17, 95% CI -38 to 5 per 100 people),83 while similar proportions of CCTA and usual care patients had revisits to the ED during 30 days of followup as reported in the larger trial (8.0% vs. 7.2%, RD 0.5, 95% CI -2.5 to 3.5).81 The smaller trial found no significant difference between the CCTA and usual care groups in change in quality of life, as measured by either the SF-12 Physical Component Score or the SF-12 Mental Component Score.83

The single observational study reported no deaths in either group within 30 days of the index visit.107 The risk of acute MI was not statistically different between the CCTA and the usual care groups over 30 days (0.3% vs. 0.6%, adjusted OR [CCTA as referent] 4.3, 95% CI 0.3 to 71.4, p=0.31); all MIs occurred during the index visit. Patients in the usual care group were significantly more likely to be hospitalized at the index visit compared with those who underwent CCTA initially (40% vs. 14%; adjusted OR 5.5, 95% CI 3.8 to 8.0, p<0.001). The likelihood of returning to the ED for any cause within 30 days of the index visit was similar following usual care compared with CCTA (3.6% vs. 1.3%; adjusted OR 8.5, 95% CI 0.4 to 180, p=0.17); however, among patients that returned to the ED, those in the usual care group were significantly more likely to return for chest pain (2.2% vs. 0.6%; adjusted OR 5.1, 95% CI 1.3 to 20.3, p=0.02).

###### Clinical Management

ICA referral was similar between CCTA and usual care patients at both the index ED visit (4.1% vs. 3.9%) as reported by the larger trial (4.1% vs. 3.9%),81 and during the 30- and 90-day followup periods as reported by both trials (pooled, 5.2% vs. 4.7%, RD 1, 95% CI -1 to 3 per 100 people, I^2^=0%) (Figure 10).81,83 However, ICA results showed fewer false positives (i.e., no obstructive CAD) in patients referred following CCTA compared with usual testing at the index ED visit (24% vs. 56%) and at 30 days (29% vs. 53%) in the larger trial,81 and during 90 days of followup (25% vs. 75%) in the smaller trial.83 The larger trial found that CCTA testing was associated with less stress testing than usual care at the index ED visit (13.7% vs. 57.8%, RD -44.1, 95% CI -49.2 to -39.1 per 100 people) and less additional noninvasive testing of any type within 30 days in the CCTA group (23.1% vs. 66.4%, RD -43.3, 95% CI -48.4 to -38.1 per 100 people). While stress testing through 30 days of followup was done in fewer CCTA patients (16.9% vs. 59.8%, RD -42.9, 95% CI -48.0 to -37.8 per 100 people), a similar number of patients in the CCTA and usual care groups received resting echocardiogram within 30 days (6.2% vs. 6.6%).81 The smaller trial of 60 patients found that through 90 days of followup, the CCTA group had less additional noninvasive testing (33% vs. 60%, RD -27, 95% CI -51 to -2), which included exercise stress testing (7% vs. 20%), nuclear perfusion testing (10% vs. 20%), transthoracic echocardiography (7% vs. 17%), and stress echocardiography (10% vs. 3%).83 CCTA was associated with slightly more revascularization procedures at the time of the index visit, as reported by the larger trial (2.5% vs. 0.9%, RD 1.7, 95% CI 0.3 to 3.0 per 100 people),81 while revascularization was similar between the CCTA and usual care groups during the 30- and 90-day followup periods, as reported across both trials (pooled, 2.7% vs. 1.2%, RD 1, 95% CI 0 to 3 per 100 people, I^2^=0) (Figure 11).81,83 There were no significant differences between the CCTA group and the usual care group in prescription or use of medications (aspirin, thienopyridines, or statins) at either the index visit or during 30 days of followup in the larger trial.81 There were also no differences between the two groups in the likelihood of having a followup visit with a cardiologist81,83 or with a primary care or other physician.83

Figure 10 Meta-analysis results for risk of invasive coronary angiography across studies comparing CCTA with usual care in patients with low to intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

This figure is a forest plot that displays risk for invasive coronary angiography (ICA) across studies comparing coronary computed tomography angiography with standard of care (SOC) in patients with intermediate pretest risk. The risk for ICA during 30- and 90-day followup appears to be greater for the SOC group as reported by two trials; however, there was no statistically significant difference between the two groups (RD 1, 95% CI -1 to 3 per 100 people, I2=0%).

Figure 11 Meta-analysis results for risk of revascularization across studies comparing CCTA with usual care in patients with low to intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference

This figure is a forest plot that displays risk for revascularization across studies comparing coronary computed tomography angiography with standard of care (SOC) in patients with intermediate pretest risk. The risk for revascularization during 30- and 90-day followup appears to be slightly more common in the SOC group, but there was no statistical difference between the groups as reported by two trials (RD 1, 95% CI 0 to 3 per 100 people, I2=0).

In the single observational study, the usual care group was significantly more likely to be referred for subsequent ICA (3.0% vs. 0.9%, adjusted OR 7.2, 95% CI 2.5 to 20.6, p<0.0001) or stress testing (20.6% vs. 3.7%, adjusted OR 6.1, 95% CI 3.8 to 9.8, p<0.001) compared with the CCTA group.107 There was no significant difference between the groups in the proportion receiving revascularization, either PCI or CABG (usual care 2.1% vs. CCTA 2.6%, adjusted OR 2.1, 95% CI 0.7 to 6.1, p=0.19).

###### Harms of Index Test and Consequences of Testing

The larger trial reported a similarly low incidence of bradycardia (presumed to be related to the medication to control heart rate) following CCTA (0.1%) and usual care (0.2%).81 The single observational study reported the overall median dose of radiation in the CCTA group only, which was 5.88 mSv (95% CI 5.2 to 6.4).107

###### Harms of Additional Testing, Differential Effectiveness or Safety in Subgroups

Not reported for low- to intermediate-risk patients.

#### Anatomic Tests Versus Functional Tests

##### CCTA Versus Exercise ECG

Two fair-quality studies, including one trial and one retrospective observational study, compared 64-slice dual source CCTA with exercise ECG in patients at low to intermediate pretest risk (see Appendix E and G for details).79,100 An additional publication was also found that provided data on extracardiac findings on CCTA from the observational study.106 Exercise ECG followed the Bruce protocol in the trial and a “standardized protocol” in the observational study. Patients enrolled in the RCT (N=562) presented to a single ED in Australia with acute, undifferentiated chest pain.79 This trial was supported by various grants (Queensland Emergency Medicine Research Foundation, Smart Future Fellowship Early Career Grant, and the Washington–Queensland Trans-Pacific Fellowship fund). In the observational study (N=498), patients with stable angina were referred from primary care to one of two clinics in Denmark based on geographic location, with one clinic using CCTA and the other exercise ECG as the primary initial test for CAD.100 The source of funding was not reported for this study. Within each study, patients in the CCTA and exercise ECG groups were similar in age, sex, and cardiac risk factors. Across the trial and the observational study, mean ages (52 vs. 55 years) and sex (female 42% vs. 48%) were similar, respectively; however, the two populations differed regarding symptoms and various cardiac risk factors, respectively, including typical angina (90% vs. 14%), hypertension (31% vs. 56%), hyperlipidemia (25% vs. 83%), and smoking (23% vs. 48%). In the observational study, the mean overall baseline risk score (according to Diamond and Forrester) was 26 ± 23 percent and did not differ between test groups; the trial did not report baseline risk scores for its population. Both studies reported outcomes at 12 months, and the trial also reported outcomes at 1 and 6 months. Methodological shortcomings included unclear randomization sequence generation and allocation concealment in the RCT and unclear blinding of outcomes assessment in both studies.

###### Clinical Outcomes

In the trial of ED patients, there were no deaths through 30 days and similar mortality rates between CCTA and exercise ECG groups through 12 months (0.6% vs. 0.4%, RD 0.2, 95% CI -1.0 to 1.4 per 100 people).79 None of the deaths were cardiac-related. At the index visit, MI diagnosis occurred at a similar rate in CCTA and exercise ECG groups (1.9% vs. 1.7%, RD 0.2, 95% CI -2.0 to 2.4 per 100 people) and there were no additional MIs through 30 days in either group.79 Unstable angina was similar between groups at the index visit (3.4% vs. 1.3%, RD 2.2, 95% CI -0.3 to 4.6 per 100 people) and no additional cases were reported through 30 days. Through 12-month followup, hospitalizations for any reason (10.2% vs. 10.8%) and ED visits for recurrent chest pain or cardiac symptoms (12.5% vs. 10.5%) were similar between groups. However, the length of stay in the ED was significantly shorter in the CCTA group compared with the exercise ECG group (13.5 vs. 19.7 hours; p=0.003). Outcomes in the observational study of outpatients were similar, with no deaths through 12 months, and no difference in the risk of MI between CCTA and exercise ECG groups (0% vs. 1.2%, unadjusted p=0.08) through the same followup period.100

###### Clinical Management

While the trial found that CCTA was associated with more ICA referrals through 12 months (9.0% vs. 2.3%, RD 4.8, 95% CI 0.8 to 8.9 per 100 people), the observational study reported the opposite, although the results did not reach statistical significance (17.5% vs. 22.7%; unadjusted RR 0.7, 95% CI 0.54 to 1.1). Through 12 months, CCTA was associated with significantly more people undergoing revascularization compared with exercise ECG (4.3% vs. 1.3%, RD 3.1, 95% CI 0.5 to 5.7 per 100 people)79 in the RCT. In terms of the patients who tested positive after CCTA (n=31) and exercise ECG (n=65), the observational study found that CCTA patients were more likely to undergo revascularization through 12 months (45% vs. 17%, unadjusted RR 2.7, 95% CI 1.4 to 5.2), including PCI (29% vs. 15%, unadjusted RR 1.9, 95% CI 0.9 to 4.2, p=NS) and CABG (16% vs. 2%, unadjusted RR 11, 95% CI 1 to 86).100 Additional noninvasive testing was done in significantly fewer CCTA patients in the observational study (4.8% vs. 13.4%, unadjusted RR 0.4, 95% CI 0.2 to 0.7).100

###### Harms of Index Test and Consequences of Testing

The mean radiation exposure with index CCTA was reported by both studies: 3.8 mSv (95% CI 3.5 to 4.1 mSv) in the trial79 and 7.5 ± 3.6 mSv in the observational study.100 The incidence of extracardiac findings on CCTA, as reported in a subsequent publication of the observational study,106 was 17.5 percent (44/251 patients). One-fourth of these patients (n=11) had additional testing (7 chest CT scans, 4 chest x-rays, 3 hepatic ultrasounds, 1 mammogram, 1 transesophageal echocardiogram, and 1 pulmonary scintigraphy), and in two patients malignancies were diagnosed and treated (one breast lumpectomy with adjuvant radiotherapy and one lung lobectomy).

###### Harm of Additional Testing

Radiation dose was also reported for index testing plus downstream diagnostic tests in a fair-quality retrospective cohort, with the CCTA group having significantly greater exposure compared with exercise ECG regardless of initial test result (range of means for positive, negative, and inconclusive test results: 7.8 to 13 vs. 0.7 to 5.4, p<0.001 for all comparisons), but not when downstream revascularization was considered in test-positive patients (28 [CCTA] vs. 32 [exercise ECG], p=0.61) (Appendix G, Table G4).

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of CCTA versus exercise ECG with regard to patient characteristics or other factors were provided in either study.

##### CCTA Versus SPECT

Two trials, one good quality77 and one fair quality,78 and one fair-quality observational study90 compared CCTA with SPECT in patients with low to intermediate risk (see Appendix E and G for details).

Goldstein et al. conducted two trials of patients presenting to the ED with acute chest pain; one trial published in 2007 enrolled 203 patients78 and the other, published in 2011, enrolled 749 patients77 (the enrollment periods did not overlap). Although Goldstein et al. 2007 specified that patients be at very low to low pretest risk and Goldstein et al. 2011 included patients at low to intermediate pretest risk, the median TIMI scores were identical in both studies (1.0). Because of this, and because demographics and outcomes were similar across both studies, they are analyzed here together as trials of low- to intermediate-risk patients. The 2007 trial collected data from a single ED,78 while the 2011 trial was multicenter (16 EDs).77 Both trials were conducted in the United States and received funding via research grants from the Minestrelli Advanced Cardiac Research Imaging78 and Bayer Pharmaceuticals.77 CCTA scans were obtained with a 64-slice CT in the earlier trial or a 64- to 320-slice CT scanner in the other. The 2007 trial employed exercise stress SPECT while the 2011 trial used either exercise or pharmacological stress, though the percentage of patients who received each type of stress was not reported. No patients had a history known CAD. Aside from the 2007 trial having slightly younger (mean age 48 vs. 51 years) and fewer male patients (43% vs. 57%) in the CCTA group than the SPECT group, the trials had similar baseline characteristics and cardiac risk factors (i.e., hypertension, dyslipidemia, diabetes, smoking) between groups. Mean age was 50 years in both trials, and males comprised 49.5 percent (2007) and 46.1 percent (2011) of patients. The 2007 trial had considerably more patients with a family history of CAD (41.6%) than did the 2007 study (30.3%). Outcomes were reported through 6 months, with complete followup of 97.0 and 89.7 percent, respectively. The 2011 trial had no apparent methodological shortcomings.77 However, the 2007 trial had several methodological shortcomings including unclear methods for allocation concealment, lack of analysis according to allocated treatment assignment, lack of blinded outcomes assessment, and significant baseline differences between groups that were not controlled for.78

Cheezum et al. retrospectively enrolled 252 consecutive patients who had undergone exercise stress (72%) or pharmacologic stress (28%) SPECT who were then matched by age and sex to 241 patients who underwent 64-slice CCTA. All patients were at intermediate risk presenting with chest pain (89%) or dyspnea (11%) to a single center in the United States (90.0% were outpatients).90 According to Diamond-Forrester, the overall pretest risk was very low (<5%) in 3 percent, low (5%–10%) in 14.5 percent, and intermediate (10%–90%) in 82.5 percent of the population. No patient had a history of CAD. The majority of patient characteristics were similar between groups; the mean age was 53 years, and 44.5 percent of patients were female. Patients were followed for a mean of 30 ± 7 months, with complete followup in 97.2 percent of patients. The only methodological shortcoming was lack of blinded outcomes assessment.

###### Clinical Outcomes

No patients died through 6 months followup in either trial. The 2007 trial reported no MI events in either group at any time through 6 months.78 In contrast, the 2011 trial reported a total of six MI events at the index visit; although the cause and precise timing of these events was not reported, they were not detected by resting ECG or serum biomarker testing within the first 4 hours of evaluation (otherwise the patients would have been excluded) and thus occurred or were detected after study enrollment. CCTA and SPECT patients had a similar risk of MI diagnosis at the index ED visit (0.3% vs. 1.5%, RD -1.2%, 95% CI -2.6 to 0.19); no additional MI events occurred in either group after the index visit through 6-month followup.77 The 2011 trial reported no repeat cardiovascular hospitalizations in either group through 6 months.77 Both trials reported a similar occurrence of repeat ED visits for cardiovascular causes between the CCTA and SPECT groups through 6 months (1.9 vs. 2.5 per 100 people; pooled RD -1, 95% CI -2 to 1) (Figure 12); these visits occurred in fewer patients in the 2011 trial (0.6% vs. 1.3%, RD -0.7, 95% CI -2.3 to 0.8)77 than in the 2007 trial (6% in both groups).78 Repeat cardiovascular office visits occurred in 2 percent of patients in both groups in the 2007 trial. Test results were normal in fewer CCTA patients than SPECT patients in both the 2011 trial (82.2% vs. 89.9%, RD -7.7%, 95% CI -12.8 to -2.6) and in the 2007 trial (68% vs. 95%, RD -27%, 95% CI -37 to -17). The 2007 trial reported that the diagnosis was “clinically correct” in a similar percentage of patients between groups (95% vs. 91%, RD 4%, 95% CI -3 to 11) according to either a definitive diagnosis made during ICA or by the occurrence of a major adverse cardiac event including cardiac death, acute MI, or unstable angina through 6-month followup.78 Clinical outcomes for test-positive versus test-negative patients were not reported by either trial.

Figure 12 Meta-analysis results for risk of repeat cardiovascular emergency department visits across studies comparing CCTA with SPECT in patients with low to intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference; SPECT = single-positron emission tomography

This figure is a forest plot that displays risk of repeat cardiovascular emergency department (ED) visits across studies comparing coronary computed tomography with single positron emission computed tomography in patients with low to intermediate pretest risk. The risk for repeat cardiovascular ED visits during 30- and 90-day followup was not differen between groups, as reported by two trials (pooled RD -1, 95% CI -2 to 1).

The observational study reported all events through a mean of 30 ± 7 months.90 There were no cardiovascular deaths in either group; 2.4 percent of patients in both groups died of other unknown causes through the followup period, as identified upon medical record review. The risk of the composite major adverse cardiac event outcome (cardiac death, MI, acute coronary syndrome, or revascularization) was similar between CCTA and SPECT patients (0.4% vs. 0.9%). Cardiovascular hospitalization occurred at a similar rate in the CCTA and SPECT groups (6.6% vs. 4.3%) as did cardiovascular ED visits (13.1% vs. 14.0%). Clinical outcomes were not stratified by test results.90

###### Clinical Management

ICA referral rates were similar between CCTA and SPECT groups in both trials at the index visit (7.6% vs. 5.5%, pooled RD 4, 95% CI -4 to 11 per 100 people, I^2^=71.7%) as well as through 6-month followup (0.7% vs. 1.3%, pooled RD -1, 95% CI -5 to 3 per 100 people, I^2^=71.1%) (Figure 13).77,78 In the smaller 2007 trial, of those referred for ICA the results showed a similar proportion of false positives (i.e., no obstructive CAD) between groups (CCTA 25% vs. SPECT 29%, respectively).78 At the index ED visit, 10.7 percent (2011 trial) and 24 percent (2007 trial) of patients in the CCTA group underwent additional testing with SPECT, while 1.8 percent (2011 trial) of patients in the SPECT group underwent additional testing with CCTA at this initial visit. Overall, additional noninvasive testing at the index visit occurred more commonly in the CCTA group, with the larger 2011 trial reporting 10.2 percent for CCTA and 0.9 percent for SPECT (RD 9.4, 95% CI 6.1 to 12.7 per 100 patients) and the smaller 2007 trial reporting 24 percent for CCTA and 0 percent for SPECT (RD 24 per 100 people, p<0.001). The smaller trial found that after the index visit through 6-month followup, additional SPECT was done similarly across both groups (1% vs. 3%).78 Across both studies, fewer CCTA patients were discharged home from the ED at the index visit (76.1% vs. 84.4%, pooled RD -8, 95% CI -13 to -3 per 100 patients, I^2^=0%) (Figure 14); in general, discharge occurred upon normal test results.77,78 Across both trials, CCTA and SPECT groups were similar regarding revascularization at the index ED visit (3.9% vs. 2.1%, pooled RD 2, 95% CI 0 to 4 per 100 people, I^2^=3.8%) and after the index visit through 6 months (0.5% vs. 0%, pooled RD 0, 95% CI 0 to 1 per 100 people, I^2^=3.8%) (Figure 15); this effect was consistent for both PCI and CABG evaluated separately at the index ED visit (PCI: 2.5%–3% vs. 1.0%–2.4%; CABG: 1.1%–2.0% vs. 0%) and through 6-month followup (PCI: 0.3%–1.0% vs. 0%; CABG: 0% in both groups).77,78

Figure 13 Meta-analysis results for risk of referral for invasive coronary angiography across studies comparing CCTA with SPECT in patients with low to intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference; SPECT = single-positron emission tomography

This figure is a forest plot that displays risk of referral for invasive coronary angiography (ICA) across studies comparing coronary computed tomography with single positron emission computed tomography in patients with low to intermediate pretest risk. The risk of referral for ICA was similar between groups at the index visit (pooled RD 4, 95% CI -4 to 11 per 100 people, I2=71.7%) as well as through 6 months of followup (pooled RD -1, 95% CI -5 to 3 per 100 people, I2=71.1%), as reported by two trials.

Figure 14 Meta-analysis results for discharge to home following index visit across studies comparing CCTA with SPECT in patients with low to intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference; SPECT = single-positron emission tomography

* Fewer patients were discharged home following initial testing with CCTA.

This figure is a forest plot that displays results for discharge to home follow index visit across studies comparing comparing coronary computed tomography (CCTA) with single positron emission computed tomography (SPECT) in patients with low to intermediate pretest risk. Across two studies, fewer CCTA patients were discharged home from the emergency department at the index visit (pooled RD -8, 95% CI -13 to -3 per 100 patients, I2=0%).

Figure 15 Meta-analysis results for risk of revascularization across studies comparing CCTA with SPECT in patients with low to intermediate pretest risk

CCTA = coronary computed tomography angiography; CI = confidence interval; RD = risk difference; SPECT = single-positron emission tomography

This figure is a forest plot that displays risk of revascularization across studies comparing coronary computed tomography with single positron emission computed tomography in patients with low to intermediate pretest risk. Across two trials, there was no difference between groups in need for revascularization at the index visit (pooled RD 2, 95% CI 0 to 4 per 100 people, I2=3.8%) or at followup through 6 months (pooled RD 0, 95% CI 0 to 1 per 100, I2=3.8%).

The observational study reported all events through a mean of 30 ± 7 months.90 CCTA patients were less likely than SPECT patients to undergo ICA (3.3% vs. 8.1%, RR 0.4, 95% CI 0.2 to 0.9) or additional testing with CCTA (0.4% vs. 4.7%, RR 0.1, 95% CI 0.01 to 0.7). Also, of those patients referred for ICA, there were fewer false positives (i.e., no obstructive CAD) after CCTA versus SPECT (33% vs. 60%). However, the groups were similar in regards to other types of noninvasive test utilization, including SPECT (5.7% vs. 6.0%), exercise echocardiography (1.2% vs. 0.9%), and exercise ECG (2.5% vs. 2.1%). Overall, CCTA patients were slightly less likely to need additional testing than SPECT patients although this difference did not reach statistical significance (11.5% vs. 17.0%, RR 0.7, 95% CI 0.4 to 1.1).90

###### Harms of Index Test and Consequences of Testing

There were no test complications in either group, as reported by the 2007 Goldstein trial.78 The 2011 Goldstein trial noted that radiation exposure at the index visit was significantly lower in the CCTA group compared with the SPECT group (median 11.5 vs. 12.8 mSv, p=0.02).77 In the observational study, incidental findings requiring further investigation following CCTA occurred in 7.1 percent of patients. In the 252 patients who received CCTA, pulmonary nodule (≥4 mm) was found in five patients; hepatic cyst in three patients; liver hemangioma, fatty liver, and mediastinal lymphadenopathy in two patients each; and pulmonary embolism, thoracic aortic aneurysm, esophageal thickening, and pleural thickening in one patient each.

###### Harms of Additional Testing

No harms of additional testing were reported in any of the three studies.

###### Harms of Additional Testing Differential Effectiveness or Safety in Subgroups

Not reported for this patient population.

##### Noncomparative Studies: Anatomical

###### Calcium Scoring

Three noncomparative studies of calcium scoring in patients at low to intermediate pretest risk reported on predictive accuracy. One study was conducted in an outpatient setting (N=422),111 one in the ED (N=263),122 and the setting was unclear in the third study of patients who were referred for invasive coronary angiography (N=2088).120 Of note, this latter study excluded patients who underwent elective revascularization within 60 days after index CT to control for procedure-driven events. Patients presenting to the ED were younger, more likely male, and, with the exception of smoking which was higher in this population, had fewer cardiac risk factors than patients in the other studies. Mean ages ranged from 47.3 to 58.6 years across studies and a slight majority of patients were male (49.3%–60%). In terms of test-positive patients, in all studies, the frequency of cardiac events was higher compared with test-negative patients. Across the two non-ED studies with mean followups of 2.5 years, the frequency of any cardiac event was 5 and 11 per 100 people (vs. 1 per 100 people in both), mortality was 2 per 100 people in both (vs. 0 and 1 per 100 people), and MI was 1 and 2 per 100 people (vs. 0 events); in the ED study, over 5 years followup, the frequency of any cardiac event was 20 per 100 people compared with no events (see Appendix F for details).

##### Noncomparative Studies: Functional

###### Stress Echocardiography

Two noncomparative studies of stress echocardiography in patients at low to intermediate pretest risk reported on predictive accuracy. One study was a conducted in an outpatient setting and used treadmill exercise only (N=7236)114 while the other was conducted in an ED and employed exercise (72%) or dobutamine (28%) as a stressor (N=108).110 The mean age of both study populations was 54 ± 12 years. Compared with the ED study, the outpatient study enrolled fewer females (30% vs. 50%), had more patients with hyperlipidemia (59% vs. 31%), and included patients with known CAD (10% vs. 0%). In terms of test-positive patients, regardless of setting, the frequency of cardiac events was greater compared with test-negative patients. In the outpatient setting, over a mean followup of 4.8 years, higher annualized mortality rates per person year of followup were reported: ischemia (0.53, 95% CI 0.33 to 0.80) and fixed wall motion abnormality (0.93, 95% CI 0.56 to 1.31) versus normal (0.30, 95% CI 0.24 to 0.37). In the ED setting, the frequency of any cardiac event over a mean followup period of 1 year was 75 per 100 people compared with no events (see Appendix F for details).

###### Stress ECG

Four noncomparative studies of stress ECG in patients at low to intermediate pretest risk reported on predictive accuracy. Three studies employed exercise stress (treadmill or bicycle)109,111,116 and one used either exercise or dobutamine stress.110 One study was conducted in an outpatient setting, one in an ED, and the setting was unclear in the remaining two studies. Samples sizes ranged from 108 to 2,977, mean ages ranged from 50 to 61 years, and the majority of populations were male (51%–60%). The proportion of patients with relevant cardiac risk factors varied across the studies. As compared with a negative result, a positive stress ECG was associated with a higher frequency of any cardiac event across three of the studies (N=5,353), with followup ranging from 1 to 3 years (2 to 30 per 100 people vs. 1 to 3 per 100 people). Of note the largest event rate (30%) in those who tested positive was seen in the study conducted in the ED at 1 year of followup. In the fourth study (N=422),111 the frequency of cardiac events over a mean 2.6 years was similar between groups (5 and 4 per 100 people) as was mortality (0 for both) and MI (1 per 100 people for both) (see Appendix F for details).

## Intermediate to High Pretest Risk of Coronary Artery Disease

### Key Points

Evidence for all primary outcomes and comparators not listed was insufficient to draw conclusions because of study limitations and/or imprecision in the observational study or because of lack of evidence.

#### CCTA Versus SPECT

- In intermediate- to high-risk patients, there was insufficient evidence from one small poor-quality trial with a mean 1.8 months of followup without any deaths or MIs found. Strength of evidence was low that cardiac hospitalizations occurred at a similar rate between groups. CCTA was associated with more revascularizations, as well as slightly more ICA referrals and slightly but not significantly less noninvasive cardiac imaging tests through the same followup period (low strength of evidence).

### Detailed Synthesis

A total of three studies were identified in populations with intermediate to high pretest risk of CAD and two (3 publications) included the following comparisons: PET versus SPECT (1 prospective observational)93,95 and CCTA versus SPECT (1 RCT)84 (Table 11); one additional noncomparative study reported on the predictive accuracy of stress echocardiography.112

Table 11 Summary of findings and strength of evidence: Intermediate to high pretest risk

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | PET vs. SPECT | 1 observational study (N=1113) | Hospital and outpatient centers | Through 24 months, mortality was more common in PET than SPECT patients (5.5% vs. 1.6%, unadjusted RR 3.4, 95% CI 1.6 to 7.2). Definitive conclusions are not possible^†^ | Insufficient
Mortality (all-cause) | CCTA vs. SPECT | 1 RCT (N=180) | Outpatient | There were no deaths in either group through a mean of 55 days followup. Definitive conclusions are not possible^†^ | Insufficient
Myocardial Infarction | PET vs. SPECT | 1 observational study (N=1113) | Hospital and outpatient centers | The frequency of MI was similar between groups: 1.1% (PET) vs. 1.2% (SPECT). Definitive conclusions are not possible^†^ | Insufficient
Myocardial Infarction | CCTA vs. SPECT | 1 RCT (N=180) | Outpatient | There were no MIs in either group through a mean of 55 days followup. Definitive conclusions are not possible^†^ | Insufficient
Invasive Coronary Angiography Referral | PET vs. SPECT | 1 observational study (N=1113) | Hospital and outpatient centers | PET was associated with significantly more ICA referrals through 90 days (11% vs. 4%, adjusted OR 5.03, 95% CI 1.04 to 24.43) and 24 months (15.0% vs. 6.7%, unadjusted RR 2.2, 95% CI 1.5 to 3.2, p<0.0001). Definitive conclusions are not possible^†^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. SPECT | 1 RCT (N=180) | Outpatient | Strength of evidence is low that difference in ICA referral was not found: CCTA vs. SPECT (13% vs. 8%, RD 5, 95% CI -4 to 14 per 100 people, p=NS) through a mean of 1.8 months | Low
Revascularization | PET vs. SPECT | 1 observational study (N=1113) | Hospital and outpatient centers | Revascularization was performed more frequently following PET at both 90 days (7% vs. 1.4%, RR 3.5, 95% CI 1.7 to 7.0) and 24 months (8% vs. 2.4%, RR 3.3, 95% CI 1.8 to 6.1). Definitive conclusions are not possible^†^ | Insufficient
Revascularization | CCTA vs. SPECT | 1 RCT (N=180) | Outpatient | CCTA was associated with more revascularizations than SPECT (8% vs. 1%, RD 6.6%, 95% CI 0.7%–12.5%) through a mean of 1.8 months. | Low
Percutaneous Coronary Intervention | PET vs. SPECT | 1 observational study (N=1113) | Hospital and outpatient centers | PCI was performed more frequently following PET through 90 days (4.6% vs. 1.4%, RR 3.2, 95% CI 1.5 to 7.1) and 24 months (5.7% vs. 1.8%, RR 2.9, 95% CI 1.5 to 5.7). Definitive conclusions are not possible^†^ | Insufficient
Coronary Artery Bypass Graft | PET vs. SPECT | 1 observational study (N=1113) | Hospital and outpatient centers | CABG was performed slightly more frequently following PET at the index visit (1.6% vs. 0.4%, RR, 4.6, 95% CI 1.007 to 21.4) and through 24 months (2.0% vs. 0.4%, RR 5.7, 95% CI 1.3 to 25.5). Definitive conclusions are not possible^†^ | Insufficient
Additional Testing | CCTA vs. SPECT | 1 RCT (N=180) | Outpatient | There is low-strength evidence that a difference in use of additional testing was not found. Fewer CCTA patients had additional noninvasive cardiac imaging test through a mean of 1.8 ± 1.1 months though the result was not significant (3% vs. 10%, RD -7, 95% CI -14 to 0.4 per 100 people). | Low
Hospitalization (Cardiac related) | CCTA vs. SPECT | 1 RCT (N=180) | Outpatient | CAD-related hospitalization was similar between the CCTA and SPECT groups (12% vs. 11%) through a mean of 1.8 months | Low

CABG = coronary artery bypass graft; CAD = coronary artery disease; CCTA = coronary computed tomography angiography; CI = confidence interval; ICA = invasive coronary angiography; NS = not statistically significant; PCI = percutaneous coronary intervention; PET = positron emission tomography; RCT = randomized controlled trial; RD = risk difference; RR = relative risk; SPECT = single-photon emission computed tomography

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Definitive conclusions are not possible because of study limitations and/or imprecision in observational studies or lack of data in RCTs.

#### Functional Tests Versus Functional Tests

##### PET Versus SPECT

One large, fair-quality, registry-based observational study with two publications compared PET with SPECT93,95 (see Appendix E and G for details); no other studies compared different types of functional testing in this population. The study enrolled 1,113 patients at intermediate to high pretest risk presenting with chest pain and/or dyspnea to hospitals and outpatient centers (42 sites) in the United States and Canada.93,95 The study was funded by grants from the National Heart, Lung, and Blood Institute and Bracco Diagnostics. Exercise stress testing was used alone (65%) or in combination with pharmacological stress (7%) in those undergoing SPECT; all patients evaluated with PET had pharmacological stress testing. Those receiving PET were slightly older (mean age 63 vs. 60 years), more likely to be female (59% vs. 51%) and Caucasian (80% vs. 68%), and with a greater prevalence of diabetes (41% vs. 31%), elevated cholesterol (65% vs. 60%), and hypertension (73% vs. 66%) compared with those who had SPECT. Angina (68% vs. 79%) was less common in those receiving PET and pretest CAD risk was slightly lower (probability of significant CAD 0.45 vs. 0.38 for SPECT) based on the Pryor method.93 Outcomes were reported through both 3 months93 and 24 months.95 Methodological shortcomings included lack of blinded outcomes assessment and significant baseline differences between groups.

###### Clinical Outcomes

Mortality through 24 months occurred in significantly more PET patients than in those tested with SPECT (5.5% vs. 1.6%, unadjusted RR 3.4, 95% CI 1.6 to 7.2), while MI occurrence was similar between groups (1.1% vs. 1.2%) through the same followup period.95 Clinical outcomes for test-positive versus test-negative patients were not reported.

###### Clinical Management

ICA referral rates were higher following PET compared with SPECT at both 90 days (11% vs. 4%, adjusted OR 5.03, 95% CI 1.04 to 24.43) and 24 months (15.0% vs. 6.7%, unadjusted RR 2.2, 95% CI 1.5 to 3.2, p<0.0001); however, there were fewer patients with false positives (i.e., no obstructive CAD) according to ICA results following PET (32.8% vs. 45.8%).95 The proportions of those who did not have obstructive disease at ICA who had a positive imaging study were 28.3 percent and 39.1 percent for PET and SPECT;93 differences did not reach statistical significance (p=NR). Overall, more PET patients received revascularization through both 90 days (7% vs. 1.4%, RR 3.5, 95% CI 1.7 to 7.0) and 24 months (8% vs. 2.4%, RR 3.3, 95% CI 1.8 to 6.1). PCI was performed more frequently following PET through 90 days (4.6% vs. 1.4%, RR 3.2, 95% CI 1.5 to 7.1, p=0.0020) and 24 months (5.7% vs. 1.8%, RR 2.9, 95% CI 1.5 to 5.7, p=0.0012); similarly, PET was associated with slightly more CABG procedures than SPECT at the index visit (1.6% vs. 0.4%, RR, 4.6, 95% CI 1.007 to 21.4, p=0.0299) and through 24 months (2.0% vs. 0.4%, RR 5.7, 95% CI 1.3 to 25.5, p=0.0103). Of those who had ICA (n=120), PCI frequency was similar for PET (30%) and SPECT (29%), but CABG was more common following PET versus SPECT (13% vs. 2.6%).95 At 90 days, post-test changes in use of aspirin (OR 1.14, 95% CI 0.79 to1.66), beta-blocker (OR 0.86, 95% CI 0.52 to 1.41), or lipid-lowering agents (OR 1.02, 95% CI 0.71 to 1.47) were similar in both groups after adjustment for baseline characteristics.

###### Harms of Index Test and Consequences of Testing

PET was associated with significantly lower exposure to radiation at the index visit compared with SPECT (mean 4.0 vs. 11.0 mSv, p<0.0001).95

###### Harms of Additional Testing

Compared with SPECT, the mean total radiation exposure over the 24-month study period was significantly lower following PET (6.0 vs. 11.6 mSv, p<0.0001).95 However, during followup, radiation exposure was higher in the group initially tested with PET than with SPECT (2.0 vs. 0.6 mSv, p <0.0001).95

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of PET versus SPECT with regard to patient characteristics or other factors were provided.

#### Anatomic Tests Versus Functional Tests

##### CCTA Versus SPECT

One poor-quality trial compared CCTA with SPECT in 180 patients at intermediate to high pretest risk presenting with stable chest pain and suspected CAD at one of two outpatient cardiology clinics in the United States (see Appendix E and G for details);84 no other studies compared anatomical and functional testing in this population. The trial was funded by grants from GE Healthcare and Vital Images. Outcomes for 98.3 percent of patients were reported at a mean of 1.8 ± 1.1 months. CCTA scans were obtained with a 64-detector row CT scanner and iodinated contrast. Rest-stress SPECT employed exercise or pharmacological stress, though the percentage of patients who received each type of stress was not reported. No patients had a history of MI, known CAD, or prior revascularization as per inclusion requirements. CCTA patients were slightly younger (mean age 56 vs. 59), more likely to be male (58% vs. 43%), and have typical angina (32% vs. 23%) than SPECT patients. The percentage of patients with atypical or noncardiac angina were similar across groups. CCTA patients were more likely to be at high pretest risk (33% vs. 24%), though there were no differences between groups in intermediate (63% vs. 67%) or low (4% vs. 9%) risk. Pretest Framingham risk estimates were similar between CCTA and SPECT groups (mean score 18.3 vs. 19.2). Methodological shortcomings included unclear methods for randomization and unclear allocation concealment, lack of blinded outcomes assessment, and significant baseline differences between groups. It was not clear whether both groups had similar length of followup.

###### Clinical Outcomes

All outcomes were reported at the mean followup of 1.8 ± 1.1 months, which correlates to approximately 1 to 3 months.84 No patient died or had an MI in either group. The frequency of CAD-related hospitalization was similar between the CCTA and SPECT groups (12% vs. 11%). Test results were positive (abnormal) in 30 percent of CCTA and 36 percent of SPECT patients; the remaining patients tested negative. There were no differences between groups in the mean change from baseline of any subscale of the Seattle Angina Questionnaire, including quality of life/disease perception, physical limitation, angina stability, angina frequency, and treatment satisfaction subscales. Clinical outcomes for test-positive versus test-negative patients were not reported.

###### Clinical Management

ICA referral rates were higher following CCTA versus SPECT (13% vs. 8%, RD 5, 95% CI -4 to 14 per 100 people) through a mean of 1.8 ± 1.1 months, though the difference did not reach statistical significance.84 Fewer CCTA patients had any additional noninvasive cardiac imaging test during the followup period but the result was not significant (3% vs. 10%, RD -7, 95% CI -14 to 0.4 per 100 people). However, CCTA patients were more likely to undergo subsequent revascularization (CABG or PCI) (8% vs. 1%, RD 6.6, 95% CI 0.7 to 12.5 per 100 people) during followup. Compared with baseline use, more CCTA patients used aspirin (within-person change from baseline: 22% vs. 8%, p=0.04) and statin (within-person change from baseline: 7% vs. -3.5%, p=0.03) during followup than SPECT patients, however there was no difference between groups in the within-person change in other medications (nonstatin lipid-lowering medications, beta-blockers, angiotensin-converting enzyme inhibitors, angiotensin receptor antagonists, or calcium channel blockers). Overall, initial testing with CCTA is more likely to result in coronary revascularization and more aggressive medical therapy than initial testing with SPECT.

###### Harms of Index Test and Consequences of Testing

CCTA was associated with significantly lower exposure to radiation at the index visit compared with SPECT (median IQR] 6.5 [5.1 to 13.3] vs. 13.3 [13.1 to 38.0] mSv, p<0.0001).

###### Harms of Additional Testing

Compared with SPECT, the median total radiation exposure over the 1.8-month followup period was significantly lower following CCTA (7.3 [IQR 5.1 to 13.7] vs. 13.3 [IQR 13.1 to 38.0] mSv, p<0.0001); however, during followup, radiation exposure was higher in the group initially tested with CCTA than with SPECT (0.8 vs. 0 mSv).

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of CCTA versus SPECT with regard to patient characteristics or other factors were provided.84

#### Noncomparative Studies: Functional

No noncomparative studies of anatomical testing in patients at intermediate to high risk met the inclusion criteria that reported outcomes of interest. For functional testing in this population, only studies of stress echocardiography were identified.

##### Stress Echocardiography

One noncomparative study of stress echocardiography in patients at low to intermediate pretest risk reported on predictive accuracy.112 This study enrolled 244 women with a mean age of 60 ± 10 years, and employed either exercise or pharmacological (70% dipyridamole; 30% dobutamine) stress in an outpatient setting. Atypical as opposed to typical angina was more common (63% vs. 36%). The frequency of any cardiac event over a mean of 36 months was substantially higher in those who had a positive compared with a negative result on stress echocardiography (33 vs. 2 per 100 people) (see Appendix F for details).

## High Pretest Risk of Coronary Artery Disease

### Key Points

Given the focus of the report on evaluation of testing based on pretest risk, results for the high pretest risk groups are presented here even though evidence from these groups was rated as insufficient.

#### SPECT Versus Exercise ECG

- In a small subgroup of high-risk outpatients, there was insufficient evidence that ICA referral was less common in SPECT compared with the exercise ECG group; data also suggest that additional noninvasive imaging following SPECT may be less common, though the sample size was too small to reach statistical significance (insufficient evidence).

### Detailed Synthesis

One RCT was identified in a population with high pretest risk of CAD and compared SPECT versus exercise ECG (Table 12).85

Table 12 Summary of findings and strength of evidence: High pretest risk

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | CCTA vs. usual care^†^ | 1 RCT (n=56 in high-risk subgroup) | ED | No deaths through 1 month in either group. Definitive conclusions are not possible.^‡^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. usual care^†^ | 1 RCT (n=56 in high-risk subgroup) | ED | At the index visit, fewer CCTA patients underwent ICA (75% vs. 93%, RD -18, 95% CI -37 to 0.8, p=0.0714). Definitive conclusions are not possible.^‡^ | Insufficient
Invasive Coronary Angiography Referral | SPECT vs. exercise ECG | 1 RCT (n=106 in high-risk subgroup) | Outpatient | ICA was less common following SPECT vs. exercise ECG through a mean of 22 months (44% vs. 85%, RD -41, 95% CI -58 to -24 per 100 people). Definitive conclusions are not possible.^‡^ | Insufficient
Revascularization | CCTA vs. usual care^†^ | 1 RCT (n=56 in high-risk subgroup) | ED | Revascularization frequencies at the index visit were: CCTA (43%) vs. usual care(50%) (RD -7, 95% CI -33 to 19 per 100 people, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient
Additional Testing | SPECT vs. exercise ECG | 1 RCT (n=106 in high-risk subgroup) | Outpatient | Additional testing through a mean of 22 months was: SPECT (0%) vs. ECG (5%), RD -5, 95% CI -10 to 1 per 100 people, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. usual care^†^ | 1 RCT (n=56 in high-risk subgroup) | ED | Hospitalization for acute coronary syndrome at the ED index visit were: CCTA (57%) vs. usual care (64%) (RD -07, 95% CI -33 to 18 per 100 people, p=NS). Definitive conclusions are not possible.^‡^ | Insufficient

CCTA = coronary computed tomography angiography; CI = confidence interval; ECG = electrocardiography; ED = emergency department; ICA = invasive coronary angiography; NS = not statistically significant; RCT = randomized controlled trial; RD = risk difference; SPECT = single-photon emission computed tomography

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Usual care consisted of a conventional diagnostic strategy using serial ECGs and cardiac biomarkers.

‡ Definitive conclusions are not possible because of lack of data from subgroup analyses in RCTs.

#### Functional Tests Versus Functional Tests

##### SPECT Versus Exercise ECG

One fair-quality trial compared SPECT with exercise ECG in high-risk patients (see Appendix E and G for details). No other studies compared different types of functional testing in this population.85 The trial included 457 patients referred for stable chest pain to a single outpatient center in the United Kingdom. Grants were received from Bristol-Myers Squibb and Northwick Park Cardiac Research as well as from an individual. Results were stratified based on pretest risk; 106 patients had high pretest likelihood of CAD. Patients underwent either SPECT (n=45) or exercise ECG (n=61). Treadmill exercise was employed in both groups and pharmacological stress was employed in some patients receiving SPECT. Groups were similar overall in age (mean age 59 years), sex (43.5% female), and cardiac risk factors but were not compared within the high-risk group. Baseline risk scores were not reported. Outcomes were reported for 96.9 percent of patients over a mean of 22 months. Methodological shortcomings included lack of allocation concealment and lack of blinded outcome assessment.

###### Clinical Outcomes

Not reported for high-risk patients.

###### Clinical Management

ICA referral through 22 months occurred in significantly fewer SPECT than exercise ECG patients (44% vs. 85%, RD -41, 95% CI -58 to -24 per 100 people). This trial used Bayesian methods to model post-test risk and reported that 77 percent of those with high pretest risk finished with high post-test risk (SPECT 56% vs. ECG 93%) and that those with a normal or low-risk test in either arm did not receive ICA. Additional noninvasive imaging was performed somewhat less frequently in patients who underwent SPECT compared with exercise ECG (0% vs. 5%, RD -5, 95% CI -10 to 1 per 100 people), but the difference was not statistically significant. Medication therapy was prescribed significantly more often in the SPECT group based on initial test results (56% vs. 10%, RD 46, 95% CI 29 to 62 per 100 people).

###### Harms of Index Test and Consequences of Index and Additional Testing; Differential Effectiveness or Safety in Subgroups

Not reported for high-risk patients.

##### Noncomparative Studies

No noncomparative studies of anatomical or functional noninvasive tests were identified that reported on predictive accuracy in high pretest risk patients in our specific population.

## Mixed Population: Pretest Risk Not Reported or Results Not Stratified by Risk

### Key Points

Evidence for all primary outcomes and comparators not listed was insufficient to draw conclusions because of study limitations and/or imprecision in the observational study or because of lack of evidence.

#### CCTA Versus Usual Care

- In a population presenting to the ED and not stratified by risk (1 fair-quality trial), there was low-strength evidence that a difference between groups was not found in 1-month MI or contrast-induced nephropathy.

#### SPECT Versus Exercise ECG

- In outpatients not stratified by risk, there was low-strength evidence from one trial that a difference was not found between groups in all-cause mortality or MI through a mean of 22 months, while SPECT was associated with fewer revascularizations than exercise ECG.

#### Exercise ECG Versus Nuclear MPI

- Low-strength evidence from a large administrative database of mixed risk-level Medicare outpatients suggested that 6-month mortality was similar between groups. Patients who underwent exercise ECG were less likely to undergo ICA through 6 months than those who were tested with MPI; revascularization (including CABG and PCI evaluated separately) was performed similarly between groups (low strength of evidence for both).

#### Stress Echocardiography Versus Nuclear MPI

- Low-strength evidence from a large administrative database of mixed risk-level Medicare outpatients suggested that 6-month mortality was similar between groups. Through 6 months, ICA referral was statistically less frequent in the stress echocardiography group, while additional noninvasive testing was slightly more common in this group (low strength of evidence). There were no apparent clinical differences between groups in referral for revascularization (including CABG and PCI evaluated separately) (low strength of evidence).

#### CCTA Versus Exercise ECG

- One fair-quality trial of ED patients at various pretest risk levels with 12 months followup found low-strength evidence that a difference between groups was not found in all-cause mortality or MI, while there was moderate-strength evidence that cardiac-related hospitalizations were less common in the CCTA group. CCTA was associated with more ICAs and more revascularizations (including PCI), though CABG was utilized similarly between groups (low strength of evidence).

#### CCTA Versus Nuclear MPI

- One large fair-quality database study of mixed-risk level Medicare outpatients provided low-strength evidence that all-cause mortality was similar through 6 months. CCTA patients were more likely to undergo ICA, additional noninvasive testing, and revascularization (including PCI and CABG evaluated separately) through 6 months (low strength of evidence).
- One fair-quality registry study provided low-strength evidence that revascularization was more common following CCTA through a median of 1.42 years; the setting was not reported.

### Detailed Synthesis

A total of 18 studies were identified in populations with mixed pretest risk of CAD or for whom risk was not reported. Nine studies included the following comparisons (1 administrative database study reported outcomes for 6 different test comparisons): CCTA versus usual care (1 RCT),75 exercise ECG (1 RCT,82 1 administrative database102), SPECT (1 prospective registry,104 1 administrative database97), nuclear MPI (1 prospective observational,105 1 administrative database102), and stress echocardiography (1 administrative database);102 SPECT versus exercise ECG (1 RCT,85 1 administrative database102); and stress echocardiography versus exercise ECG (1 RCT,86 1 prospective observational,96 1 administrative database102) and SPECT (1 administrative database102) (Tables 13–15). Four additional noncomparative studies (1 study reported data for 2 separate tests) reported on the predictive accuracy of stress echocardiography (2 studies),117,121 stress ECG (2 studies),115,117 and calcium scoring (1 study);124 and five studies were included for safety only following CT (2 prospective observational)98,99 and stress echocardiography (2 prospective,91,101 1 retrospective observational103).

Table 13 Summary of findings and strength of evidence: Mixed pretest risk—anatomical testing versus standard of care

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Myocardial infarction | CCTA vs. usual care^†^ | 1 RCT (N=266) | ED | There was low-strength evidence a difference in MI was not found. Through 30 days, no patient in the CCTA group had a myocardial infarction vs. one in the usual care group (0% vs. 0.8%). | Low
Harms of the Index Test | CCTA vs. usual care^†^ | 1 RCT (N=266) | ED | There were no cases of contrast-induced nephropathy between groups. | Low

CCTA = coronary computed tomography angiography; ED = emergency department; RCT = randomized controlled trial.

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Usual Care consisted of a conventional diagnostic strategy using serial ECGs and cardiac biomarkers.

Table 14 Summary of findings and strength of evidence: Mixed pretest risk—functional versus functional testing

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | SPECT vs. exercise ECG | 1 RCT (N=457) | Outpatient | There was low-strength evidence a difference in mortality was not found; frequency by 22 months was 0.8% vs. 0.9% for SPECT and exercise ECG, respectively. | Low
Mortality (all-cause) | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | Frequency of mortality was similar between groups through 6 months (0.78% vs. 1.28%, adjusted OR 0.93, 95% CI 0.83 to 1.04). | Low
Mortality (all-cause) | Stress echocardiography vs. exercise ECG | 1 observational study (n=5894 with no known CAD) | Outpatient | Through a mean of 34 months followup, adjusted rates stratified by low, intermediate, and high post-test risk were consistently and statistically lower in the exercise echocardiography group vs. the exercise ECG group for cardiac death (0.4% vs. 0.9%; 1.3% vs. 1.4%; 2.5% vs. 2.9%, p<0.006). Definitive conclusions are not possible.^†^ | Insufficient
Mortality (all-cause) | Stress echocardiography vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | 6-month mortality was similar between groups although the difference was statistically significant (0.95% vs. 0.78%; unadjusted RR 1.2, 95% CI 1.1 to 1.4). Definitive conclusions are not possible.^†^ | Insufficient
Mortality (all-cause) | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | All-cause mortality was similar for stress echocardiography and MPI through 6 months (0.95% vs. 1.28%, adjusted OR 1.00, 95% CI 0.90 to 1.10). | Low
Myocardial Infarction | SPECT vs. exercise ECG | 1 RCT (N=457) | Outpatient | There was low-strength evidence a difference in MI was not found through a mean of 22 months followup (0% vs. 0.5%). | Low
Invasive Coronary Angiography Referral | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | By 6 months, referral for ICA was less frequent following exercise ECG (9.04% vs. 12.13%, adjusted OR 0.72, 95% CI 0.70 to 0.75). | Low
Invasive Coronary Angiography Referral | Stress echocardiography vs. exercise ECG | 1 observational study (n=5894 with no known CAD) | Outpatient | Through a mean of 34 months, ICA referral was similar in patients at low (6% vs. 8%) and intermediate post-test risk (12% vs. 14%) but more frequency in stress echocardiography patients considered to be at high post-test risk (40% vs. 28%, p<0.0001). Definitive conclusions are not possible.^†^ | Insufficient
Invasive Coronary Angiography Referral | Stress echocardiography vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | Through 6 months, ICA referral was similar although the difference was statistically significant (9.50% vs. 9.04%, unadjusted RR 1.05, 95% CI 1.02 to 1.09). Definitive conclusions are not possible.^†^ | Insufficient
Invasive Coronary Angiography Referral | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | By 6 months, referral for ICA was less frequent following stress echocardiography (9.50% vs. 12.13%; adjusted OR 0.78, 95% CI 0.76 to 0.81). | Low
Revascularization | SPECT vs. exercise ECG | 1 RCT (N=457) | Outpatient | SPECT was associated with fewer revascularizations that exercise ECG (10.8% vs. 17.9%, RD -7.1, 95% CI -13.6 to -0.6 per 100 people). | Low
Revascularization | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | Revascularization through 6 months was similar between groups although the difference was statistically significant (4.31% vs. 4.59%, respectively; adjusted OR 0.90, 95% CI 0.85 to 0.94). | Low
Revascularization | Stress echocardiography vs. exercise ECG | 1 observational study (n=5894 with no known CAD) | Outpatient | Through a mean of 34 months, revascularization was performed in a similar percentage of stress echocardiography patients at low (5% vs. 7%) and intermediate post-test risk (8% vs. 9%) but in more stress echocardiography patients considered to be at high post-test risk (29% vs. 20%). Definitive conclusions are not possible.^†^ | Insufficient
Revascularization | Stress echocardiography vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | Through 6 months, the frequency of revascularization was similar between groups (4.22% vs. 4.31%). Definitive conclusions are not possible.^†^ | Insufficient
Revascularization | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | Revascularization through 6 months was similar between groups although the difference was statistically significant (4.22% vs. 4.59%, adjusted OR 0.93, 95% CI 0.88 to 0.98). | Low
Percutaneous Coronary Intervention | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | Through 6 months, PCI was similar between groups although the difference was statistically meaningful (2.57% vs. 3.37%, adjusted OR 0.72, 95% CI 0.68 to 0.77). | Low
Percutaneous Coronary Intervention | Stress echocardiography vs. exercise ECG | 1 observational study (n=5894 with no known CAD) | Outpatient | Through a mean of 34 months, PCI was performed in a similar percentage of stress echocardiography patients at low (4% vs. 6%) and intermediate post-test risk (5% vs. 6%) but in more stress echocardiography patients considered to be at high post-test risk (22% vs. 12%). Definitive conclusions are not possible.^†^ | Insufficient
Percutaneous Coronary Intervention | Stress echocardiography vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | Through 6 months, there was a similar frequency of PCI between groups (2.61% vs. 2.57%). Definitive conclusions are not possible.^†^ | Insufficient
Percutaneous Coronary Intervention | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | Through 6 months, PCI referral occurred at a similar rate between groups although the difference was statistically significant (2.61% vs. 3.37%, adjusted OR 0.76, 95% CI 0.72 to 0.81). | Low
Coronary Artery Bypass Graft | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | Through 6 months, CABG was done similarly between groups although the difference was statistically significant (1.82% vs. 1.29%, adjusted OR 1.37, 95% CI 1.26 to 1.49). | Low
Coronary Artery Bypass Graft | Stress echocardiography vs. exercise ECG | 1 observational study (n=5894 with no known CAD) | Outpatient | Through a mean of 34 months, CABG was performed in a similar percentage of stress echocardiography patients at low (1% vs. 2%) and intermediate post-test risk (3% in both groups) but in fewer stress echocardiography patients considered to be at high post-test risk (6% vs. 18%). Definitive conclusions are not possible.^†^ | Insufficient
Coronary Artery Bypass Graft | Stress echocardiography vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | CABG was performed similarly between groups through 6 months (1.69% vs. 1.82%). Definitive conclusions are not possible.^†^ | Insufficient
Coronary Artery Bypass Graft | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | Through 6 months, CABG referral occurred at a similar rate between groups although the difference was statistically significant (1.69% vs. 1.29%, adjusted OR 1.40, 95% CI 1.29 to 1.52). | Low
Additional Testing | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | Referral for additional testing was significantly more frequent for exercise ECG than MPI in the 6 months after initial testing (19.34% vs. 3.22%, adjusted OR 7.46, 95% CI 7.16 to 7.77). | Low
Additional Testing | Exercise echocardiography vs. exercise ECG | 1 RCT (N=111) | Various | Stress echocardiography was associated with significantly less additional testing compared with exercise ECG (3.5% vs. 24.1%; RD=22, 95% CI -34 to -10). Definitive conclusions are not possible.^†^ | Insufficient
Additional Testing | Stress echocardiography vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | Additional noninvasive testing through 6 months was more common following stress (5.57% vs. 19.34%, unadjusted RR 0.29, 95% CI 0.28 to 0.30); this was driven by significantly fewer referrals for MPI (4.03% vs. 16.47%; unadjusted RR 0.24, 95% CI 0.24 to 0.25). Definitive conclusions are not possible.^†^ | Insufficient
Additional Testing | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | Referral for additional testing was somewhat more frequent for stress echocardiography than MPI in the 6 months after initial testing (5.57% vs. 3.22%; adjusted OR 1.92, 95% CI 1.83 to 2.0). | Low
Hospitalization (Cardiac related) | Exercise ECG vs. nuclear MPI | 1 observational study (N=193,406 Medicare) | Outpatient | Similar very low frequency of hospitalization for acute MI through 6 months (0.32% vs. 0.43%). Definitive conclusions are not possible.^†^ | Insufficient
Hospitalization (Cardiac related) | Stress echo vs. exercise ECG | 1 observational study (N=141,667 Medicare) | Outpatient | Similar very low frequency of hospitalization for acute MI through 6 months (0.32% in both groups). Definitive conclusions are not possible.^†^ | Insufficient
Hospitalization (Cardiac related) | Stress echocardiography vs. nuclear MPI | 1 observational study (N=212,947 Medicare) | Outpatient | Hospitalization for acute MI through 6 months was similar between groups although the difference was statistically significant (0.32% vs. 0.43%, adjusted OR 0.83, 95% CI 0.70 to 0.98). Definitive conclusions are not possible.^†^ | Insufficient

CABG = coronary artery bypass graft; CAD = coronary artery disease; CI = confidence interval; ECG = electrocardiography; ICA = invasive coronary angiography; MI = myocardial infarction; MPI = myocardial perfusion imaging; NS = not statistically significant; OR = odds ratio; PCI = percutaneous intervention; RCT = randomized controlled trial; RD = risk difference; SPECT = single-photon emission computed tomography

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Definitive conclusions are not possible because of study limitations and/or imprecision in observational studies or lack of data in RCTs.

Table 15 Summary of findings and strength of evidence: Mixed pretest risk—anatomical versus functional testing

Outcome^*^ | Comparison | Number of Studies (N) | Setting | Conclusions | Strength of Evidence
Mortality (all-cause) | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | There is low-strength evidence that no difference was found in all-cause mortality between groups through 12 months (0.4% in both groups). | Low
Mortality (all-cause) | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | Through 6 months, mortality was similar between groups although the results were statistically significant (1.05% vs. 0.78%, unadjusted RR 1.3, 95% CI 1.08 to 1.68). Definitive conclusions are not possible.^†^ | Insufficient
Mortality (all-cause) | CCTA vs. SPECT | 1 observational study (N=9690) | NR | The 9-month risk of MI was similar in both groups (0.4% vs. 0.6%). Definitive conclusions are not possible.^†^ | Insufficient
Mortality (all-cause) | CCTA vs. nuclear MPI | 1 observational study (N=141,163 Medicare) | Outpatient | No difference between groups through 6 months (1.05% vs. 1.28%, adjusted OR 1.11, 95% CI 0.88 to 1.38). | Low
Mortality (all-cause) | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | 6-month mortality was similar between groups (0.95% vs. 1.05%, unadjusted RR 1.1 95% CI 0.9 to 1.4). Definitive conclusions are not possible.^†^ | Insufficient
Myocardial Infarction | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | There is low-strength evidence that no difference was found through 12 months in the incidence of MI between groups (0.41% vs. 0.82%, RD -0.4, 94% CI -1.8 to 1.0 per 100 people). | Low
Invasive Coronary Angiography Referral | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | CCTA was associated with higher referral rates for ICA through 12 months, though the difference was not statistically significant (27.2% vs. 20.8%; RD 6.3, 95% CI -1.2 to 13.9 per 100 people, p=0.1011). | Low
Invasive Coronary Angiography Referral | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | CCTA was associated with higher referral rates for ICA through 6 months (22.9% vs. 9.0%, unadjusted RR 2.5, 95% CI 2.4 to 2.7). Definitive conclusions are not possible.^†^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. SPECT | 2 observational studies (N=12,132) | NR | Results were inconsistent between studies, with one reporting that ICA was less common in CCTA patients through 9 months (6.2% vs. 9.5%, OR 1.61, 95% CI 1.32 to 1.97), while the other study found no difference between groups (10.6% vs. 10.2%) through 6 months. Definitive conclusions are not possible.^†^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. nuclear MPI | 1 observational study (N=1856) | NR | Groups were similar regarding ICA referral through a median of 1.42 years followup (31% vs. 33%). Definitive conclusions are not possible.^†^ | Insufficient
Invasive Coronary Angiography Referral | CCTA vs. nuclear MPI | 1 observational study (N=141,163 Medicare) | Outpatient | Higher 6-month ICA referral following CCTA compared with MPI was reported (22.94% vs. 12.13%, adjusted OR 2.19, 95% CI 2.08 to 2.32). | Low
Invasive Coronary Angiography Referral | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | ICA was more common following CCTA through 6 months (22.9% vs. 9.5%, unadjusted RR 2.4, 95% CI 2.3 to 2.5). Definitive conclusions are not possible.^†^ | Insufficient
Revascularization | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | Through 12 months there was greater risk of revascularization with CCTA compared with exercise ECG (15.2% vs. 7.7%, RD 7.5, 95% CI 1.9 to 13.0 per 100 people). | Low
Revascularization | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | CCTA was associated with more revascularization procedures through 6 months (11% vs. 4.3%, unadjusted RR 2.65, 95% CI 2.47 to 2.84). Definitive conclusions are not possible.^†^ | Insufficient
Revascularization | CCTA vs. SPECT | 2 observational studies (N=12,132) | NR | CCTA and SPECT groups were similar regarding subsequent revascularization (2.1%–6.2% vs. 1.6%–5.9%) during 6 to 9 months followup. Definitive conclusions are not possible.^†^ | Insufficient
Revascularization | CCTA vs. nuclear MPI | 1 observational study (N=1856) | NR | Revascularization was more common following CCTA than SPECT through a median of 1.42 years (% NR, adjusted OR 1.62, 95% CI 1.20 to 2.18). | Low
Revascularization | CCTA vs. nuclear MPI | 1 observational (N=141,163 Medicare) | Outpatient | Revascularization was higher in CCTA than MPI at 6 months (11.41% vs. 4.59%, adjusted OR 2.76, 95% CI 2.56 to 2.98). | Low
Revascularization | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | Revascularization was more common in the 6 months following CCTA compared with stress echocardiography (11.4% vs. 4.2%, unadjusted RR 2.7, 95% CI 2.5 to 2.9). Definitive conclusions are not possible.^†^ | Insufficient
Percutaneous Coronary Intervention | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | CCTA was associated with a significantly higher risk of PCI through 12 months (11.9% vs. 4.9%, RD 7, 95% CI 2 to 12 per 100 people). | Low
Percutaneous Coronary Intervention | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | Through 6 months, CCTA patients had more PCI procedures (7.9% vs. 2.6%, unadjusted RR 3.05, 95% CI 2.80 to 3.33). Definitive conclusions are not possible.^†^ | Insufficient
Percutaneous Coronary Intervention | CCTA vs. SPECT | 2 observational studies (N=12,132) | NR | Both studies found no difference between CCTA and SPECT groups in the frequency of PCI (0.1%–3.9% vs. 0.1%–4.0%) during 6 to 9 months followup. Definitive conclusions are not possible.^†^ | Insufficient
Percutaneous Coronary Intervention | CCTA vs. nuclear MPI | 1 observational study (N=141,163 Medicare) | Outpatient | PCI rates were higher in CCTA patients through 6 months followup (7.85% vs. 3.37%, adjusted OR 2.49, 95% CI 2.28 to 2.72). | Low
Percutaneous Coronary Intervention | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | By 6 months, PCI was more common in the CCTA group (7.85% vs. 2.61%, unadjusted RR 3.01 95% CI 95% CI 2.77 to 3.27). Definitive conclusions are not possible.^†^ | Insufficient
Coronary Artery Bypass Graft | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | Through 12 months, there was no difference between groups in CABG (3.3% vs. 2.9%, RD 0.00, 95% CI -0.03 to 0.04 per 100 people). | Low
Coronary Artery Bypass Graft | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | There was only a small difference between groups in the risk for CABG through 6 months (3.7% vs. 1.8%; unadjusted RR 2.04 95% CI 1.80 to 2.30). Definitive conclusions are not possible.^†^ | Insufficient
Coronary Artery Bypass Graft | CCTA vs. SPECT | 2 observational studies (N=12,132) | NR | Both studies found no difference between CCTA and SPECT groups in the need for CABG (0.7%–2.3% vs. 0.5%–1.9%) during 6 to 9 months followup. Definitive conclusions are not possible.^†^ | Insufficient
Coronary Artery Bypass Graft | CCTA vs. nuclear MPI | 1 observational study (N=141,163 Medicare) | Outpatient | CABG was more common in CCTA patients through 6 months followup (3.71% vs. 1.29%, adjusted OR 3.00, 95% CI 2.63 to 3.42). | Low
Coronary Artery Bypass Graft | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | By 6 months, CABG had been performed somewhat more frequently in the CCTA group (3.71% vs. 1.69%, unadjusted RR 2.19, 95% CI 1.94 to 2.47). Definitive conclusions are not possible.^†^ | Insufficient
Additional Testing | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | CCTA resulted in fewer additional noninvasive cardiac tests through 12 months (2.4% vs. 31.3%, RD -29, 95% CI -37 to -23 per 100 people). | Moderate
Additional Testing | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | There was less additional noninvasive testing in CCTA patients through 6 months (5% vs. 19%; unadjusted RR 0.26, 95% CI 0.23 to 0.28). Definitive conclusions are not possible.^†^ | Insufficient
Additional Testing | CCTA vs. SPECT | 2 observational studies (N=12,132) | NR | Results were inconsistent between studies, with one study showing no difference between groups in the 9-month risk of additional testing (0.8% vs. 0.7%), and the other study showing that CCTA patients were more likely to undergo additional testing through 6 months (7.5% vs. 1.4%, OR 0.17, 95% CI 0.13 to 0.22). Definitive conclusions are not possible.^†^ | Insufficient
Additional Testing | CCTA vs. nuclear MPI | 1 observational study (N=141,163 Medicare) | Outpatient | Any additional noninvasive testing through 6 months was more common in CCTA than MPI patients (4.98% vs. 3.22%, adjusted OR 1.52, 95% CI 1.37 to 1.69). | Low
Additional Testing | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | Additional noninvasive testing through 6 months was similar between groups, although the difference was statistically significant (4.98% vs. 5.57%, unadjusted RR 0.89, 95% CI 0.81 to 0.98). Definitive conclusions are not possible.^†^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | Hospitalization for cardiac causes occurred less frequently in the CCTA group (0.8% vs. 6.9%, RD -6.1, 95% CI -9.5 to -2.7 per 100 people) through 12 months. | Moderate
Hospitalization (Cardiac related) | CCTA vs. exercise ECG | 1 observational study (N=69,883 Medicare) | Outpatient | Through 6 months, hospitalization for acute MI occurred at a similar rate across groups although the results were statistically significant (0.19% vs. 0.32%, unadjusted RR 0.60, 95% CI 0.37 to 0.99). Definitive conclusions are not possible.^†^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. SPECT | 1 observational study (N=9690) | NR | The 9-month rate of hospitalization for cardiovascular causes was similar in the CCTA and SPECT patients (4.2% vs. 4.1%). Definitive conclusions are not possible.^†^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. nuclear MPI | 1 observational study (N=141,163 Medicare) | Outpatient | Hospitalization for acute MI through 6 months was similar between groups, though the results were statistically significant (0.19% vs. 0.43%, adjusted OR 0.60, 95% CI 0.37 to 0.98). Definitive conclusions are not possible.^†^ | Insufficient
Hospitalization (Cardiac related) | CCTA vs. stress echocardiography | 1 observational study (N=89,424 Medicare) | Outpatient | Through 6 months, hospitalization for acute MI slightly was similar between groups (0.19% vs. 0.32%, unadjusted RR 0.61, 95% CI 0.37 to 1.0). Definitive conclusions are not possible.^†^ | Insufficient
Harms of Index Test | CCTA vs. exercise ECG | 1 RCT (N=500) | ED | There were no complications associated with either test (specifics not reported). Definitive conclusions are not possible.^†^ | Insufficient
Harms of Index Test | CCTA vs. nuclear MPI | 1 observational study (N=1856) | NR | There was no difference in the risk of adverse events during the test between CCTA and MPI patients (0.5% vs. 0.9%); no other details were reported. Definitive conclusions are not possible.^†^ | Insufficient

CABG = coronary artery bypass graft; CAD = coronary artery disease; CCTA = coronary computed tomography angiography; CI = confidence interval; ECG = electrocardiography; ED = emergency department; ICA = invasive coronary angiography; MI = myocardial infarction; MPI = myocardial perfusion imaging; NS = not statistically significant; OR = odds ratio; PCI = percutaneous intervention; RCT = randomized controlled trial; RD = risk difference; RR = relative risk; SPECT = single-photon emission computed tomography

* Primary outcomes not listed in this table had no evidence and thus insufficient strength of evidence.

† Definitive conclusions are not possible because of study limitations and/or imprecision in observational studies or lack of data in RCTs.

#### Anatomic Tests Versus Standard of Care

##### CCTA Versus Standard of Care

One fair-quality RCT compared CCTA with usual care in patients combined across three pretest risk levels (low 37%, intermediate 42%, high 21%) (see Appendix E and G for details). Only those results not stratified by pretest risk level (which are reported in the appropriate sections) are reported here. The trial enrolled 266 patients presenting with chest pain to a single ED in South Korea.75 Study funding was not reported. CCTA was performed with 64-slice scanning (n=133) and usual care consisted of a conventional diagnostic strategy (e.g., serial ECGs and cardiac biomarkers) (n=133). Subsequent diagnostic tests were done at the discretion of the treating physician. Overall, groups were similar in age (mean 57.5 years), sex (38.7% female), and cardiac risk factors. Baseline risk scores were not reported. Outcomes were reported at the index visit and at 1-month followup. Methodological shortcomings included unclear randomization method, allocation concealment, and blinding of outcomes assessment.

###### Clinical Outcomes

Through 1-month followup, no patients in the CCTA group and one patient in the usual care group experienced a nonfatal MI (0% vs. 0.8%, p=0.32).75

###### Clinical Management

Ten percent of CCTA patients underwent additional noninvasive stress testing after the index visit and through 30 days. In the usual care group, noninvasive testing was done at the discretion of the physician in 50 percent of patients at the index visit. Because this is a first test in the usual care patients, it is not considered “additional” noninvasive testing.75

###### Harms of Index Test and Consequences of Testing

No incidence of contrast-induced nephropathy was reported in either group. Following imaging with CCTA, two patients (1.5%) developed a diffusing, irritating skin rash which resolved spontaneously; radiation exposure averaged 12.5 ± 2.0 mSv in this group (not reported for the usual care group).75

###### Harms of Additional Testing, Differential Effectiveness or Safety in Subgroups

Not reported for this population.

#### Functional Tests Versus Functional Tests

##### SPECT Versus Exercise ECG

One fair-quality RCT compared SPECT with exercise ECG and enrolled patients at various pretest risk levels (low 16%, intermediate 61%, high 23%) presenting with stable chest pain at a single outpatient center in the United Kingdom (see Appendix E and G for details).85 Only those results not stratified by pretest risk level (which are reported in the appropriate sections) are reported here. This trial was funded by unrestricted grants from Bristol-Myers Squibb Medical Imaging, Northwick Park Cardiac Research Fund, and from an individual. A symptom limited Bruce or modified Bruce exercise protocol was used in 62 percent of patients undergoing SPECT (n=250) and 100 percent of patients undergoing ECG testing (n=207); the remaining SPECT patients received dipyridamole infusion unless there was a contraindication in which case dobutamine stress was performed. The two groups were similar with regard to mean age (59 years) and sex (44% female), but more patients in the SPECT group were Caucasian (56% vs. 47%) and were more likely to have hypertension (53% vs. 46%) and diabetes (19% vs. 14%). The pretest likelihood of CAD differed substantially in subjects undergoing SPECT versus exercise ECG: low (11% vs. 21%), intermediate (71% vs. 49%), and high (18% vs. 29%). Baseline risk scores were not reported. Outcomes were reported for 96.9 percent of patients over a mean of 22 months. Methodological concerns included lack of concealed allocation and uncertainty regarding blinded assessment of outcomes.

###### Clinical Outcomes

Overall mortality was very low in both SPECT and exercise ECG groups through a mean of 22 months followup (0.8% vs. 0.9%). MI through the same followup occurred in no SPECT patients and one exercise ECG patient (0% vs. 0.5%); this event was fatal.85

###### Clinical Management

ICA referral was significantly less following SPECT (16% vs. 47%; RD -30.9, 95% CI -39.2 to -22.7) and results showed false positives (i.e., no obstructive disease) in fewer SPECT patients (17.1% vs. 36.7%). Fewer patients who had SPECT as the index test underwent revascularization compared with those who had an exercise ECG as their index test (10.8% vs. 17.9%, RD -7.1, 95% CI -13.6 to -0.6 per 100 people).85

###### Harms of Index Test and Consequences of Testing, Harms of Additional Testing, Differential Effectiveness or Safety in Subgroups

Not reported in this population.

##### Exercise ECG Versus Nuclear MPI

One large, fair-quality administrative database study was conducted using a 20 percent random sample of Medicare claim records from 2006 to 2008 (N=282,830);102 patients could receive one of four tests including exercise ECG (n=61,063) and MPI (n=132,343) (see Appendix E and G for details). Included claims were limited to those in an outpatient setting for patients aged 66 years or older; no patient had a history of known CAD (within the previous 9 months) or prior MI or revascularization (within the previous 12 months). This study was designed to evaluate CCTA, but the data provided allowed some comparisons across the other tests. Current Procedural Terminology (CPT) codes that included both and stress (exercise and pharmacological) ECG and stress SPECT and PET were provided; test details that included information regarding how a test was chosen for a given patient were not reported. Pretest CAD risk and other baseline risk scores were also not reported. Exercise ECG patients were slightly younger than MPI patients (mean age 73.1 vs. 75.7 years), slightly less likely to be female (49.0% vs. 54.5%), and had significantly fewer risk factors and comorbidities. Outcomes were reported at 6 months and adjusted for confounding baseline variables. This study was funded by the American Heart Association. Methodological limitations included lack of blinded outcomes assessment and significant baseline differences between groups, although these differences were controlled for with the adjusted risk estimates.

###### Clinical Outcomes

The 6-month risk of death from any cause was similar between exercise ECG and MPI (0.78% vs. 1.28%, adjusted OR 0.93, 95% CI 0.83 to 1.04), as was the risk of hospitalization for acute MI (0.32% vs. 0.43%, adjusted OR 0.86, 95% CI 0.72 to 1.03).102 Clinical outcomes for test-positive versus test-negative patients were not reported.

###### Clinical Management

Lower 6-month ICA referral rates were reported following exercise ECG compared with MPI (9.04% vs. 12.13%, adjusted OR 0.72, 95% CI 0.70 to 0.75). Any additional noninvasive testing through 6 months was significantly more common in ECG versus MPI patients (19.34% vs. 3.22%, adjusted OR 7.46, 95% CI 7.16 to 7.77); this difference was statistically significant for all types of noninvasive tests employed (e.g., MPI, stress echocardiography, and exercise ECG) except CCTA. The need for any revascularization through 6 months was similar between groups although the difference was statistically meaningful (4.31% vs. 4.59%, respectively; adjusted OR 0.90, 95% CI 0.85 to 0.94); this trend held true for both PCI (2.57% vs. 3.37%, adjusted OR 0.72, 95% CI 0.68 to 0.77) and CABG (1.82% vs. 1.29%, adjusted OR 1.37, 95% CI 1.26 to 1.49). Although fewer patients underwent ICA in the exercise ECG group, they were significantly more likely to receive revascularization following ICA than MPI patients (46.49% vs. 37.53%, adjusted OR 1.30, 95% CI 1.21 to 1.40).

###### Harms of Index Test and Consequences of Testing and Harms of Additional Testing

No harms related to either the index or additional testing were reported.

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of nuclear MPI and exercise ECG with regard to patient characteristics or other factors were provided, however the database study focused on Medicare beneficiaries (age ≥ 66 years).102

##### Stress Echocardiography Versus Exercise ECG

One poor-quality RCT86 and two observational studies, one fair quality102 and one poor quality,96 were identified that compared stress echocardiography to exercise ECG (see Appendix E and G for details).

The RCT compared dobutamine (n=47) and exercise stress echocardiography (n=57), and exercise ECG (n=54) in women with chest pain who had no history of cardiac disease but who had at least two cardiac risk factors.86 Patients were recruited from family medicine, EDs, and inpatient cardiology (number of sites and locations not reported) and 90.3 percent were followed for a mean of 28.1 ±14.2 months. Ages were similar across groups (mean 54.5 years) as was the proportion of Caucasians (97.5%). Patients in the stress echocardiography groups were more likely to have hypertension than those in the exercise ECG group (53.8% vs. 38.9%); all other relevant cardiac risk factors were similar. Pretest CAD risk and other baseline risk scores were not reported. This trial was funded in part by a clinical research grant from the American Society of Echocardiography. Methodological shortcomings included lack of information on random sequence generation and allocation concealment, lack of information on patients who withdrew after consent, potentially clinically significant baseline differences between groups, and failure to control for possible confounding.

One poor-quality prospective observational study compared exercise stress echocardiography with exercise ECG in patients with suspected or known CAD.96 Results were stratified according to history of CAD; therefore, only data for the 5,894 (77.0%) patients without known CAD are included in this report. However, demographics, risk factors, and test details were not reported separately for this subgroup. The study was conducted in the United States at a single large cardiac referral center; choice of test was made according to physician preference and institutional practice. Funding was received from the American Society of Echocardiography and the National Heart Foundation of Australia. Complete followup data were available for all patients for a mean of 33.6 months; however, followup periods differed between the echocardiography and ECG groups (mean 38.4 ± 24 vs. 30 ± 24 months, respectively). Overall, groups were similar in mean age (62 years) and sex (41% female) and there were no statistically significantly differences between groups in clinical risk factors. Twelve percent of the patients were considered low risk, 59 percent intermediate, and 29 percent high risk when pretest clinical risk was defined as predicted annualized risk of death or MI. Methodological shortcomings included lack of information regarding blinded outcome assessment and whether baseline risks were similar in the subset of patients with no history of CAD, and unclear reporting of loss-to-followup.

A large, fair-quality administrative database study was conducted using a 20 percent random sample of Medicare claim records from 2006 to 2008 (N=282,830).102 Patients could receive one of four tests, including stress echocardiography (n=80,604) and exercise ECG (n=61,063), and the followup period was 6 months. Pretest CAD risk and other baseline risk scores were not reported. Included claims were limited to an outpatient setting for patients aged 66 years or older; no patient had a history of known CAD (within the previous 9 months) or prior MI or revascularization (within the previous 12 months). This study was designed to evaluate CCTA, but the data provided allowed some comparisons across the other tests. No test details were reported to include information regarding how a test was chosen for a given patient; only CPT codes that included both stress echocardiography and exercise and pharmacological stress ECG were provided. Both groups were similar in regards to mean age (73.5 years), the proportion of Caucasian patients (88.3%), and relevant cardiac risk factors; however, the stress echocardiography group included more women (57.5% vs. 49.0%). This study was funded by the American Heart Association. Methodological limitations included lack of blinded outcomes assessment and lack of adjustment for differences in age.

###### Clinical Outcomes

The RCT reported that cardiac outcomes (defined as a composite including cardiac death, MI, unstable angina, or coronary angiography demonstrating 50% or more luminal narrowing) occurred at a similar rate following stress echocardiography and exercise ECG (7.7% vs. 7.4%).86 When stratified by the result of the test, patients with positive result stress echocardiography results were slightly more likely to have a cardiac outcome than patients with a positive stress ECG (44% [7/16] vs. 38% [3/8]), however the sample size was small. Patients with a negative stress echocardiography result were slightly less likely to have a noncardiac outcome (defined as no cardiac event and/or diagnosis of a noncardiac source of the original pain) than patients with a negative exercise ECG (86% [74/86] vs. 91% [30/33]). Ten of 21 patients with a positive test result had a cardiac outcome (positive predictive value 47.6 per 100 people). The proportion of cases with definitive and accurate results was statistically higher for exercise stress echocardiography than exercise ECG (84% vs. 67%, RD 17, 95% CI 3 to 31). The poorer performance of the exercise ECG was driven by the number of inconclusive tests rather than inaccurate results.

The prospective observational study reported adjusted cardiac death and a composite of death or MI split according to three categories of post-test risk, namely low, intermediate, and high.96 Through a mean of 34 months followup, adjusted rates stratified by low, intermediate, and high post-test risk were consistently and statistically lower in the exercise echocardiography group versus the exercise ECG group for both cardiac death (0.4% vs. 0.9%; 1.3% vs. 1.4%; 2.5% vs. 2.9%) and for the composite of death or MI (1.6% vs. 1.8%; 2.2% vs. 3.4%; 4.6% vs. 5.5%) (p<0.006).

The database study of Medicare claims reported that the 6-month risk of death from any cause was somewhat higher following stress echocardiography than exercise ECG (0.95% vs. 0.78%, unadjusted RR 1.21, 95% CI 1.08 to 1.35).102 Hospitalization for acute MI was the same (0.32%) for both groups.

###### Clinical Management

The RCT reported that additional pharmacological stress echocardiography was performed because indeterminate test results were seen in significantly fewer exercise echocardiography patients than exercise ECG patients (4% vs. 24%, RD -21, 95% CI -33 to -8 per 100 people).86 This is not reported for the patients randomized to pharmacologic stress echocardiography as the initial test, as this test was considered definitive and no patients in this group were referred for additional testing per protocol. All of the second tests were negative; no other information was provided on followup treatment or testing.

The prospective study found that through a mean of 34 months, ICA was performed in a similar percentage of stress echocardiography patients at low (6% vs. 8%) and intermediate post-test risk (12% vs. 14%); however ICA was more common following stress echocardiography in those considered to be at high post-test risk (40% vs. 28%, p<0.0001).96 The pattern was the same for revascularization (low post-test risk 5% vs. 7%; intermediate 8% vs. 9%; high 29% vs. 20%), including PCI (low post-test risk 4% vs. 6%; intermediate 5% vs. 6%; high 22% vs. 12%). However, the pattern was different in terms of referral for CABG, with similar results following stress echocardiography between all post-test risk groups: (low post-test risk 1% vs. 2%; intermediate 3% in both groups; high 6% vs. 8%).

In the database study on Medicare claims, there was no difference between groups in referral for ICA (9.50% vs. 9.04%, unadjusted RR 1.05, 95% CI 1.02 to 1.09), although the result was statistically significant.102 In the patients referred for ICA, fewer stress echocardiography patients received revascularization (43.65% vs. 46.49%, unadjusted RR 0.94, 95% CI 0.90 to 0.98). Referral for any additional noninvasive cardiac test was done in fewer stress echocardiography than exercise ECG patients in the 6 months following initial testing (5.57% vs. 19.34%, unadjusted RR 0.29, 95% CI 0.28 to 0.30). The need for any revascularization in the same time period was similar between groups (4.22% vs. 4.31%); this was also true for PCI (2.61% vs. 2.57%) and CABG (1.69% vs. 1.82%).

###### Harms of Index Test and Consequences of Testing

No information on harms was provided by the previously-described studies. However, three additional studies were identified in the population of interest comparing stress echocardiography with exercise ECG that reported complications. There were no incidences of major periprocedural side effects or complications in either group (all patients had both tests), as reported by two large studies (N=429 and 244 women).101,112 Two studies reported side effects for the echocardiography group only; all patients underwent dipyridamole stress. One study91 reported chest pain (37%), flushing (22%), headache (30%), dyspnea (11%), hypotension (6.4%), nausea (5.5%), dizziness (4.5%), and ST segment depression (49.5%) in 109 of 130 patients and the other reported low incidences of excessive tachycardia with palpitations (0.2%) and hypotension and symptomatic bradycardia (0.5%) in their population (N=429).101

###### Harms or Consequences of Additional Testing

None of the three studies reported harms or consequences of additional testing.

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of stress echocardiography and exercise ECG with regard to patient characteristics or other factors were provided, however the trial enrolled only women86 and one focused on Medicare beneficiaries.102

##### Stress Echocardiography Versus Nuclear MPI

Only one fair-quality study compared stress echocardiography to nuclear MPI; pretest risk was not reported (see Appendix E and G for details). Shreibati et al. conducted a large administrative database study using a 20 percent random sample of Medicare claim records from 2006 to 2008 (N=282,830); patients could receive one of four tests including stress echocardiography (n=80,604) and MPI (n=132,343).102 Pretest CAD risk and other baseline risk scores were not reported. Claims were limited to those in an outpatient setting for patients ages 66 years or older; no patient had a history of known CAD (within the previous 9 months) or prior MI or revascularization (within the previous 12 months). This study was designed to evaluate CCTA, but the data provided allowed some comparisons across the other tests. No test details were reported to include information regarding how a test was chosen for a given patient; only CPT codes that included both stress echocardiography and stress SPECT and PET were provided. Patients in the stress echocardiography and MPI groups were similar, respectively, in terms of mean age (73.8 vs. 75.7 years), sex (57.5% vs. 54.5% female), and race (89.1% vs. 89.3% Caucasian). However, those who underwent stress echocardiography had significantly fewer reported cardiac risk factors (i.e., diabetes 20.8% vs. 31.6%; hyperlipidemia 64.6% vs. 74.8%; hypertension 60.2% vs. 74.9%). Outcomes were reported at 6 months and adjusted for confounding baseline variables. This study was funded by the American Heart Association. Methodological limitations included lack of blinded outcomes assessment and significant baseline differences between groups.

###### Clinical Outcomes

In this study of Medicare claims, the 6-month risk of death from all causes was similar for stress echocardiography and MPI (0.95% vs. 1.28%, adjusted OR 1.00, 95% CI 0.90 to 1.10), as was the rate of hospitalization for acute MI (0.32% vs. 0.43%, adjusted OR 0.83, 95% CI 0.70 to 0.98), although the results were statistically significant.102

###### Clinical Management

Through 6-month followup, referral for ICA was significantly less frequent following stress echocardiography (9.50% vs. 12.13%; adjusted OR 0.78, 95% CI 0.76 to 0.81). The need for any revascularization in the same time period was similar between groups (4.22% vs. 4.59%, adjusted OR 0.93, 95% CI 0.88 to 0.98); this was true for both PCI (2.61% vs. 3.37%, adjusted OR 0.76, 95% CI 0.72 to 0.81) and CABG (1.69% vs. 1.29%, adjusted OR 1.40, 95% CI 1.29 to 1.52). In the patients referred for ICA, more stress echocardiography patients received revascularization (43.65% vs. 37.53%, adjusted OR 1.23, 95% CI 1.15 to 1.32). Referral for any additional noninvasive cardiac test was somewhat more frequent in stress echocardiography patients (5.57% vs. 3.22%; adjusted OR 1.92, 95% CI 1.83 to 2.0).102

###### Harms of Index Test and Consequences of Testing

No information on harms was provided by the previously-described study. However, one additional study was identified in the population of interest that compared dobutamine stress echocardiography with SPECT and reported complications for the echocardiography arm only (n=70).103 Overall, there were no serious side effects including sustained arrhythmia, severe hypotension, or MI. Reported complications included: chest pain requiring test termination (11%), extracardiac side effects (e.g., dyspnea, nausea) (5.7%), increased blood pressure (2.9%), and multiple ventricular ectopy (1.4%).

###### Harms of Additional Testing

Not reported.

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of stress echocardiography and MPI with regard to patient characteristics or other factors were provided, however the database study included only Medicare patients.

#### Anatomic Tests Versus Functional Tests

##### CCTA Versus Exercise ECG

Two fair-quality studies, one RCT82 and one retrospective database study,102 compared CCTA with exercise ECG in patients with mixed pretest risk (see Appendix E and G for details).

In the trial, patients with low (43%), intermediate (23%), and high (34%) pretest risk (defined as <30%, 30%–60%, and >60% according to Diamond and Forrester) presented with stable chest pain to two EDs in Northern Ireland.82 Patients were randomized to either 64-slice CCTA with contrast (n=243) or exercise ECG testing using the Bruce protocol (n=245). Both groups were similar in terms of mean age (58 years), presenting symptoms, and all patients reported cardiac risk factors. However, more women received CCTA compared with exercise ECG (47% vs. 39%). Outcomes were reported at 3 and 12 months and 97.6 percent of patients completed final followup. This trial received funding from the South Eastern Health and Social Care Trust and the Northern Ireland Cardiovascular Network. Methodological shortcoming included no statement of concealed allocation and lack of clear blinding of outcome assessors.

A large administrative database study was conducted using a 20 percent random sample of Medicare claim records from 2006 to 2008 (N=282,830). Patients could receive one of four tests including CCTA (n=8820) and exercise ECG (n=61,063) and the followup period was 6 months.102 Pretest CAD risk and other baseline risk scores were not reported. Included claims were limited to those in an outpatient setting for patients aged 66 years or older; no patient had a history of known CAD (within the previous 9 months) or prior MI or revascularization (within the previous 12 months). This study was designed to evaluate CCTA, but the data provided allowed some comparisons across the other tests. No test details were reported. Only CPT codes that included both CCTA and stress (exercise and pharmacological) ECG were provided regarding how a test was chosen for a given patient. Mean age was similar in both groups (73 years) and a higher percentage of women had undergone CCTA (55.8% vs. 49.0%). Cardiac risk factors were more prevalent in the CCTA compared with the ECG group: hypertension (65.5% vs. 57.5%), hyperlipidemia (72.1% vs. 65.1%), and diabetes (30.0% vs. 25.0%). This study was funded by the American Heart Association. Methodological limitations included lack of blinded outcomes assessment and significant baseline differences between groups.

###### Clinical Outcomes

In the trial, no difference was found in all-cause mortality between groups through 12 months (0.4% vs. 0.4%) and no patients died of cardiac-related events.82 Similarly, there was no difference in the incidence of MI (0.41% vs. 0.82%, RD -0.4, 94% CI -1.8 to 1.0 per 100 people) or acute coronary syndrome (0.41% vs. 1.2%, RD -0.8, 95% CI -2 to 0.8 per 100 people). Hospitalization for cardiac causes occurred significantly less frequently in the CCTA group (0.8% vs. 6.9%, RD -6.1, 95% CI -9.5 to -2.7 per 100 people) through 12 months. In the Medicare claims study, 6-month all-cause mortality was similar between groups, although the results were statistically significant (1.05% vs. 0.78%; RR 1.3, 95% CI 1.08 to 1.68). Risk of hospitalization for MI was reduced in the CCTA group compared with the exercise ECG group (0.19% vs. 0.32%, unadjusted RR 0.60, 95% CI 0.37 to 0.99).102

In the RCT, using the Seattle Angina Questionnaire, quality of life improved slightly more from baseline in the CCTA group versus the exercise ECG group at 3 (difference between groups: -5.7, p=0.014) and 12 months (difference between groups: -4.8; p=0.041). Using the same tool, patient assessment of angina stability was also improved more in the CCTA group at 3 (difference between groups: -11.1; p=0.001) and 12 months (difference between groups: -6.8; p=0.028). Frequencies of angina symptoms were similar between groups at both timepoints.82

###### Clinical Management

The trial of ED patients reported that through 12 months, CCTA was associated with a greater frequency of ICA referral compared with exercise ECG (27.2% vs. 20.8%, RD 6.3, 95% CI -1.2 to 13.9 per 100 people, p=0.1011), though the result did not achieve statistical significance.82 During this period, more patients underwent revascularization following testing with CCTA compared with exercise ECG (15.2% vs. 7.7%, RD 7.5, 95% CI 1.9 to 13.0 per 100 people), including PCI (12% vs. 5%, RD 7, 95% CI 2 to 12 per 100 people), and referral for CABG was similar between groups (3.3% vs. 2.9%, RD 0.00, 95% CI -0.03 to 0.04 per 100 people). CCTA resulted in significantly fewer additional noninvasive cardiac tests through 12 months (2.4% vs. 31.3%, RD -29, 95% CI -37 to -23 per 100 people). More patients assigned to CCTA received medical therapy (40.7% vs. 14.3%, RD 26, 95% CI 19 to 34 per 100 people) and fewer received no intervention (44% vs. 78%; RD -0.37, 95% CI -0.45 to -0.29) compared with the exercise ECG group. However, the CCTA group had fewer revisits for chest pain (3.3% vs.13.1%; RD -0.10, 95% CI -0.15 to -0.05) and fewer days in the hospital for chest pain (mean 7 vs. 56 days) than exercise ECG.

The database study of Medicare outpatients found that CCTA was associated with higher referral rates for ICA through 6 months (22.9% vs. 9.0%, unadjusted RR 2.5, 95% CI 2.4 to 2.7) as well as higher rates of revascularization (11% vs. 4.3%, unadjusted RR 2.65, 95% CI 2.47 to 2.84). Similarly, the study found increased referral for PCI with CCTA compared with exercise ECG through 6 months (7.9% vs. 2.6%, unadjusted RR 3.05, 95% CI 2.80 to 3.33) but there was only a small difference between groups in the risk for CABG (3.7% vs. 1.8%, unadjusted RR 2.04, 95% CI 1.80 to 2.30). There was less additional noninvasive testing in CCTA patients through 6 months (5% vs. 19%; unadjusted RR 0.26, 95% CI 0.23 to 0.28), driven by a significantly lower referral rate for MPI (2.7% vs. 16.5%, unadjusted RR 0.17, 95% CI 0.15 to 0.19, respectively).102

###### Harms of Index Test and Consequences of Testing

In the RCT of mixed risk-level patients comparing CCTA and exercise ECG testing, there was only a statement of no complications associated with any investigation.82

###### Harms of Additional Testing

Not reported by either study.

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of CCTA versus exercise ECG with regard to patient characteristics or other factors were provided in either study, however the database study included only Medicare patients.

##### CCTA Versus SPECT

Two observational studies, one fair quality97 and one poor quality,104 compared CCTA to SPECT but did not report or stratify results by pretest risk of CAD (see Appendix E and G for details).97,104 Min et al. 2008 compared CCTA (n=1,938) to SPECT (n=7,752) in an administrative database study using records dated January through March 2006 from a large private United States claims database where SPECT patients were matched to CCTA patients.97 Pretest CAD risk and other baseline risk scores were not reported. Outcomes were reported at 9 months. Tandon et al. 2012 reported 6-month results from a prospective registry study of 2,442 patients (University of Ottawa Heart Institute Cardiac CT Registry); 1,221 consecutive CCTA patients were enrolled between 2006 and 2009 and matched to 1,221 SPECT patients from the same time period.104 Overall, the median pretest CAD risk in this population was 12.3 (scale not reported) and the Morise score was a mean 10.7 ± 3.0. The number of sites and the setting was not reported in either study, and the database study was conducted in the United States and the registry study in Canada. Funding for the database study came from a GE Healthcare grant; the registry study received support from the Ontario Research Fund and the Canada Foundation for Innovation. The database study did not report any test details.97 The registry study used 64-slice CCTA with contrast and rest-stress SPECT employed exercise or pharmacological stress (percentage of each not reported).104 The database study considered patients with no history of CAD recorded in the 9 months prior to testing and the registry study enrolled patients with no history of CAD or revascularization. Except slightly more CCTA patients having baseline dyslipidemia (47.4% vs. 38.7%) in the registry study,97 CCTA and SPECT groups were comparable in all baseline characteristics reported; this is likely a consequence of the patient-matching process during enrollment. Methodological limitations included lack of blinded outcomes assessment, unclear attrition, and lack of controlling for confounding of baseline differences between groups in dyslipidemia in the registry study.

###### Clinical Outcomes

In the registry study, 0.2 percent of CCTA patients died of cardiac causes during the followup period, but mortality rates in the SPECT group were not reported.104 The database study reported similar 9-month risk of MI in both CCTA and SPECT groups (0.4% vs. 0.6%),97 and the registry study reported MI in 0.5 percent of CCTA patients during 6-month followup, but again did not report data for the SPECT group.104 The database study found the 9-month risk of hospitalization for cardiovascular causes was similar in the CCTA and SPECT patients (4.2% vs. 4.1%), although the length of stay was significantly shorter in the CCTA group (4.5 ± 4.1 vs. 7.4 ± 13.3 days, mean difference -2.9, 95% CI -3.5 to 2.3).97 The database study also found no difference between groups in the risk of new-onset angina through 9 months (3.0% vs. 3.5%).97

###### Clinical Management

The database study reported that fewer CCTA patients underwent ICA within the 9-month followup period compared with SPECT patients (6.2% vs. 9.5%, OR 1.61, 95% CI 1.32 to 1.97),97 while the registry found no difference between groups (10.6% vs. 10.2%) through 6 months.104 In the latter study, however, ICA results showed significantly fewer false positives (i.e., no obstructive CAD) in patients that received CCTA as the index test (9.7% vs. 25.8%). Although there was no difference between CCTA and SPECT groups in the database study in the 9-month risk of additional CCTA testing (0.8% vs. 0.7%), CCTA patients were more likely to undergo additional SPECT (7.5% vs. 1.4%, OR 0.17, 95% CI 0.13 to 0.22).97 The registry did not report additional noninvasive testing.104 Both studies found no difference between CCTA and SPECT groups in the need for subsequent revascularization, including PCI and CABG, during the followup periods.97,104 The database study reported similar CAD-specific medication use between groups; there was also no difference in the percentage of patients who attended cardiovascular outpatient visits during the 9-month followup period.97

###### Harms of Index Test and Consequences of Testing

Radiation exposure was significantly greater following index CCTA compared with SPECT in one registry study (median, IQR 14.9 [13.1 to 17.1] vs. 10.5 [10.1 to 11.4] mSv, p<0.001).104

###### Harms of Additional Testing

Radiation exposure from subsequent invasive coronary angiography was also significantly greater in patients who underwent CCTA versus SPECT in one registry study (median, IQR 15.2 [12.7 to 17.1] [n=129] vs. 10.8 [10.2 to 11.7] [n=125] mSv, p<0.001).104

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of CCTA versus SPECT with regard to patient characteristics or other factors were provided in either study.97,104

##### CCTA Versus Nuclear MPI

Two fair-quality observational studies compared CCTA to MPI (SPECT or PET) (see Appendix E and G for details).102,105 Shreibati et al. conducted a large administrative database study using a 20 percent random sample of Medicare claim records from 2006 to 2008 (N=282,830). Patients could receive one of four tests including CCTA (n=8820) and MPI (n=132,343).102 The database study was limited to claims in an outpatient setting for patients ages 66 years or older and patients did not have a history of known CAD (within the previous 9 months) or prior MI or revascularization (within the previous 12 months). Yamauchi et al. reported data from a prospective observational study conducted across 81 centers in Japan in which patients could receive CCTA (n=635), MPI (n=1221), or ICA (not included in this report). The setting was not reported.105 The database study reported 6-month outcomes,102 while the prospective study reported outcomes for 96.6 percent of patients at a median followup of 17.0 ± 5.9 months.105 In general, no test details were reported in either study. Both studies employed MPI and Shrebati et al. specified a number of CPT codes that included both SPECT and PET.102 Yamauchi et al. did not indicate which types of imaging constituted MPI105 and an assumption was made by the authors of this report that both SPECT and PET were likely to have been used. No information was provided regarding how a test was chosen for a given patient in the database study;102 in the prospective nonrandomized study the test was selected at the discretion of the physician.105 In the database study, CCTA patients were slightly younger than MPI patients (mean age 73.56 vs. 75.71 years, p<0.001), had fewer risk factors and comorbidities, and outcomes were adjusted for confounding baseline variables. Females comprised 54.6 percent of the population, and pretest CAD risk (or other baseline risk score) was not reported.102 Those in the prospective nonrandomized study population had a mean age of 66 years, and 44.5 percent were female. Patients tested with CCTA group were less likely than those who received MPI to have milder symptoms (New York Heart Association class I [80.6% vs. 91.9%]; and Canadian Cardiovascular Society class I [61.8% vs. 77.9%]).105 The database study was funded by the American Heart Association and the prospective observational study did not report its source of funding. Methodological limitations included lack of blinded outcomes assessment and significant baseline differences between groups.

###### Clinical Outcomes

In the database study, the 6-month risk of death from any cause was similar between CCTA and MPI groups (1.05% vs. 1.28%, adjusted OR 1.11, 95% CI 0.88 to 1.38). The same study reported a slightly lower 6-month risk of acute MI hospitalization in the CCTA group (0.19% vs. 0.43%, adjusted OR 0.60, 95% CI 0.37 to 0.98).102 The prospective observational study found no difference between CCTA and MPI groups in the median 17-month risk of the composite major adverse cardiac event (e.g., death, acute MI, major cardiac event, or late [>3 months] revascularization) (2.1% vs. 2.6%, crude RR 0.81, 95% CI 0.43 to 1.53).105 Clinical outcomes for test-positive versus test-negative patients were not reported.

###### Clinical Management

While the database study reported higher 6-month ICA referral rates following CCTA compared with MPI (22.94% vs. 12.13%, adjusted OR 2.19, 95% CI 2.08 to 2.32 [MPI as reference group]),102 the prospective observational study found no difference between the two groups through a median of 17 months of followup (31% vs. 33%).105 In the database study, any additional noninvasive testing through 6 months was more common in CCTA than MPI patients (4.98% vs. 3.22%, adjusted OR 1.52, 95% CI 1.37 to 1.69, MPI as reference group); this difference was statistically significant for all types of noninvasive tests employed (MPI, stress echocardiography, exercise ECG) except CCTA.102 The prospective observational study reported similar trends, with any additional test (including ICA) being performed in more CCTA than MPI patients (40% vs. 35%, crude RR 1.14, 95% CI 1.01 to 1.29) through a median of 17 months of followup.105 The database study found that the need for any revascularization was higher in CCTA patients (11.41% vs. 4.59%, adjusted OR 2.76, 95% CI 2.56 to 2.98 [MPI as reference group]) through 6 months; this trend held true for both PCI (7.85% vs. 3.37%, adjusted OR 2.49, 95% CI 2.28 to 2.72) and CABG (3.71% vs. 1.29%, adjusted OR 3.00, 95% CI 2.63 to 3.42 [MPI as reference group]).102 In the database study, not only did more CCTA patients undergo ICA, they were more likely to receive revascularization following ICA than MPI patients (48.79% vs. 37.53%, adjusted OR 1.56, 95% CI 1.41 to 1.73 [MPI as reference group], p<0.001).102 The prospective observational study similarly reported a higher risk of any revascularization in the CCTA group (percentages not reported, adjusted OR 1.62, 95% CI 1.20 to 2.18) through a median of 17 months of followup.105

###### Harms of Index Test

There was no difference in the risk of adverse events during the test between CCTA and MPI patients (0.5% vs. 0.9%), as reported by one observational study.105 No additional details were provided.

###### Harms of Additional Testing

No harms of additional testing were reported in either of the two studies.

###### Differential Effectiveness or Safety in Subgroups

Although no formal test for interaction was performed, the database study102 found that the unadjusted 6-month risk of catheterization and revascularization (evaluated separately) were significantly higher in CCTA patients than MPI patients across all subgroups tested, including age (stratified into four groups: 66-69 years, 70-74 years, 75-79 years, and 80-84 years), sex, race (African-American, Caucasian), hypertension, hyperlipidemia, diabetes, tobacco use, Medicaid, year of index test, and referral region.

##### CCTA Versus Stress Echocardiography

One large, fair-quality administrative database study was identified (see Appendix E and G for details). This study analyzed a 20 percent random sample of Medicare claim records from 2006 to 2008 (N=282,830) and patients could receive one of four tests including CCTA (n=8820) and stress echocardiography (n=80,604). The followup period was 6 months.102 Pretest CAD risk and other baseline risk scores were not reported. Included claims were limited to those in an outpatient setting for patients ages 66 years or older. No patient had a history of known CAD (within the previous 9 months) or prior MI or revascularization (within the previous 12 months). No test details were reported to include information regarding how a test was chosen for a given patient; only CPT codes that included both CCTA and stress echocardiography were provided. Mean age was similar in both groups (74 years) as was sex (CCTA 56% vs. echocardiography 58% female). Cardiac risk factors were more prevalent in the CCTA compared with the echocardiography group: hypertension (65.5% vs. 60.2%), hyperlipidemia (72.1% vs. 64.6%), and diabetes (29.9% vs. 26.4%). This study was funded by the American Heart Association. Methodological limitations included lack of blinded outcomes assessment and significant baseline differences between groups.

###### Clinical Outcomes

The 6-month risk of death from any cause was similar between CCTA and stress echocardiography (1.05% vs. 0.95%, unadjusted RR 1.11, 95% CI 0.90 to 1.38), as was the risk of hospitalization for acute MI (0.19% vs. 0.32%, unadjusted RR 0.61, 95% CI 0.37 to 1.00). Clinical outcomes for test-positive versus test-negative patients were not reported.

###### Clinical Management

Significantly higher 6-month ICA referral rates were reported following CCTA compared with stress echocardiography (22.94% vs. 9.50%, unadjusted RR 2.41, 95% CI 2.31 to 2.52). Any additional noninvasive testing through 6 months was similar between groups, respectively (4.98% vs. 5.57%, unadjusted RR 0.89, 95% CI 0.81 to 0.98), but statistically meaningful; this held true for all types of noninvasive tests employed (e.g., CCTA, MPI, stress echocardiography, and exercise ECG). The need for any revascularization through 6 months was significantly greater following CCTA compared with echocardiography (11.41% vs. 4.22%, respectively; unadjusted RR 2.70, 95% CI 2.53 to 2.89); this trend held true for both PCI (7.85% vs. 2.61%, unadjusted RR 3.01, 95% CI 2.77 to 3.27) and CABG (3.71% vs. 1.69%, unadjusted RR 2.19, 95% CI 1.94 to 2.47). Not only were patients who received CCTA significantly more likely to undergo ICA, they also slightly more likely to receive revascularization following ICA compared with exercise ECG patients (48.79% vs. 43.65%, unadjusted RR 1.12, 95% CI 1.06 to 1.18).

###### Harms of Index Test and Consequences of Testing and Harms of Additional Testing

No harms related to either the index or additional testing were reported.

###### Differential Effectiveness or Safety in Subgroups

No analyses related to differential effectiveness or safety of nuclear MPI and exercise ECG with regard to patient characteristics or other factors were provided, however the database study focused on Medicare beneficiaries (age ≥ 66 years).

#### Noncomparative Studies: Anatomical

##### Calcium Scoring

One noncomparative study of calcium scoring in patients with an unclear pretest risk reported on predictive accuracy.124 Calcium scoring was performed via nonenhanced electron beam computed tomography; a score of ≥1.4 was considered a positive test result and a score of <1.4 was considered a negative test result. A total of 255 patients were analyzed with a mean age of 58 ± 11 years; the proportion of males and females and relevant cardiac risk factors were not reported. Over a mean followup period of 42 months, the frequency of major adverse cardiac events was significantly higher in those who had a positive compared with a negative result: 20 versus 2 per 100 people (see Appendix F for details).

Two additional studies were identified in our patient population that reported incidental findings at the time of index testing. One study reported incidental findings in 80 (7.8%) of the 1,031 patients who underwent calcium scoring via multidetector CT at the time of SPECT in a single ED.98 Findings included pulmonary nodules or mediastinal/hilar calcifications (n=11), pleural effusions or pulmonary infiltrates (n=7), dilated aorta (n=28), pericardial thickening or effusion (n=16), hiatal hernia (n=7), liver cysts (n=2), valvular calcifications (n=8), and abnormal venous anatomy (n=1). No information was provided about subsequent treatment. In the second study, major noncardiac abnormal findings on CCTA (plus calcium scoring) included pulmonary embolism (n=86), acute aortic syndromes (n=13), malignancy (n=6), pneumonia (n=35), advanced emphysema (n=1), and large pericardial (n=15) or pleural (n=22) effusion; these patients were subsequently excluded from analysis because of concerns regarding the effect on immediate patient care or short- or long-term prognosis.99 Nonacute findings (e.g. lung nodules <8 mm, subsegmental atelectasis, bronchial wall thickening, or hiatal hernia) did not preclude exclusion in the study, however the authors did not report if or how many of these findings were present in their population (N=458).

#### Noncomparative Studies: Functional

##### Stress Echocardiography

Two noncomparative studies of stress echocardiography in patients with unknown pretest risk reported on predictive accuracy. Both studies were conducted in an outpatient setting and employed treadmill exercise stress. One study enrolled a high number of patients with known CAD but only the outcomes for the subgroup of patients without known CAD are presented here (n=211).121 The second study enrolled only women and 18 percent of the population had known CAD (N=405).117 Mean ages were 62 and 56 years. Cardiac risk factors were reported variably across studies. In the study conducted in women only, the frequency of any cardiac events was 31 versus 4 per 100 people over a mean of 41 months (OR 9.8, 95% CI 4.4 to 21.9; and for cardiac death: OR 13.6, 95% CI 4.5 to 42). In the second study, the frequency of any cardiac event and MI at 12 months was 32 versus 7 per 100 people and 9 versus 1 per 100 people, respectively; there were no deaths reported in either group (see Appendix F for details).

##### Stress ECG

Two noncomparative studies of stress ECG in patients with unknown pretest risk reported on predictive accuracy. One study (N=132) was conducted in elderly patients (mean age 71 years) hospitalized for cardiac events associated with suspected CAD, and utilized bicycle exercise or dipyridamole stress.115 The second study was conducted in an outpatient setting, enrolled women only (mean age 56 years), and employed treadmill exercise (N=405).117 The latter study also excluded patients with early revascularization to control for test-driven events. In the study that enrolled women only, a positive test, compared with a negative test, was associated with a significantly greater risk of any cardiac event over a mean 41 months of followup (15 vs. 5 per 100 people; OR 3.1, 95% CI 1.2 to 7.9) but not with the risk of cardiac-related death (OR 1.6, 95% CI 0.3 to 8.8). In the study enrolling only elderly patients, the frequency of any cardiac event was higher in test-positive compared with test-negative patients (40 vs. 22 per 100 people); the rate in the positive group was driven by a high occurrence of hospitalization for revascularization. Conversely, the frequency of reported MI was less in those with positive results (3 vs. 14 per 100 people) and frequency of mortality was the same between groups (7 per 100 people) (see Appendix F for details).