# References

1 Lozano R, Naghavi M, Foreman K, et al. Global and regional mortality from 235 causes of death for 20 age groups in 1990 and 2010: a systematic analysis for the Global Burden of Disease Study 2010. Lancet. 2012;380(9859):2095-128. [pmid: 23245604].
2 Go AS, Mozaffarian D, Roger VL, et al. Heart disease and stroke statistics--2013 update: a report from the American Heart Association. Circulation. 2013;127(1):e6-e245. [pmid: 23239837].
3 Ruigomez A, Rodriguez LA, Wallander MA, et al. Chest pain in general practice: incidence, comorbidity and mortality. Fam Pract. 2006;23(2):167-74. [pmid: 16461444].
4 Heidenreich PA, Trogdon JG, Khavjou OA, et al. Forecasting the future of cardiovascular disease in the United States: a policy statement from the American Heart Association. Circulation. 2011;123(8):933-44. [pmid: 21262990].
5 Detry JM. The pathophysiology of myocardial ischaemia. Eur Heart J. Dec. Suppl G. 1996;17:48-52. [pmid: 8960456].
6 Schoen FJ, Mitchel RN. Chapter 13, The heart. Kumar V, Abbas AK, Aster JC, editors. Robbins & Cotran Pathophysiologic Basis of Disease. 9th ed. Philadelphia. W. B. Saunders Company. 2015:524-78.
7 Lloyd-Jones D, Adams RJ, Brown TM, et al. Heart disease and stroke statistics--2010 update: a report from the American Heart Association. Circulation. Feb. 23. 2010;121(7):e46-e215. [pmid: 20019324].
8 Fihn SD, Gardin JM, Abrams J, et al. 2012 ACCF/AHA/ACP/AATS/PCNA/SCAI/STS Guideline for the diagnosis and management of patients with stable ischemic heart disease: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines, and the American College of Physicians, American Association for Thoracic Surgery, Preventive Cardiovascular Nurses Association, Society for Cardiovascular Angiography and Interventions, and Society of Thoracic Surgeons. J Am Coll Cardiol. 2012;60(24):e44-e164. [pmid: 23182125].
9 Cheng VY, Berman DS, Rozanski A, et al. Performance of the traditional age, sex, and angina typicality-based approach for estimating pretest probability of angiographically significant coronary artery disease in patients undergoing coronary computed tomographic angiography: results from the multinational coronary CT angiography evaluation for clinical outcomes: an international multicenter registry (CONFIRM). Circulation. Nov. 2011;124(22):2423-32. 1. 8. [pmid: 22025600].
10 Diamond GA, Forrester JS. Analysis of probability as an aid in the clinical diagnosis of coronary-artery disease. N Engl J Med. Jun. 1979;300(24):1350-8. [pmid: 440357].
11 Weiner DA, Ryan TJ, McCabe CH, et al. Exercise stress testing. Correlations among history of angina, ST-segment response and prevalence of coronary-artery disease in the Coronary Artery Surgery Study (CASS). N Engl J Med. Aug. 1979;301(5):230-5. [pmid: 449990].
12 Pryor DB, Shaw L, McCants CB, et al. Value of the history and physical in identifying patients at increased risk for coronary artery disease. Ann Intern Med. Jan. 1993;118(2):81-90. [pmid: 8416322].
13 Morise AP, Haddad WJ, Beckner D. Development and validation of a clinical score to estimate the probability of coronary artery disease in men and women presenting with suspected coronary disease. Am J Med. Apr. 1997;102(4):350-6. [pmid: 9217616].
14 Antman EM, Cohen M, Bernink PJ, et al. The TIMI risk score for unstable angina/non-ST elevation MI: A method for prognostication and therapeutic decision making. JAMA. Aug. 16. 2000;284(7):835-42. [pmid: 10938172].
15 Goldman L, Cook EF, Johnson PA, et al. Prediction of the need for intensive care in patients who come to the emergency departments with acute chest pain. N Engl J Med. Jun. 6. 1996;334(23):1498-504. [pmid: 8618604].
16 Reilly BM, Evans AT, Schaider JJ, et al. Impact of a clinical decision rule on hospital triage of patients with suspected acute cardiac ischemia in the emergency department. JAMA. Jul. 17. 2002;288(3):342-50. [pmid: 12117399].
17 Chun AA, McGee SR. Bedside diagnosis of coronary artery disease: a systematic review. Am J Med. Sep. 2004;117(5):334-43. [pmid: 15336583].
18 Amsterdam EA, Wenger NK, Brindis RG, et al. 2014 AHA/ACC Guideline for the Management of Patients With Non-ST-Elevation Acute Coronary Syndromes: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014. Sep. 18.
19 Wolk MJ, Bailey SR, Doherty JU, et al. ACCF/AHA/ASE/ASNC/HFSA/HRS/SCAI/SCCT/SCMR/STS 2013 multimodality appropriate use criteria for the detection and risk assessment of stable ischemic heart disease: a report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Heart Association, American Society of Echocardiography, American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, and Society of Thoracic Surgeons. J Am Coll Cardiol. Feb. 2014;63(4):380-406. [pmid: 24355759].
20 Gibbons RJ, Balady GJ, Bricker JT, et al. ACC/AHA 2002 guideline update for exercise testing: summary article: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1997 Exercise Testing Guidelines). Circulation. Oct. 2002;106(14):1883-92. [pmid: 12356646].
21 Mark DB, Hlatky MA, Harrell FE, et al. Exercise treadmill score for predicting prognosis in coronary artery disease. Ann Intern Med. Jun. 1987;106(6):793-800. [pmid: 3579066].
22 Fleischmann KE, Hunink MG, Kuntz KM, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. Sep. 1998;280(10):913-20. [pmid: 9739977].
23 Kim C, Kwok YS, Heagerty P, et al. Pharmacologic stress testing for coronary disease diagnosis: A meta-analysis. Am Heart J. Dec. 2001;142(6):934-44. [pmid: 11717594].
24 Mc Ardle BA, Dowsley TF, deKemp RA, et al. Does rubidium-82 PET have superior accuracy to SPECT perfusion imaging for the diagnosis of obstructive coronary disease?: A systematic review and meta-analysis. J Am Coll Cardiol. Oct. 2012;60(18):1828-37. [pmid: 23040573].
25 Nagel E, Lehmkuhl HB, Bocksch W, et al. Noninvasive diagnosis of ischemia-induced wall motion abnormalities with the use of high-dose dobutamine stress MRI: comparison with dobutamine stress echocardiography. Circulation. Feb. 1999;99(6):763-70. [pmid: 9989961].
26 Greenwood JP, Maredia N, Younger JF, et al. Cardiovascular magnetic resonance and single-photon emission computed tomography for diagnosis of coronary heart disease (CE-MARC): a prospective trial. Lancet. Feb. 2012;379(9814):453-60. [pmid: 22196944].
27 Bonow RO. What's past is prologue: advances in cardiovascular imaging. Lancet. Feb. 2012;379(9814):393-5. [pmid: 22196943].
28 Budoff MJ, Dowe D, Jollis JG, et al. Diagnostic performance of 64-multidetector row coronary computed tomographic angiography for evaluation of coronary artery stenosis in individuals without known coronary artery disease: results from the prospective multicenter ACCURACY (Assessment by Coronary Computed Tomographic Angiography of Individuals Undergoing Invasive Coronary Angiography) trial. J Am Coll Cardiol. Nov. 2008;52(21):1724-32. [pmid: 19007693].
29 Meijboom WB, Meijs MF, Schuijf JD, et al. Diagnostic accuracy of 64-slice computed tomography coronary angiography: a prospective, multicenter, multivendor study. J Am Coll Cardiol. Dec. 2008;52(25):2135-44. [pmid: 19095130].
30 Stein PD, Yaekoub AY, Matta F, et al. 64-slice CT for diagnosis of coronary artery disease: a systematic review. Am J Med. Aug. 2008;121(8):715-25. [pmid: 18691486].
31 Miller JM, Rochitte CE, Dewey M, et al. Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. Nov. 2008;359(22):2324-36. [pmid: 19038879].
32 Villines TC, Hulten EA, Shaw LJ, et al. Prevalence and severity of coronary artery disease and adverse events among symptomatic patients with coronary artery calcification scores of zero undergoing coronary computed tomography angiography: results from the CONFIRM (Coronary CT Angiography Evaluation for Clinical Outcomes: An International Multicenter) registry. J Am Coll Cardiol. Dec. 2011;58(24):2533-40. [pmid: 22079127].
33 Fuster V. 50th anniversary historical article. Acute coronary syndromes: the degree and morphology of coronary stenoses. J Am Coll Cardiol. 1999;34(7):1854-6. [pmid: 10588194].
34 Topol EJ, Nissen SE. Our preoccupation with coronary luminology. The dissociation between clinical and angiographic findings in ischemic heart disease. Circulation. 1995;92(8):2333-42. [pmid: 7554219].
35 Zir LM, Miller SW, Dinsmore RE, et al. Interobserver variability in coronary angiography. Circulation. 1976;53(4):627-32. [pmid: 1253383].
36 Shaw LJ, Min JK, Hachamovitch R, et al. Cardiovascular imaging research at the crossroads. JACC Cardiovasc Imaging. Mar. 2010;3(3):316-24. [pmid: 20223430].
37 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clinical Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
38 Gerber TC, Carr JJ, Arai AE, et al. Ionizing radiation in cardiac imaging: a science advisory from the American Heart Association Committee on Cardiac Imaging of the Council on Clinical Cardiology and Committee on Cardiovascular Imaging and Intervention of the Council on Cardiovascular Radiology and Intervention. Circulation. Feb. 24. 2009;119(7):1056-65. [pmid: 19188512].
39 Einstein AJ, Berman DS, Min JK, et al. Patient-centered imaging: shared decision making for cardiac imaging procedures with exposure to ionizing radiation. J Am Coll Cardiol. Apr. 22. 2014;63(15):1480-9. [pmid: 24530677].
40 Hoffmann U, Venkatesh V, White RD, et al. ACR Appropriateness Criteria((R)) acute nonspecific chest pain-low probability of coronary artery disease. J Am Coll Radiol. Oct. 2012;9(10):745-50. [pmid: 23025871].
41 Earls JP, Berman EL, Urban BA, et al. Prospectively gated transverse coronary CT angiography versus retrospectively gated helical technique: improved image quality and reduced radiation dose. Radiology. Mar. 2008;246(3):742-53. [pmid: 18195386].
42 Chinnaiyan KM, Boura JA, DePetris A, et al. Progressive radiation dose reduction from coronary computed tomography angiography in a statewide collaborative quality improvement program: results from the Advanced Cardiovascular Imaging Consortium. Circ Cardiovasc Imaging. Sep. 2013;6(5):646-54. [pmid: 23926193].
43 Cerqueira MD, Allman KC, Ficaro EP, et al. Recommendations for reducing radiation exposure in myocardial perfusion imaging. J Nucl Cardiol. Aug. 2010;17(4):709-18. [pmid: 20503120].
44 Halliburton SS, Abbara S, Chen MY, et al. SCCT guidelines on radiation dose and dose-optimization strategies in cardiovascular CT. J Cardiovasc Comput Tomogr. Jul-Aug. 2011;5(4):198-224. [pmid: 21723512].
45 Mettler FA Jr., Thomadsen BR, Bhargavan M, et al. Medical radiation exposure in the U.S. in 2006: preliminary results. Health Phys. Nov. 2008;95(5):502-7. [pmid: 18849682].
46 Einstein AJ, Henzlova MJ, Rajagopalan S. Estimating risk of cancer associated with radiation exposure from 64-slice computed tomography coronary angiography. JAMA. Jul. 18. 2007;298(3):317-23. [pmid: 17635892].
47 Levine GN, Bates ER, Blankenship JC, et al. 2011 ACCF/AHA/SCAI Guideline for Percutaneous Coronary Intervention: executive summary: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines and the Society for Cardiovascular Angiography and Interventions. Catheter Cardiovasc Interv. Feb. 15. 2012;79(3):453-95. [pmid: 22328235].
48 Qaseem A, Fihn SD, Dallas P, et al. Management of stable ischemic heart disease: summary of a clinical practice guideline from the American College of Physicians/American College of Cardiology Foundation/American Heart Association/American Association for Thoracic Surgery/Preventive Cardiovascular Nurses Association/Society of Thoracic Surgeons. Ann Intern Med. Nov. 20. 2012;157(10):735-43. [pmid: 23165665].
49 Antithrombotic Trialists' Collaboration. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. BMJ. Jan. 12. 2002;324(7329):71-86. [pmid: 11786451].
50 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. Jul. 6. 2002;360(9326):7-22. [pmid: 12114036].
51 LaRosa JC, Grundy SM, Waters DD, et al. Intensive lipid lowering with atorvastatin in patients with stable coronary disease. N Engl J Med. Apr. 7. 2005;352(14):1425-35. [pmid: 15755765].
52 Warren SG, Brewer DL, Orgain ES. Long-term propranolol therapy for angina pectoris. Am J Cardiol. Mar. 4. 1976;37(3):420-6. [pmid: 816188].
53 Krikler DM. Calcium antagonists for chronic stable angina pectoris. Am J Cardiol. Jan. 30. 1987;59(3):95B-100B. [pmid: 2880496].
54 Kannam JP, Gersh BJ. Nitrates in the management of stable angina pectoris. UpToDate. Kaski JC, editor. Waltham, MA. UpToDate. 2015. April 30, 2015.
55 Wilson SR, Scirica BM, Braunwald E, et al. Efficacy of ranolazine in patients with chronic angina observations from the randomized, double-blind, placebo-controlled MERLIN-TIMI (Metabolic Efficiency With Ranolazine for Less Ischemia in Non-ST-Segment Elevation Acute Coronary Syndromes) 36 Trial. J Am Coll Cardiol. Apr. 28. 2009;53(17):1510-6. [pmid: 19389561].
56 Trikalinos TA, Siebert U, Lau J. Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Med Decis Making. Sep-Oct. 2009;29(5):E22-9. [pmid: 19734441].
57 Katritsis DG, Ioannidis JP. Percutaneous coronary intervention versus conservative therapy in nonacute coronary artery disease: a meta-analysis. Circulation. Jun. 7. 2005;111(22):2906-12. [pmid: 15927966].
58 Katritsis DG, Ioannidis JP. PCI for stable coronary disease. N Engl J Med. Jul. 26. 2007;357(4):414-5. author reply 7-8. [pmid: 17652659].
59 Hambrecht R, Walther C, Mobius-Winkler S, et al. Percutaneous coronary angioplasty compared with exercise training in patients with stable coronary artery disease: a randomized trial. Circulation. Mar. 23. 2004;109(11):1371-8. [pmid: 15007010].
60 Cecil WT, Kasteridis P, Barnes JW Jr., et al. A meta-analysis update: percutaneous coronary interventions. Am J Manag Care. Aug. 2008;14(8):521-8. [pmid: 18690768].
61 Boden WE, O'Rourke RA, Teo KK, et al. Optimal medical therapy with or without PCI for stable coronary disease. N Engl J Med. Apr. 12. 2007;356(15):1503-16. [pmid: 17387127].
62 Pitt B, Waters D, Brown WV, et al. Aggressive lipid-lowering therapy compared with angioplasty in stable coronary artery disease. Atorvastatin versus Revascularization Treatment Investigators. N Engl J Med. Jul. 8. 1999;341(2):70-6. [pmid: 10395630].
63 Stergiopoulos K, Brown DL. Initial coronary stent implantation with medical therapy vs medical therapy alone for stable coronary artery disease: meta-analysis of randomized controlled trials. Arch Intern Med. Feb. 27. 2012;172(4):312-9. [pmid: 22371919].
64 Hueb W, Lopes N, Gersh BJ, et al. Ten-year follow-up survival of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. Sep. 7. 2010;122(10):949-57. [pmid: 20733102].
65 Deb S, Wijeysundera HC, Ko DT, et al. Coronary artery bypass graft surgery vs percutaneous interventions in coronary revascularization: a systematic review. JAMA. Nov. 20. 2013;310(19):2086-95. [pmid: 24240936].
66 Hlatky MA, Boothroyd DB, Bravata DM, et al. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. Apr. 4. 2009;373(9670):1190-7. [pmid: 19303634].
67 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
68 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. [Updated March 2011]. The Cochrane Collaboration. 2011. www.cochrane-handbook.org.
69 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Healthcare Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
70 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
71 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. Mar. 30. 1996;15(6):619-29. [pmid: 8731004].
72 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
73 Methods Guide for Medical Test Reviews. AHRQ Publication No.12-EC017. Rockville MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. May 14, 2015.
74 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
75 Chang SA, Choi SI, Choi EK, et al. Usefulness of 64-slice multidetector computed tomography as an initial diagnostic approach in patients with acute chest pain. Am Heart J. Aug. 2008;156(2):375-83. [pmid: 18657674].
76 Douglas PS, Hoffmann U, Patel MR, et al. outcomes of anatomical versus functional testing for coronary artery disease. N Engl J Med. Apr. 2. 2015;372(14):1291-300. [pmid: 25773919].
77 Goldstein JA, Chinnaiyan KM, Abidov A, et al. The CT-STAT (Coronary Computed Tomographic Angiography for Systematic Triage of Acute Chest Pain Patients to Treatment) trial. J Am Coll Cardiol. Sep. 27. 2011;58(14):1414-22. [pmid: 21939822].
78 Goldstein JA, Gallagher MJ, O'Neill WW, et al. A randomized controlled trial of multi-slice coronary computed tomography for evaluation of acute chest pain. J Am Coll Cardiol. Feb. 27. 2007;49(8):863-71. [pmid: 17320744].
79 Hamilton-Craig C, Fifoot A, Hansen M, et al. Diagnostic performance and cost of CT angiography versus stress ECG--a randomized prospective study of suspected acute coronary syndrome chest pain in the emergency department (CT-COMPARE). Int J Cardiol. Dec. 20. 2014;177(3):867-73. [pmid: 25466568].
80 Hoffmann U, Truong QA, Schoenfeld DA, et al. Coronary CT angiography versus standard evaluation in acute chest pain. N Engl J Med. Jul. 26. 2012;367(4):299-308. [pmid: 22830462].
81 Litt HI, Gatsonis C, Snyder B, et al. CT angiography for safe discharge of patients with possible acute coronary syndromes. N Engl J Med. Apr. 12. 2012;366(15):1393-403. [pmid: 22449295].
82 McKavanagh P, Lusk L, Ball PA, et al. A comparison of cardiac computerized tomography and exercise stress electrocardiogram test for the investigation of stable chest pain: the clinical results of the CAPP randomized prospective trial. Eur Heart J Cardiovasc Imaging. Apr. 2015;6(4):441-8. [pmid: 25473041].
83 Miller AH, Pepe PE, Peshock R, et al. Is coronary computed tomography angiography a resource sparing strategy in the risk stratification and evaluation of acute chest pain? Results of a randomized controlled trial. Acad Emerg Med. May. 2011;18(5):458-67. [pmid: 21569165].
84 Min JK, Koduru S, Dunning AM, et al. Coronary CT angiography versus myocardial perfusion imaging for near-term quality of life, cost and radiation exposure: a prospective multicenter randomized pilot trial. J Cardiovasc Comput Tomogr. Jul-Aug. 2012;6(4):274-83. [pmid: 22732201].
85 Sabharwal NK, Stoykova B, Taneja AK, et al. A randomized trial of exercise treadmill ECG versus stress SPECT myocardial perfusion imaging as an initial diagnostic strategy in stable patients with chest pain and suspected CAD: cost analysis. [Erratum appears in J Nucl Cardiol. 2007 May-Jun;14(3):414]. J Nucl Cardiol. Apr. 2007;14(2):174-86. [pmid: 17386379].
86 Sanfilippo AJ, Abdollah H, Knott TC, et al. Stress echocardiography in the evaluation of women presenting with chest pain syndrome: a randomized, prospective comparison with electrocardiographic stress testing. Can J Cardiol. Apr. 2005;21(5):405-12. [pmid: 15861257].
87 Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results from the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) trial. Circulation. Sep. 13. 2011;124(11):1239-49. [pmid: 21844080].
88 Levsky JM, Spevack DM, Travin MI, et al. coronary computed tomography angiography versus radionuclide myocardial perfusion imaging in patients with chest pain admitted to telemetry: a randomized trial. Ann Intern Med. Aug. 4. 2015;163(3):174-83. [pmid: 26052677].
89 Truong QA, Hayden D, Woodard PK, et al. Sex differences in the effectiveness of early coronary computed tomographic angiography compared with standard emergency department evaluation for acute chest pain: the Rule-Out Myocardial Infarction with Computer-Assisted Tomography (ROMICAT)-II Trial. Circulation. Jun. 25. 2013;127(25):2494-502. [pmid: 23685743].
90 Cheezum MK, Hulten EA, Taylor AJ, et al. Cardiac CT angiography compared with myocardial perfusion stress testing on downstream resource utilization. J Cardiovasc Comput Tomogr. Mar-Apr. 2011;5(2):101-9. [pmid: 21256102].
91 Ferrara N, Leosco D, Abete P, et al. Dipyridamole echocardiography as a useful and safe test in the assessment of coronary artery disease in the elderly. J Am Geriatr Soc. Oct. 1991;39(10):993-9. [pmid: 1918787].
92 Gruettner J, Fink C, Walter T, et al. Coronary computed tomography and triple rule out CT in patients with acute chest pain and an intermediate cardiac risk profile. Part 1: impact on patient management. Eur J Radiol. Jan. 2013;82(1):100-5. [pmid: 22749769].
93 Hachamovitch R, Nutter B, Hlatky MA, et al. Patient management after noninvasive cardiac imaging results from SPARC (Study of Myocardial Perfusion and Coronary Anatomy Imaging Roles in Coronary Artery Disease). J Am Coll Cardiol. Jan. 31. 2012;59(5):462-74. [pmid: 22281249].
94 Henzler T, Gruettner J, Meyer M, et al. Coronary computed tomography and triple rule out CT in patients with acute chest pain and an intermediate cardiac risk for acute coronary syndrome: part 2: economic aspects. Eur J Radiol. Jan. 2013;82(1):106-11. [pmid: 22835878].
95 Hlatky MA, Shilane D, Hachamovitch R, et al. Economic outcomes in the Study of Myocardial Perfusion and Coronary Anatomy Imaging Roles in Coronary Artery Disease registry: the SPARC Study. J Am Coll Cardiol. Mar. 18. 2014;63(10):1002-8. [pmid: 24636556].
96 Marwick TH, Shaw L, Case C, et al. Clinical and economic impact of exercise electrocardiography and exercise echocardiography in clinical practice. Eur Heart J. Jun. 2003;24(12):1153-63. [pmid: 12804930].
97 Min JK, Shaw LJ, Berman DS, et al. Costs and clinical outcomes in individuals without known coronary artery disease undergoing coronary computed tomographic angiography from an analysis of Medicare category III transaction codes. Am J Cardiol. Sep. 15. 2008;102(6):672-8. [pmid: 18773986].
98 Nabi F, Chang SM, Pratt CM, et al. Coronary artery calcium scoring in the emergency department: identifying which patients with chest pain can be safely discharged home. Ann Emerg Med. Sep. 2010;56(3):220-9. [pmid: 20138399].
99 Nance JW Jr., Schlett CL, Schoepf UJ, et al. Incremental prognostic value of different components of coronary atherosclerotic plaque at cardiac CT angiography beyond coronary calcification in patients with acute chest pain. Radiology. Sep. 2012;264(3):679-90. [pmid: 22820732].
100 Nielsen LH, Markenvard J, Jensen JM, et al. Frontline diagnostic evaluation of patients suspected of angina by coronary computed tomography reduces downstream resource utilization when compared to conventional ischemia testing. Int J Cardiovasc Imaging. Jul. 2011;27(6):813-23. [pmid: 21042860].
101 Severi S, Picano E, Michelassi C, et al. Diagnostic and prognostic value of dipyridamole echocardiography in patients with suspected coronary artery disease. Comparison with exercise electrocardiography. Circulation. Mar. 1994;89(3):1160-73. [pmid: 8124803].
102 Shreibati JB, Baker LC, Hlatky MA. Association of coronary CT angiography or stress testing with subsequent utilization and spending among Medicare beneficiaries. JAMA. Nov. 16. 2011;306(19):2128-36. [pmid: 22089720].
103 Takeuchi M, Sonoda S, Miura Y, et al. Comparative diagnostic value of dobutamine stress echocardiography and stress thallium-201 single-photon-emission computed tomography for detecting coronary artery disease in women. Coron Artery Dis. Nov. 1996;7(11):831-5. [pmid: 8993941].
104 Tandon V, Hall D, Yam Y, et al. Rates of downstream invasive coronary angiography and revascularization: computed tomographic coronary angiography vs. Tc-99m single photon emission computed tomography. Eur Heart J. Mar. 2012;33(6):776-82. [pmid: 21893487].
105 Yamauchi T, Tamaki N, Kasanuki H, et al. Optimal initial diagnostic strategies for the evaluation of stable angina patients: a multicenter, prospective study on myocardial perfusion imaging, computed tomographic angiography, and coronary angiography. Circ J. 2012;76(12):2832-9. [pmid: 22975716].
106 Nielsen LH, Olsen J, Markenvard J, et al. Effects on costs of frontline diagnostic evaluation in patients suspected of angina: coronary computed tomography angiography vs. conventional ischaemia testing. Eur Heart J Cardiovasc Imaging. May. 2013;14(5):449-55. [pmid: 22922828].
107 Poon M, Cortegiano M, Abramowicz AJ, et al. Associations between routine coronary computed tomographic angiography and reduced unnecessary hospital admissions, length of stay, recidivism rates, and invasive coronary angiography in the emergency department triage of chest pain. J Am Coll Cardiol. Aug. 6. 2013;62(6):543-52. [pmid: 23684682].
108 Buchsbaum M, Marshall E, Levine B, et al. Emergency department evaluation of chest pain using exercise stress echocardiography. Acad Emerg Med. Feb. 2001;8(2):196-9. [pmid: 11157301].
109 Cho I, Shim J, Chang HJ, et al. Prognostic value of multidetector coronary computed tomography angiography in relation to exercise electrocardiogram in patients with suspected coronary artery disease. J Am Coll Cardiol. Nov. 20. 2012;60(21):2205-15. [pmid: 23103039].
110 Colon PJ 3rd, Guarisco JS, Murgo J, et al. Utility of stress echocardiography in the triage of patients with atypical chest pain from the emergency department. Am J Cardiol. Nov. 15. 1998;82(10):1282-4. A10. [pmid: 9832109].
111 Dedic A, Genders TS, Ferket BS, et al. Stable angina pectoris: head-to-head comparison of prognostic value of cardiac CT and exercise testing. Radiology. Nov. 2011;261(2):428-36. [pmid: 21873254].
112 Dodi C, Cortigiani L, Masini M, et al. The incremental prognostic value of pharmacological stress echo over exercise electrocardiography in women with chest pain of unknown origin. Eur Heart J. Jan. 2001;22(2):145-52. [pmid: 11161916].
113 Elhendy A, Shub C, McCully RB, et al. Exercise echocardiography for the prognostic stratification of patients with low pretest probability of coronary artery disease. Am J Med. Jul. 2001;111(1):18-23. [pmid: 11448656].
114 Fine NM, Pellikka PA, Scott CG, et al. Characteristics and outcomes of patients who achieve high workload (>10 metabolic equivalents) during treadmill exercise echocardiography. Mayo Clin Proc. Dec. 2013;88(12):1408-19. [pmid: 24290114].
115 Gentile R, Vitarelli A, Schillaci O, et al. Diagnostic accuracy and prognostic implications of stress testing for coronary artery disease in the elderly. Ital Heart J. Jul. 2001;2(7):539-45. [pmid: 11501963].
116 Hachamovitch R, Berman DS, Kiat H, et al. Exercise myocardial perfusion SPECT in patients without known coronary artery disease: incremental prognostic value and use in risk stratification. Circulation. Mar. 1. 1996;93(5):905-14. [pmid: 8598081].
117 Heupler S, Mehta R, Lobo A, et al. Prognostic implications of exercise echocardiography in women with known or suspected coronary artery disease. J Am Coll Cardiol. Aug. 1997;30(2):414-20. [pmid: 9247513].
118 Innocenti F, Cerabona P, Donnini C, et al. Long-term prognostic value of stress echocardiography in patients presenting to the ED with spontaneous chest pain. Am J Emerg Med. Jul. 2014;32(7):731-6. [pmid: 24768667].
119 Innocenti F, Lazzeretti D, Conti A, et al. Stress echocardiography in the ED: diagnostic performance in high-risk subgroups. Am J Emerg Med. Sep. 2013;31(9):1309-14. [pmid: 23827088].
120 Kim YJ, Hur J, Lee HJ, et al. Meaning of zero coronary calcium score in symptomatic patients referred for coronary computed tomographic angiography. Eur Heart J Cardiovasc Imaging. Sep. 2012;13(9):776-85. [pmid: 22461571].
121 Krivokapich J, Child JS, Gerber RS, et al. Prognostic usefulness of positive or negative exercise stress echocardiography for predicting coronary events in ensuing twelve months. Am J Cardiol. Mar. 15. 1993;71(8):646-51. [pmid: 8447259].
122 Laudon DA, Behrenbeck TR, Wood CM, et al. Computed tomographic coronary artery calcium assessment for evaluating chest pain in the emergency department: long-term outcome of a prospective blind study. Mayo Clin Proc. Apr. 2010;85(4):314-22. [pmid: 20360291].
123 Petretta M, Daniele S, Acampa W, et al. Prognostic value of coronary artery calcium score and coronary CT angiography in patients with intermediate risk of coronary artery disease. Int J Cardiovasc Imaging. Aug. 2012;28(6):1547-56. [pmid: 21922205].
124 Schmermund A, Stang A, Mohlenkamp S, et al. Prognostic value of electron-beam computed tomography-derived coronary calcium scores compared with clinical parameters in patients evaluated for coronary artery disease. Prognostic value of EBCT in symptomatic patients. Zeitschrift fur Kardiologie. Sep. 2004;93(9):696-705. [pmid: 15365737].
125 Villines TC, Hulten EA, Shaw LJ, et al. Prevalence and severity of coronary artery disease and adverse events among symptomatic patients with coronary artery calcification scores of zero undergoing coronary computed tomography angiography: results from the CONFIRM (Coronary CT Angiography Evaluation for Clinical Outcomes: An International Multicenter) registry. J Am Coll Cardiol. Dec. 6. 2011;58(24):2533-40. [pmid: 22079127].
126 Ollendorf DA, Colby JA, Cameron C, et al. Cardiac Nuclear Imaging. Final Appraisal Document. Prepared by the Institute for Clinical and Economic Review. Olympia, WA. Health Technology Assessment Program, Washington State Health Care Authority. August. 12. 2013. www.hca.wa.gov/hta/documents/cni_final_report_081313.pdf.
127 Ollendorf DA, Göhler A, Pearson SD. Coronary Computed Tomographic Angiography for Detection of Coronary Artery Disease. Prepared by the Institute for Clinical and Economic Review. Olympia, WA. Health Technology Assessment Program. October. 17. 2008. www.icer-review.org/wp-content/uploads/2013/04/CCTA_Rpt_Draft.pdf.
128 Dolor RJ, Patel MR, Melloni C, et al. Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women. Comparative Effectiveness Review No. 58. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 12-EHC034-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
129 Mujtaba S, Pena JM, Pamerla M, et al. Publication trends in noninvasive cardiovascular imaging: 1991-2011: a retrospective observational study. Am J Cardiovasc Disease. 2013;3(4):247-54. [pmid: 24224136].
130 Ronan G, Wolk MJ, Bailey SR, et al. ACCF/AHA/ASE/ASNC/HFSA/HRS/SCAI/SCCT/SCMR/STS 2013 Multimodality Appropriate Use Criteria for the Detection and Risk Assessment of Stable Ischemic Heart Disease: a report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Heart Association, American Society of Echocardiography, American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, and Society of Thoracic Surgeons. J Nucl Cardiol. 2014;21(1):192-220. [pmid: 24374980].
131 American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Society of Echocardiography, American Heart Associaton, et al. ACCF/ASE/AHA/ASNC/HFSA/HRS/SCAI/SCCM/SCCT/SCMR 2011 Appropriate Use Criteria for Echocardiography. A Report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Society of Echocardiography, American Heart Association, American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Critical Care Medicine, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance American College of Chest Physicians. J Am Soc Echocardiogr. Mar. 2011;24(3):229-67. [pmid: 21338862].
132 Patel MR, Bailey SR, Bonow RO, et al. ACCF/SCAI/AATS/AHA/ASE/ASNC/HFSA/HRS/SCCM/SCCT/SCMR/STS 2012 Appropriate Use Criteria for Diagnostic Catheterization: a report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, Society for Cardiovascular Angiography and Interventions, American Association for Thoracic Surgery, American Heart Association, American Society of Echocardiography, American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society of Critical Care Medicine, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, and Society of Thoracic Surgeons. J Am Coll Cardiol. May. 29. 2012;59(22):1995-2027. [pmid: 22578925].
133 Pellikka PA, Nagueh SF, Elhendy AA, et al. American Society of Echocardiography recommendations for performance, interpretation, and application of stress echocardiography. J Am Soc Echocardiogr. Sep. 2007;20(9):1021-41. [pmid: 17765820].
134 Patel MR, Dehmer GJ, Hirshfeld JW, et al. ACCF/SCAI/STS/AATS/AHA/ASNC/HFSA/SCCT 2012 Appropriate Use Criteria for Coronary Revascularization focused update: a report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, Society for Cardiovascular Angiography and Interventions, Society of Thoracic Surgeons, American Association for Thoracic Surgery, American Heart Association, American Society of Nuclear Cardiology, and the Society of Cardiovascular Computed Tomography. J Am Coll Cardiol. Feb. 28. 2012;59(9):857-81. [pmid: 22296741].
135 Shaw LJ, Berman DS, Picard MH, et al. Comparative definitions for moderate-severe ischemia in stress nuclear, echocardiography, and magnetic resonance imaging. JACC Cardiovasc Imaging. Jun. 2014;7(6):593-604. [pmid: 24925328].
136 Rauch G, Rauch B, Schuler S, et al. Opportunities and challenges of clinical trials in cardiology using composite primary endpoints. World J Cardiol. Jan. 26. 2015;7(1):1-5. [pmid: 25632312].
137 Wasfy MM, Brady TJ, Abbara S, et al. Comparison of the Diamond-Forrester method and Duke Clinical Score to predict obstructive coronary artery disease by computed tomographic angiography. Am J Cardiol. Apr. 1. 2012;109(7):998-1004. [pmid: 22236462].