# Methods

The methods for this Comparative Effectiveness Review follow the guidance in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (Methods Guide).67

## Topic Refinement and Review Protocol

The topic for this Comparative Effectiveness Review was ranked as a priority topic by a panel of stakeholders convened through the Duke Evidence-based Practice Center's Cardiovascular Topic Identification project. The preliminary Key Questions and scope were developed with input from Key Informants, representing practicing clinicians, patients, payers, and others with experience in making health care decisions. The Key Questions were posted on AHRQ's Web site for public comment for 4 weeks. Public comments and input from the Technical Expert Panel (TEP) were used to develop the final Key Questions and protocol. The TEP, convened to provide high-level content and methodological guidance to the review process, consisted of experts in cardiology and cardiac diagnostic testing, radiology, internal medicine, and health services research, as well as professional organizations and policymakers. TEP members disclosed all financial or other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the TEP members had no conflicts of interest that precluded participation.

Both the final topic refinement document and the systematic review protocol, developed prior to initiation of the review, can be found on the AHRQ Web site at www://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/. The protocol is also registered with the PROSPERO international database of prospectively registered systematic reviews (CRD42015022081).

## Literature Search Strategy

### Search Strategy

A research librarian conducted searches for primary studies in the following databases through July 2015: Ovid MEDLINE^®^, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Evidence-Based Medicine Reviews–Health Technology Assessment. A search strategy was developed based on an analysis of the medical subject heading (MeSH) terms and text words of key articles identified a priori. The full search strategy is available in Appendix A. Search start dates were not restricted. The reference lists of included articles and relevant review articles were also reviewed. All citations were downloaded and imported into an electronic database (EndNote^®^ X7 Thomson Reuters, Philadelphia, PA). A list of relevant drugs and manufacturers was provided to the Scientific Resource Center, which requested Scientific Information Packets, and relevant published and unpublished studies were assessed for inclusion in the final report.

Because of the large number of citations retrieved by our database searches, two experienced team members created a list of search terms using the exclusion criteria in the PICOTS (populations, interventions, comparators, outcomes, timing, and setting) table and applied a systematic search in EndNote in order to further exclude studies with a high likelihood of not being relevant. The full list of terms and methods used is available in Appendix A. Citations without abstracts, those not available in English, and certain publication types (case report, narrative review) were excluded. For the remaining citations, titles were searched for terms related to unequivocally excluded populations (e.g., stent, cardiomyopathy), interventions (e.g., ultrasound, Doppler, screening), and outcomes. The title was chosen as the search field because it should contain only terms most relevant to the purpose of the study. Out of a total of 17,146 citations, 8,186 were excluded using this method.

Literature searches were updated during the public comment and peer review period in order to ensure that any new publications that meet our inclusion criteria were incorporated into the final report.

### Inclusion and Exclusion Criteria

Criteria for inclusion and exclusion of studies were based on the Key Questions and the PICOTS (populations, interventions, comparators, outcomes, timing, and setting) approach, as described in Table 6. Studies of stable symptomatic adult patients undergoing their first noninvasive diagnostic test for suspected coronary artery disease (CAD) were sought. Studies of patients with known CAD, prior myocardial infarction (MI), or prior revascularization were excluded. In keeping with the review protocol, studies of patients with definite acute coronary syndrome (ACS), non-ST-elevation acute coronary syndromes (NSTE-ACS), non-ST-segment elevation myocardial infarction (NSTEMI), and ST-segment elevation myocardial infarction (STEMI) were excluded (or were included only if these patients did not comprise >20% of the study population), as were studies of patients with unstable angina and elevated serum cardiac biomarkers or electrocardiogram (ECG) changes. For all Key Questions, the focus was on evidence from comparative studies with the least potential for bias. Noncomparative studies of predictive accuracy were considered if there was a lack of comparative data for a specific diagnostic modality. Interventions of interest included functional tests (i.e., stress ECG, stress echocardiography, stress nuclear imaging [single photon emission computed tomography (SPECT) and positron emission tomography (PET)], and stress magnetic resonance imaging [MRI]) and anatomic imaging (i.e., coronary computed tomography angiography [CCTA], coronary calcium scoring via electron beam, or multidetector computed tomography [CT]). Comparators included other noninvasive tests included in the interventions, usual care (as defined by the authors), or no testing. Studies that included technologies that are not widely available, are no longer used, or have not been established for the diagnosis of CAD were excluded.

Table 6 Summary of inclusion and exclusion criteria

PICOTS | Inclusion Criteria | Exclusion Criteria
Patients | Adult patients (≥18 years of age) with suspected CAD who present with stable (nonemergent) typical or atypical symptoms suspicious for CAD (e.g., chest pain, chest tightness, chest burning, shoulder pain, palpitations, jaw pain, or nonchest pain symptoms, such as dyspnea or worsening effort tolerance) and who are considered to be at very low, low, or intermediate to high risk of CAD based on initial clinical assessment (including resting ECG) prior to first noninvasive test. Special populations and circumstances of interest include:; - Patients with renal insufficiency, diabetes, LBBB, HIV, or other comorbidities; - Women; - Those who are/are not able to exercise; - Those with atypical symptoms/atypical presentation; - Socioeconomic factors; - Clinical setting (e.g., emergency department, outpatient clinic) | - Asymptomatic patients; - Patients with known CAD; - Patients who have had previous revascularization (CABG, PTCA, stenting); - Studies in populations with >20% asymptomatic or with known CAD unless data are stratified by symptom status/CAD status; - Patients being evaluated for other cardiac diseases (e.g., valvular disease, etiology of cardiomyopathy); - Patients with unstable angina who have elevated serum cardiac biomarkers, ECG changes, etc.; those with NSTE-ACS, NSTEMI, STEMI, or definite acute coronary syndrome
Interventions | [underlined: Functional tests] (including use of exercise, vasodilator and/or dobutamine as stressor when appropriate); - Exercise electrocardiogram without imaging; - Exercise/pharmacologic echocardiography (with or without myocardial contrast); - Exercise/pharmacologic radionuclide imaging with SPECT or PET; - Pharmacologic stress magnetic resonance imaging | - Invasive coronary angiography; - Screening applications of tests (application of tests to asymptomatic people, those who are being evaluated for noncardiac surgery); - CT (other than CT for calcium scoring): studies not using 64–slice or higher resolution; - Testing for conditions other than evaluation of CAD (e.g., arrhythmia, valvular disease)
Interventions | [underlined: Anatomic imaging]
Interventions | - Coronary calcium scoring via EBCT or MDCT; - CCTA | - Technologies that are not widely available or have not been established for the diagnosis of CAD or those being assessed for feasibility (e.g., gene expression testing, Corus CAD by CardioDx, myocardial contrast echocardiography, myocardial strain imaging (post-ischemic shortening as a marker for ischemic memory), coronary FDG PET, BMIPP ischemic memory imaging, transthoracic Doppler FFR, CT-based FFR, MRA, TEE, CT perfusion); - Technologies that are no longer available or no longer widely used (e.g., MUGA, planar nuclear imaging); - Drugs or devices used in testing that are not available in the United States
Comparators | Other noninvasive tests included in the interventions, usual care, or no testing | - Invasive coronary angiography; - Studies which do not specify components of “usual care” if that is the comparator
Outcomes | [underlined: Clinical outcomes (primary focus)]; - Quality of life; - Change in angina (e.g., worsening); - MI; - Heart failure; - Stroke; - Death; - Cardiovascular hospitalization for acute coronary syndrome, heart failure, arrhythmias; - Dysrhythmia; (For studies of predictive accuracy that do not compare tests, only hard clinical outcomes will be evaluated: These are MI, death, heart failure) [underlined: Intermediate outcomes] [underlined: (to be evaluated based on comparative studies only)]; - Need for additional testing (including referral for invasive testing); - Clinical decisionmaking and management based on revised risk stratification such as use of guideline-directed medical therapy, including management of lipids, blood pressure and diabetes; counseling related to diet, physical activity, smoking cessation, alcohol use, and management of psychological factors; use of additional therapies to reduce risk of MI and death (e.g., antiplatelet therapy); - Any need for subsequent revascularization (PCI or CABG); [underlined: Harms, risks and consequences of testing (both initial and subsequent testing)]; - Harms of testing (renal failure, allergy, nephrogenic systemic fibrosis, contrast-related harms, adverse reaction to medications used for stress testing), vascular complications; - Risks and consequences (radiation exposure, psychological consequences of diagnosis, need for additional testing) | - Studies focused on “per-vessel” or “per-segment” analysis without per patient findings; - Treatments and outcomes of treatments will not be evaluated
Timing | At time of first noninvasive test for evaluation (other than initial resting ECG)
Settings | Non-emergent inpatient settings, or ambulatory/outpatient settings, including emergency department
Study Design | - High-quality systematic reviews with or without meta-analysis; - Prospective studies (RCT or observational) directly comparing interventions with comparators based on established diagnostic criteria will be sought. Retrospective studies will be considered if there are insufficient prospective studies and they are at low risk of bias.; - Studies of prognosis and decisionmaking will be included if testing results are reported in relation to clinical outcomes and if there is control for confounding as appropriate; studies of predictive accuracy will be considered if they provide clinical outcomes in untreated people. | - Studies of technique or feasibility or reporting only on the technical aspects of testing; - Studies exploring prediction models for diagnostic criteria or prognosis; - Studies comparing pharmacological agents for stress testing with each other; - Studies of serial assessment of one test; - Studies with ≤20 patients; - Non-systematic reviews; - Narrative reviews; - Abstracts, editorials, letters, conference proceedings; - White papers; - Articles identified as preliminary reports when results are published in later versions; - Case series, case reports
Publication Type | - Studies published in English in scholarly journals, published health technology assessments, or publicly available FDA reports; - Gray literature (e.g., ongoing or unpublished clinical trial data) | - Single site reports from multicenter trials; - Duplicate publications of the same study that do not report on unique outcomes or time points

BMIPP = beta-methyl iodophenyl pentadecanoic acid; CABG = coronary artery bypass grafting; CAD = coronary artery disease; CCTA = coronary computed tomography angiography; CT = computed tomography; EBCT = electron beam computed tomography; ECG = electrocardiography; FDA = U.S. Food and Drug Administration; FDG-PET = Fludeoxyglucose (18F) positron emission tomography; FFR = fractional flow reserve; HIV = human immunodeficiency virus; LBBB = left bundle branch block; MDCT = multidetector computed tomography; MI = myocardial infarction; MRA = magnetic resonance angiography; MUGA = multigated acquisition scan; NSTE-ACS = non-ST elevation acute coronary syndromes; NSTEMI = non-ST-segment elevation myocardial infarction; PCI = percutaneous coronary intervention; PET = positron emission tomography; PICOTS = patients, interventions, comparators, outcomes, timing, settings, study designs; PTCA = percutaneous transluminal coronary angioplasty; RCT = randomized controlled trial; SPECT = single photon emission computed tomography; STEMI = ST-segment elevation myocardial infarction; TEE = transesophageal echocardiography

The primary outcomes listed in the PICOTS table (Table 6) were considered to be the most clinically important and were the focus of reporting, decisions for data pooling, and determination of overall strength of evidence. Additional outcomes are reported in the detailed evidence synthesis sections of Results, organized by the Key Questions with a focus on outcomes common across studies. Where applicable and where data were available, results from the index emergency department (ED) visit and the followup period were reported separately. For studies of predictive accuracy, only hard clinical outcomes (i.e., MI, death, composite cardiac outcome, or heart failure) were evaluated. For both the initial test and any subsequent downstream testing, the primary safety outcomes were related to harms of testing (e.g., adverse reaction or allergy to contrast or stress agents) and risks and consequences of testing (e.g., radiation exposure). Studies focused on “per-vessel” or “per-segment” analysis without per-patient findings were excluded, and treatments and outcomes of treatments were beyond the scope of this report.

Studies published only as conference abstracts, non-English-language articles, and studies of nonhuman subjects were excluded. Studies had to report original data to be included.

### Study Selection

Abstracts for all citations from the literature searches were independently reviewed by two team members and results were recorded in EndNote. All citations that either reviewer found to be potentially appropriate for inclusion underwent full-text review. Two investigators independently evaluated each full-text article for final inclusion. For inclusion, both reviewers had to agree that inclusion criteria were met. Differences between reviewers were resolved through consensus and discussion. A record of studies excluded at the full-text level with reasons for exclusion is included in Appendix C.

### Data Extraction

The investigative team created a form in Microsoft^®^ Excel for abstracting the data elements for the Key Questions. The data abstraction forms were piloted by two members of the team and refinements made as needed. Two staff members were responsible for abstracting demographic information for each study and five experienced team members entered data for the outcomes of interest. After data extraction, at least one other staff member and one investigator each verified the accuracy and completeness of abstraction for each study included. Discrepancies were resolved by discussion and consensus.

Reviewers extracted information on general study characteristics (e.g., study design, study period, followup, study setting, funding, and authors' conflicts of interest), study patients (patients approached/eligible/enrolled, age, sex, comorbidities, cardiac risk factors, pretest risk for CAD as defined by the authors), intervention arm details (tests evaluated, patients treated, patients with followup, type of stressor used, type of contrast used, definition of a positive test), test results, clinical health and management outcome measures, adverse events, and information related to study quality. Outcome measures and adverse events were prespecified during the creation of the extraction form to maintain consistency in data reporting. However, unique results were added during the abstraction process as needed. Outcomes that occurred during the index ED visit were reported separately from those that occurred during the followup period; however, for some studies it was unclear if the followup period included the index visit. Limited data were extracted from studies of predictive accuracy with a focus on hard clinical outcomes (i.e., MI, death, composite cardiac outcome, and heart failure). An outline of the specific information included in the data extraction forms is available in Appendix D.

### Quality (Risk-of-Bias) Assessment of Individual Studies

Predefined criteria were used to assess the quality (risk of bias) of included randomized controlled trials (RCTs) and observational studies by using clearly defined templates and criteria as appropriate and following guidance from the AHRQ Methods Guide.67 Assessment of RCTs followed appropriate criteria and methods established in the Cochrane Handbook for Systematic Reviews of Interventions.68 Comparative observational studies were assessed for study design features and sources of potential bias. The quality of each comparative study was rated based on the following: methods used for randomization (RCTs only, requirement of computer-generated random numbers, random numbers tables, coin toss, or opaque sequentially numbered envelopes), allocation concealment (RCTs only, requirement of sealed opaque envelopes, centralized randomization, on-site computer based system with a randomization sequence that is not readable until allocation, or blocked randomization), intention to treat analysis (RCTs only), independent or blind outcome assessment, patients comparable at baseline on key CAD risk factors, prespecified threshold or definition for a positive test, acceptable attrition (≤20%), comparable attrition between treatment groups (≤10% difference between groups), controlling for possible confounding, and full reporting on prespecified outcomes. These criteria and methods were used in concordance with the AHRQ schema, wherein each study was rated as being “good,” “fair,” or “poor” quality.69 Two investigators independently assessed the quality of each study and any discrepancies were resolved through discussion and consensus.

Studies rated “good” are considered to have the least risk of bias, and their results are considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” are susceptible to some bias, although not enough to invalidate the results. These studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while others may be only possibly valid.

Studies rated “poor” have significant flaws that imply biases of various types that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies are least as likely to reflect flaws in the study design as the true difference between the compared interventions. Studies rated as being poor in quality a priori were not excluded, but considered to be less reliable than higher-quality studies when synthesizing the evidence, particularly if discrepancies between studies were present.

Each study evaluated was independently reviewed for quality by two team members. Any disagreements were resolved by consensus. The final quality assessments are described in detail in Appendix I.

### Data Synthesis

When adequate data were reported in at least two studies, meta-analysis was conducted in order to provide more precise estimates for outcomes. To determine the appropriateness of conducting meta-analysis, clinical and methodological diversity and assessed statistical heterogeneity were considered. Given the multiple interventions included in this report, a network meta-analysis was planned to estimate the relative effects of interventions that were not directly compared, and to make full use of both direct and indirect evidence.70 However, the number of included studies turned out to be very small (2 for each comparison) with a limited number of comparisons (only CCTA vs. SPECT and CCTA vs. usual care). Along with heterogeneity across studies, this made network meta-analysis impossible. Therefore, only standard meta-analysis was conducted and only binary outcomes were eligible. The profile-likelihood random-effects model71 was used to combine risk differences while incorporating variation among studies. The presence of statistical heterogeneity among the studies was assessed by using the standard Cochran's chi-square test, and the magnitude of heterogeneity was assessed by using the I^2^ statistic, which describes the percentage of variability in effect estimates because of heterogeneity versus chance (sampling error).72 Risk differences were used to describe absolute effect sizes for RCT data. The absolute approach is helpful for decisionmaking from the perspective of knowing which test has more cases per 100 (or 1000) of a clinical outcome (e.g., MI) than the other (after patients have gone through the decision/treatment pathway). The risk difference helps provide information on the difference in the number of people with a given outcome identified with each test.

To account for clinical heterogeneity, we stratified analyses by pretest risk. Within each strata, the number of studies was too small for exploring heterogeneity based on any study level characteristics. Sensitivity analyses using risk ratios were conducted to check the robustness of results to the choice of effect measure. Conclusions were generally similar and not separately reported. All analyses were performed using Stata^®^/IC 12.1 (StataCorp, College Station, TX).

## Strength of the Body of Evidence

The strength of evidence for each primary efficacy/effectiveness and safety outcome described previously was initially assessed by one researcher using the approach described in the AHRQ Methods Guide, also available from the AHRQ Web site.67,69

In determining the strength of a body of evidence regarding a given outcome, the following domains are considered:

- Study limitations: the extent to which studies reporting on a particular outcome are likely to be protected from bias; graded as low, medium, or high level of study limitations
- Consistency: the extent to which studies report the same direction of effect for a particular outcome; graded as consistent, inconsistent, or unknown (in the case of a single study)
- Directness: reflects whether the outcome is directly or indirectly related to health outcomes of interest
- Precision: describes the level of certainty of the estimate of effect for a particular outcome and includes consideration of the sample size and number of events; graded as precise or imprecise
- Reporting bias: suspected if there was evidence of selective reporting, otherwise considered to be undetected.

A final strength of evidence grade was assigned by evaluating and weighing the combined results of the previously-described domains; final grades are presented in the Discussion, and tables detailing how final grades were determined are available in Appendix J. To ensure consistency and validity of the evaluation, the strength of evidence ratings for all key outcomes were reviewed by the entire team of investigators, and discrepancies were resolved by consensus.

Bodies of evidence consisting of RCTs started as high-strength while bodies of comparative observational studies began as low-strength evidence. The strength of the evidence was then downgraded based on the limitations described previously. There are also situations in which the observational evidence may be upgraded (e.g. very large size of effect), but we found no instances in which these could be applied in this body of evidence. (See the AHRQ Methods Guide for details on upgrading; see also the AHRQ Methods Guide for Medical Test Reviews73). The overall grades and their definitions are as follows:

- High—We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
- Moderate—We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
- Low—We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient—We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Applicability

Applicability of the evidence was considered by examining the characteristics of the patient populations included in studies (e.g., demographic characteristics, presence of relevant cardiac risk factors, and pretest risk for CAD); the sample size of the studies; and clinical settings in which the studies are performed (e.g., outpatient clinic, ED) as outlined in the AHRQ Methods Guide.67,74 Variability in the studies may limit the ability to generalize the results to other populations and settings. For example, older studies of established tests may not be as applicable in light of advances in technology, and short-term outcomes based on immediate decisionmaking in the ED may not be generalizable to longer-term outcomes and decisionmaking in the outpatient setting.

## Peer Review and Public Commentary

Experts in the diagnosis and treatment of CAD, as well as individuals representing other important stakeholder groups, were invited to provide external peer review of this Comparative Effectiveness Review. The AHRQ Task Order Officer and an Evidence-based Practice Center Program Associate Editor also provided comments and editorial review. The draft report was published on the AHRQ Web site for 4 weeks in order to solicit public comments. At the end of this period, the authors considered both the peer and public review comments and generated a final report. A disposition-of-comments report detailing the authors' responses to the peer and public review comments will be made available 3 months after AHRQ posts the final report on the public Web site.