# Introduction

## Background

### Nature and Burden of Coronary Artery Disease

The public health and economic burdens of coronary artery disease (CAD) are substantial. CAD causes one in six deaths in the United States and is the leading cause of death globally.1 Annually, approximately 635,000 Americans experience a new coronary event, 280,000 have a recurrent ischemic event, and an additional 150,000 have a silent first myocardial infarction (MI).2 A large proportion of ambulatory health care visits are for evaluation of patients with suspected CAD, with an estimated 1.5 percent of the population presenting to health care providers with chest pain every year.3 An estimated $108.9 billion are spent annually on CAD treatment.4 Optimizing the process for assessing these patients presents an opportunity to improve patient outcomes and target health resources to where they can have the most impact.

The most common underlying cause of CAD is atherosclerosis, a disease process in which plaque (which has a complex and varied composition that includes lipids, inflammatory cells, smooth muscle cells, and connective tissue) builds up on artery walls. Plaque formation can lead to the partial or complete blockage of coronary arteries and as a result prevent the heart from receiving blood, oxygen, and vital nutrients. Plaque causes blockage by two mechanisms: (1) progressive narrowing of the artery because plaque compromises the vessel lumen and (2) thrombotic occlusion of the artery, which occurs when the hard surface of a plaque tears or breaks off, exposing the inner fatty pro-thrombotic, platelet-attracting components to the site, resulting in enlargement of the blockage. The resulting reduction in blood flow can be either acute or chronic and leads to an inadequate blood supply to the myocardium.5,6 Areas of atherosclerosis can also cause vascular dysfunction, which is an imbalance between relaxation and constriction in either large conduit arteries or the microcirculation. This process can occur in areas of plaque development or can occur in the absence of significant plaque but in the presence of certain predisposing diseases or atherosclerotic risk factors (e.g., lipid disorders, diabetes, smoking, and sedentary lifestyle).

The most common symptom of obstructive CAD is chest pain (angina), which is the first presenting symptom in at least 50 percent of patients with CAD.7 Other common symptoms include the angina equivalents dyspnea, early fatigue with exertion, indigestion, palpitations, tightness in the throat, and neck or arm pain. However, because these symptoms are also seen in many common noncardiac conditions, such as gastroesophageal reflux, esophageal spasm, and cervical disc disease, they are much less reliable predictors of CAD. Women and people with diabetes are less likely to experience classic angina, adding to the challenges of early CAD diagnosis in these populations. Although the onset of symptoms and clinical impact of CAD depend in part on the number and distribution of atheromatous plaques, the degree and length of coronary narrowing, microvascular function, and cardiac blood flow demand (determined by factors such as degree of usual daily activity, blood pressure, and heart rate), lesion severity is poorly correlated with symptoms and CAD may remain asymptomatic for many years.

### Patient Assessment and Pretest Risk of CAD

The 2012 American College of Cardiology Foundation/American Heart Association (ACCF/AHA) Guideline categorizes the pretest probability of CAD as low (<10%), intermediate (10%–90%), or high (>90%).8 Estimation of pretest probability starts with evaluation of patient history and presentation, including type of chest pain, age, and sex. Pretest risk of CAD can be based on a number of factors, including the presence of risk factors such as diabetes mellitus, hypertension, dyslipidemia, personal smoking history, and family history of premature atherosclerotic cardiovascular disease; however, pretest risk is often ascertained based on age, sex, and type of chest pain (i.e., typical or atypical).9 Chest pain has classically been subdivided into typical (or definite) angina, atypical (or probable) angina, and nonanginal chest pain. Typical cardiac angina is characterized by (1) a substernal discomfort which is precipitated by physical exertion or emotional stress, (2) is relieved by rest or nitroglycerine in less than 10 minutes, and (3) may be accompanied by radiation of the discomfort to either the shoulder, the jaw, or the inner aspect of the arm. Atypical angina is that which meets only two of the three characteristics of typical angina, while nonanginal chest pain only meets only one of the three characteristics of typical angina. The type of chest pain together with age and sex allow for a rough estimation of pretest probability of CAD using validated clinical risk scores such as the Diamond and Forrester Chest Pain Prediction Rule.10,11 Using this algorithm, a 55-year-old man presenting with typical chest pain would be estimated to have approximately 80 percent probability of having obstructive CAD; but this pretest likelihood would be 50 percent if the pain were atypical and 33 percent if it was nonanginal in nature. There are a number of other clinical risk prediction tools for bedside prediction of pretest probability in patients with suspected CAD, including the Morise Score, Thrombolysis in Myocardial Infarction (TIMI) risk score, and the Goldman Reilley criteria (Goldstein).12,13,14-16 However, these are rarely documented in clinical practice and baseline level of risk often revolves around the clinician's overall assessment of sociodemographic characteristics, the description of the chest pain, and the findings on resting electrocardiography (ECG).17

### Diagnosis of CAD: Overview

The first step in diagnosing CAD is a thorough clinical work-up which consists of a physical examination, patient history, obtaining some combination of a resting ECG, chest x-ray, and/or serum biomarkers such as cardiac troponins. If the cardiac troponins are consistent with myocardial injury or the ECG is suggestive of myocardial ischemia then patients should be treated according to the appropriate guidelines for an acute coronary syndrome (ACS).18

If the presentation is not acute, the ECG is nonspecific, and cardiac troponins are normal, then the stable patient may discharged. Alternatively, the patient may receive further testing to help determine the etiology of chest pain and the appropriate management, in which case the risk of CAD must be assessed based on patient history and presentation. A patient's pretest CAD risk can inform which test or procedure is most appropriate as a first step towards diagnosing CAD.

A diagnosis of CAD can be made by looking for evidence of the pathophysiologic processes of disease, including anatomic changes of the arterial wall, impaired myocardial perfusion, or consequences of impaired perfusion such as myocardial contractile dysfunction. Historically, invasive coronary angiography (ICA) has been considered the standard reference diagnostic test for anatomic CAD, defined here as any obstructive lesion that is consistent with symptoms or that may carry an increased risk of ACS, although its invasive nature makes it less ideal in many patients because of its associated risks and costs. Noninvasive tests are another option, and provide diagnostic and prognostic information that can improve risk stratification, thus guiding subsequent testing and interventions. Noninvasive diagnostic tests can be broadly divided into two categories: functional tests and anatomic tests. Functional tests provide information not provided by standard ICA, such as whether symptoms are correlated with areas of ischemia. Functional tests include exercise ECG, exercise/pharmacologic stress echocardiography, exercise/pharmacologic cardiac nuclear imaging with single-photon emission computed tomography (SPECT) or positron emission tomography (PET), pharmacologic stress magnetic resonance imaging (MRI), computed tomography (CT), and Doppler ultrasound-derived flow reserve measurements. Noninvasive anatomic tests include coronary CT angiography (CCTA) and coronary artery calcium scoring (CACS). ACCF/AHA Appropriate Use Criteria suggest that, as a general rule, functional testing is more informative than noninvasive anatomic evaluation and exercise testing is more informative than pharmacologic testing.19 Each of these tests is described in more detail in the following sections.

### Impact of Pretest Risk on Choice of Diagnostic Test

Further diagnostic testing beyond the resting ECG may be considered appropriate in patients who are symptomatic based on whether they are considered as low (less than 10% pretest probability of CAD), intermediate (10%–90% pretest probability of CAD), or high (greater than 90% pretest probability of CAD). The 2012 ACCF/AHA Guideline states that diagnostic testing is most valuable when the pretest probability of ischemic heart diseases is intermediate (10%–90%)8 and provides a range of options for which test may be used in a given scenario. However, the effectiveness of different modalities with regard to impact on clinical outcomes is not compared.8 Currently, clinical practice utilizes a variety of tests as the initial (and additional) diagnostic tests for patients at intermediate pretest risk of CAD.

Three primary areas of uncertainty exist regarding which tests, if any, may be most suitable and most beneficial for specific patient scenarios in patients who present with symptoms suggestive of CAD but do not have prior history of it, and these areas helped to frame to Key Questions of this systematic review. Namely:

- In patients with low pretest probability of CAD (<10%), are clinical outcomes improved by use of nonimaging stress testing, imaging stress testing, or no further testing? It is not clear whether imaging may be necessary in this group of patients or if there are specific subgroups of low-risk patients who might benefit more from one type of testing than another or who should have no further testing.
- How do tests compare with regard to improvement in clinical outcomes (e.g., MI, premature mortality, and congestive heart failure) in patients whose risk is very low (<5%) or in patients with intermediate to high risk? How do tests differ in their ability to reclassify patient risk after the test and to influence appropriate patient management?
- Are there differences in clinical outcomes following anatomic versus functional testing in either the low-risk group or the group with intermediate to high risk?

The overarching conceptual flow for initiating noninvasive testing based on pretest risk assessment is shown in Figure 1.

Figure 1 Overarching conceptual flow for initiating noninvasive testing based on risk assessment following initial clinical evaluation

CAD = coronary artery disease; ECG = electrocardiogram; PE = physical exam

This figure is a flow diagram that provides an overview of the conceptual flow for initiating noninvasive testing based on risk assessment following the initial clinical evaluation. The diagram delineates the most common general decision points and options for the use of noninvasive testing based on risk assessment. At each decision point in the diagram, an arrow points to the next step or steps in the process. When a person presents with symptoms suspicious for coronary artery disease (CAD) (far left of diagram) they undergo a clinical evaluation which consists of a physical exam, history, and a resting electrocardiogram (ECG). Based on the results of the clinical evaluation, a person will be categorized into one of three pre-test risk categories: intermediate or high risk, low risk, or very low risk. Those considered to be at intermediate or high risk go on to have either functional or anatomic imaging. For those considered to be at low risk, the type of testing they receive depends on their resting ECG results. If their ECG was abnormal, functional imaging, anatomical imaging, or no further testing are considered; if their ECG was normal, stress ECG, anatomic imaging, or no further testing are considered. Lastly, those at very low risk go on to have stress ECG either with or without imaging or no futher testing.

Patients at low pretest risk may undergo noninvasive testing to further delineate their risk and to provide a basis for clinical decisionmaking, although in some cases, an alternate explanation for the symptoms (such as heart burn, costochondritis, or pulmonary disease) may be evaluated first. Patients at intermediate risk commonly undergo noninvasive testing followed by appropriate treatment for comorbidities and risk factors. The ACCF/AHA intermediate range is intentionally broad, reflecting the availability of noninvasive tests that have been viewed as both safe and effective, to further stratify risk in the “intermediate pretest risk” category. In other words, the low end of the intermediate range is extended irrespective of cost because of the important health consequences of missing disease, but also results in a situation in which testing is performed in a very large number of individuals who do not have disease.9 The high end is extended because of the combination of the somewhat high cost and risk of ICA and reasonably high sensitivity of testing to detect high-risk obstructive disease. Patients at high risk may undergo noninvasive testing, although at times clinicians may appropriately decide to bypass noninvasive stress testing and proceed directly to ICA.19 This is more frequently done in patients who present to the emergency department (ED) with typical symptoms. In patients for whom clinical judgment remains equivocal, an additional test to further identify risk may be pursued.

### Noninvasive Diagnostic Tests

#### Noninvasive Functional Tests

Functional tests of interest include exercise ECG, exercise/pharmacologic stress echocardiography, exercise/pharmacologic cardiac nuclear imaging with SPECT or PET, and pharmacologic stress MRI. Additional details for each test are available in Table 1.

Table 1 Overview of included functional noninvasive tests

Test | General Use | Advantages | Disadvantages | Diagnostic Threshold and Post-Test Risk
Exercise Electrocardiography, Exercise Treadmill Testing | - Preferred initial test if there are no contraindications; - Not appropriate if there are baseline abnormalities in the ECG; - Not appropriate for patients who cannot exercise (leg claudication, deconditioning, arthritis, pulmonary disease); - Typically avoided in premenopausal women because of poor sensitivity and specificity; - Typically performed on a treadmill using various protocols (commonly Bruce protocol) | - Low cost; quick; - Functional capacity assessed; - High sensitivity for severe CAD such as multivessel disease or left main occlusive CAD | - Suboptimal sensitivity; - Low detection rate for single vessel disease; - Nondiagnostic with abnormal ECG; - Patient needs to achieve maximum heart rate; - Wide variability in sensitivity and specificity for exercise ETT has been reported across studies; - There are specific ECG criteria which determine positive and high risk for a treadmill test | Abnormal:; - >1 mm ST depression in 2 contiguous leads; - Arrhythmia; - Below average exercise capacity; High risk:; - Stress Score less than or equal to -11; - Abnormal hemodynamic response
Stress Echocardiography (exercise or pharmacologic) | - Assessment of ventricular size and function; - Assessment of wall motion abnormalities; - Visual assessment of myocardial response to stress agent.; - Exercise can be upright or supine bicycle or treadmill; - Dobutamine can be used for patients unable to exercise; - Preferred in those who are unable to exercise; - Can be used in patients with abnormal ECGs (except LBBB) | - Improved sensitivity and specificity vs. ECG; - Short exam time; simple and convenient to perform; - No radiation; - Evaluate cardiac function and structural abnormalities at the same time; - Allows localization of ischemia; - Exercise and dobutamine stress have similar value | - Decreased sensitivity for detection of single vessel disease or mild stenosis with post-exercise imaging; - Infarct zone ischemia can be difficult to detect; - Operator dependent; no quantitative analysis; - Limited by poor image quality (body habitus, pulmonary disease) and interpretation is more difficult if resting wall motion abnormalities | Abnormal:; - New WMAs with stress; - Abnormal LVEF with stress; High Risk:; - LVEF <35% at rest or during exercise; - WMA involving at least 2 of 16 segments developing with exercise or low dose dobutamine (10 mcg/kg/min) on a stress echocardiography; - WMA (>2 segments) developing at a low heart rate (<120 bpm); - Evidence of extensive ischemia on stress testing
Single Photon Emission Computed Tomography, aka myocardial scintigraphy, aka nuclear stress testing (this may be combined with scintigraphy or planar imaging) | - Assessment of ventricular size and function (computer generated); - Assessment of wall motion abnormalities (visual assessment; quite limited); - Assessment of viability; - Preferred for patients with LBBB; - Appropriate for those with poor echocardiography windows; - Stress agents include: regadenoson, adenosine, dipyridamole, and dobutamine; - Imaging agents include: 99mTc-MIBI (sestamibi), thallium, technetium, and tetrofosmin | - Evaluate perfusion (both viability and ischemia) and function; - Improved sensitivity and specificity vs. ECG; - Exercise and pharmacologic stress have similar value; - Can be quantitative | - Limited by soft tissue attenuation (body habitus, breast artifact, and liver artifact) and motion artifact; - Involves radiation exposure (∽12 mSv to 37 mSv if dual isotope protocol used); - Relative flow not absolute (can miss 3 vessel disease because of “balanced ischemia”) | Abnormal:; - Any perfusion defect; - WMAs; High Risk:; - Perfusion defect representing ≥10% of myocardium (particularly if anterior); - Multiple moderate perfusion defects; - Large fixed defect with transient ischemic LV dilation or increase in Lung to Heart Ratio; - Stress induced moderate defect with transient ischemic LV dilation or increase in Lung to Heart Ratio
Stress Positron Emission Testing | - Less clinically available; - Preferred in women and obese patients; - Assessment of ventricular size and function (visual with computer aid); - Assessment of ischemia and viability | - Accurate quantification of blood flow (absolute) because of trace kinetic modeling and attenuation correction; - PET has higher interpretive certainty than SPECT because of improved image quality (in particular for women and obese patients); - Measures absolute myocardial blood flow | - Restricted to pharmacologic stress; - High cost; - Low availability; - Radiation exposure (10–14 mSv) | Abnormal:; - Any perfusion defect; High Risk:; - Perfusion defect representing ≥10% of myocardium (particularly if anterior)
Stress Cardiac Magnetic Resonance Imaging | - Less clinically available; - Typically receive assessment of structure and function at the same time and can assess some cardiac indices (stroke volume); - Typically pharmacological – generally vasodilator perfusion stress is more commonly performed than dobutamine functional stress | - High spatial resolution; - Visualization of subendocardial perfusion; - Assessment of viability (delayed gadolinium enhancement, does not require stress agents); - No radiation; - Can provide anatomical evaluation as well | - More costly than many other noninvasive tests; - Not readily available; - Complex exam requiring specialized training | Abnormal:; - Vasodilator: any perfusion abnormality and/or infarct on late gadolinium enhancement; - Dobutamine: any or worsening new wall motion abnormality; High Risk:; - >3 of 32 stress perfusion defects; - >2 dobutamine-induced dysfunctional segments (out of 17 segments)

CAD = coronary artery disease; ECG = electrocardiography; ETT = exercise treadmill test; LBBB = left bundle branch block; LVEF = left ventricular ejection fraction; mSv = milliSeivert; PET = positron emission tomography; SPECT = single photon emission computed tomography; WMA = wall motion abnormality

Exercise ECG is often the recommended initial test. Exercise testing is more physiologic and allows for documentation of the workload at which a patient develops symptoms or ischemia (defined as >1 mm ST depression in 2 contiguous ECG leads). Exertional capacity (measured in metabolic equivalents) and hemodynamic response (abnormal heart rate or blood pressure response) to exercise also provides important prognostic information.20 The Duke treadmill score incorporates the exercise time, development of symptoms, and ST segment deviation on a treadmill test and has been correlated with outcomes.21 Exercise testing is widely available, does not require intravenous access or radiation exposure, is relatively inexpensive, and is widely validated. Despite these advantages, there are limitations including the fact that some patients are unable to exercise, some may have certain baseline ECG abnormalities that make the ECG uninterpretable during stress (left bundle branch block, left ventricular hypertrophy with repolarization abnormalities, ST segment depression of greater than or equal to 1 mm, and ventricular pre-excitation), and certain medications can cause false positive ST changes (notably digoxin).20

Stress echocardiography may be performed with exercise or through pharmacologic means (typically dobutamine). Stress echocardiography boasts improved sensitivity and specificity compared with ECG with improved localization of the at risk territory in a similar examination time frame and without radiation. It is limited by a poor image quality (often because of body habitus or pulmonary disease) and is operator dependent.

SPECT and PET are two forms of radionuclide imaging. Of the two, SPECT is more readily available and more commonly used. PET testing is much less frequently used because of limited availability and a relatively high cost. SPECT can be performed with exercise or pharmacologic agents and offers improved sensitivity and specificity compared with ECG testing and comparable diagnostic characteristics compared with echocardiography.22,23 In the case of patients with poor echocardiographic quality, this is the preferred test. SPECT can also be limited by artifacts from breast tissue, motion, and liver/gallbladder uptake of the imaging agents. While SPECT relies on relative blood flow and can miss balanced ischemia, PET provides absolute quantification of blood flow and offers improved visual certainty, which translates into improved sensitivity and specificity.24 Radionuclide imaging requires exposure to radiation which ECG testing and echocardiography do not.

Cardiac magnetic resonance imaging is an imaging modality which offers the ability to evaluate rest and stress perfusion for ischemia, cine imaging for cardiac function, and late gadolinium enhancement for evaluation of prior infarction. The operational diagnostic characteristics are superior to echocardiography and SPECT imaging.25,26 Despite its improved sensitivity and specificity, this modality is not readily available, in part because of high cost of equipment and limited availability. In addition, exploration is needed regarding information on the impact of such advances in imaging on patient well-being, downstream testing, use of procedures, and unintended findings.27 Because of technological limitations it is also, practically, limited to pharmacologic stress agents.

#### Noninvasive Anatomic Tests

Noninvasive anatomic tests include CCTA and CACS, although CACS is rarely considered appropriate in symptomatic patients. Additional details for each test are available in Table 2.

Table 2 Overview of included anatomic noninvasive tests

Test | Use | Advantages | Disadvantages | Diagnostic Threshold and Post-Test Risk
Coronary Computed Tomography Angiography (≥64 slice) | - Used as a rule-out test for low likelihood patients with chest pain; - Identify or exclude coronary luminal diameter stenoses exceeding 50%; - Clinically used in patients (assuming no diagnosis of CAD) with atypical symptoms or nondiagnostic results of a stress test or those at high risk for catheterization; - In practice it is most common to use 64-slice or more; - Can be retrospective or prospective (ECG-gated); - In EBCT or MDCT the X-ray source point is stationary, but electron beam is swept electronically; - This will almost always include a coronary artery calcium score; - Contrast agents used include: iopamidol (Isovue), iohexol (Omnipaque), ioversol (Optiray), ioxilan (Oxilan), ioxaglate (Hexabrix), and iodixanol (Visipaque) | - Noninvasive angiogram to rule out significant stenosis; - Unlike cardiac CT-quantified calcium scoring, angiography detects obstructive CAD; - Rapid; - Good negative predictive value; - Other causes of chest pain (aortic aneurysm); - High sensitivity | - Ischemia not confirmed; - Quality depends on slow heart rate; - Specificity 60%-80%; - Distal vessels difficult; - Cardiac motion artifact; - Poor quality if heart rate not well controlled (requires beta blockers); - Heavy calcification causes “bloom artifact” limiting assessment of lumen; - Fractional flow reserve is limited to proprietary software with limited validation (excluded from this analysis); - Required reconstruction of images and is time intensive; - Radiation exposure (modern is ∽3 mSv); - Limited by fast or irregular heart rate and/or motion | Abnormal:; - Any luminal irregularities (important for establishing need for secondary prevention strategies for preventing disease advancement); High Risk:; - Left main ≥50% narrowing; - Proximal LAD ≥70% narrowing; - 3 vessel disease; - Left main equivalent (i.e. proximal LAD and proximal circumflex artery)
Coronary Artery Calcium Score | - Typically used as a screening test for asymptomatic patients; - Uses the amount of calcium present in an artery to calculate a score (typically using Agatson method); - Can be performed using most CT modality and does not require contrast agent | - Screening test for asymptomatic patients to detect coronary artery calcium | - Does not detect ischemia or degree of vessel narrowing; - Radiation exposure | Various thresholds exist. The presence of any calcium in a young population is abnormal (i.e. score >0) and any calcium is associated with a higher risk. There are age/sex matched norms. >100 is associated with a 10 fold higher risk than zero. >400 is considered an indication for statin in the current guidelines regardless of other risk factors.

CAD = coronary artery disease; CT = computed tomography, ECG = electrocardiography; EBCT = electron beam computed tomography; MDCT = multidetector computed tomography; LAD = left anterior descending artery

CCTA is a relatively accessible test that has a rapid scanning time. The necessary hardware is available in most hospitals, and state-of-the-art machines have a 64-slice scanner and the ability to inject contrast. Software packages available for most modern CT scanners assist in the acquisition and processing of images. However, there are many patient-related factors which can interfere with diagnostic quality, including irregular heart rate (such as atrial fibrillation), heart rates that are too fast (>70 bpm), inability to sustain a breath hold for 5 seconds, severe calcification of the coronary arteries, and small coronary artery vessel diameter (<1.5 mm). There are additional risks incurred by the injection of iodinated contrast agents for patients who have a history of allergy or those with reduced renal function and there is some radiation exposure. Overall, adoption of CCTA has been variable across institutions and states in clinical practice. CCTA may be favored for patients considered at low risk for CAD because of its perceived high negative predictive value. It is often perceived as a “rule-out” test for CAD.28-31

CACS is obtained through performance of a noncontrast CT scan followed by a post-processing algorithm to determine an Agatson score, a volume score, or the presence of a calcium mass. The most widely used and best established measure of coronary artery calcium is the Agatson score. CACS is readily obtained and highly reproducible, and is most frequently used in asymptomatic patients for cardiovascular risk assessment. CACS is rarely appropriate for symptomatic patients, as the inability to detect calcium in the coronary arteries does not eliminate the possibility of significant stenoses.19,32

### Invasive Coronary Angiography

Historically, ICA has been considered the standard reference diagnostic test for anatomic CAD and provides information on coronary artery anatomy and lumen obstruction through introduction of a radiopaque contrast dye while obtaining concurrent fluoroscopic cine images. ICA allows visualization of the size, position, and possible stenotic areas in vessels. Various thresholds for occlusion have been used (e.g., ≥50% or ≥70% occlusion) for diagnosis of CAD. Access to the arterial system is most commonly obtained through placement of a sheath in the femoral or the radial artery and requires instrumentation in the ascending thoracic aorta proximal to the head vessels. Complications and death are rare in ICA procedures with a majority of the literature reporting ICA harms being case studies. Adverse reactions to the contrast dye may occur, including allergic response; renal dysfunction; vascular injury including arterial dissection or perforation; and embolism (i.e., strokes, transient ischemic attacks, or limb ischemia). In addition, the procedure exposes patients to ionizing radiation.

ICA may overestimate or underestimate disease depending on a variety of technical factors as well as the complexity of coronary anatomy and plaque configuration. Many lesions are eccentric, so the apparent degree of stenosis can vary depending on the angle of visualization, and reproducibility on measurement of stenosis is considered only moderate.8,33-35 ICA depicts coronary anatomy in a planar two-dimensional silhouette of the arterial lumen and interpretation can be confounded by vessel tortuosity, overlap of radiodense structures, and irregularities in plaque shape or flow of the contrast dye.34 There are aspects of the coronary anatomy which portend a high risk for future events including arterial remodeling, and many high-risk features of a plaque (e.g., a vulnerable plaque) are not evident with ICA. ICA serves best as reference standard for anatomic tests and to date, there is not a comparable reference standard for tests evaluating functional changes secondary to ischemic heart disease. These limitations have led some to question the true value of ICA as the best reference standard for determining test accuracy, particularly for functional tests. Efforts to improve the diagnostic accuracy of coronary angiography have led to intravascular ultrasound (IVUS) and fractional flow reserve (FFR) though both techniques are reliant on having obtained earlier angiographic views.

### Accuracy of Noninvasive Tests Compared With ICA

Increasingly, experts in cardiovascular health indicate that evidence on the value of noninvasive diagnostic cardiovascular testing needs to expand beyond traditional measures of test performance, such as sensitivity and specificity compared with a given reference standard and focus on evaluating the impact of such testing on hard cardiovascular outcomes.36 Thus, while diagnostic accuracy measures provide important information on test performance, the primary focus of this report is to determine whether noninvasive tests improve clinical health outcomes and impact patient management. In keeping with this focus, information on the traditional test parameters of diagnostic accuracy are described here in order to provide a foundation for the report and were not examined via the formal systematic review process.

To provide a general overview of the diagnostic accuracy of the included noninvasive tests in the target population of symptomatic patients without known CAD, a targeted search of the literature was done to identify one or two moderate- to high-quality systematic reviews (based on the AMSTAR checklist37) that compared noninvasive tests included in this report (see Tables 1 and 2) with the historic gold standard of ICA in terms of traditional diagnostic test performance measures (i.e., sensitivity, specificity, positive/negative predictive value, and positive/negative likelihood ratio).

The diagnostic test characteristics of all the included tests compared with the test results from ICA are summarized in Table 3, with more specific details available in Appendix H. The values of the various diagnostic test characteristics in these tables were taken from or calculated from the values reported in the included systematic reviews. Measures of diagnostic accuracy among patients with suspected CAD varied among the various tests: sensitivity ranged from 62 to 100 percent; specificity ranged from 68 to 89 percent; positive predictive value ranged from 57 to 94 percent; and negative predictive value ranged from 72 to 99 percent. Exercise ECG had the lowest overall diagnostic accuracy and CCTA had the highest diagnostic accuracy relative to ICA, which is perhaps consistent with CCTA as the test most similar to ICA in what it measures. The two tests classified as anatomic tests (CACS and CCTA) had the highest negative predictive values, which indicate a lower percentage of patients with significant coronary artery stenosis by ICA that would be missed by these two tests. Otherwise, there is no clear pattern to the characteristics of the different tests. For individual tests or across various tests, there is also no clear pattern in the differences between test characteristics among patients suspected of CAD only compared with all patients (i.e., suspected CAD and known CAD combined). The fact that the functional tests had lower negative predictive values does not imply that these tests would necessarily perform worse than ICA for purposes of predicting clinical outcomes such as worsening angina, incident MI, or CAD death, which is the focus of the current systematic review.

Table 3 Summary of diagnostic accuracy of noninvasive tests compared with invasive coronary angiography

Test | Population | Sensitivity | Specificity | PPV | NPV | LR + | LR - | Prevalence
Exercise Electrocardiography | Overall^*^ | 67% | 46% | 41% | 72% | NR | NR | NR
Exercise Electrocardiography | Suspected CAD | 62% | 68% | 57% | 72% | 1.94 | 0.56 | 41%
Stress Echocardiography | Overall^†^ | 84–87% | 72–77% | 85–89% | 69–73% | 3.08–3.65 | 0.18–0.21 | 66–68%
Stress Echocardiography | Suspected CAD | 88% | 89% | 93% | 80% | 8.35 | 0.13 | 64%
Single Photon Emission Computed Tomography | Overall | 83–85% | 77–85% | 79–85% | 79–85% | 3.56–5.13 | 0.18–0.22 | 50%
Single Photon Emission Computed Tomography | Suspected CAD | 83–84% | 79–85% | 72–85% | 84% | 3.88–5.01 | 0.19–0.21 | 41%^‡^
Positron Emission Tomography | Overall | 82–90% | 86–88% | 93–96% | 53–84% | 5.57–5.88 | 0.11–0.21 | 63–80%
Positron Emission Tomography | Suspected CAD | 90–91% | 82–91% | 94% | 75–84% | 4.97–8.89 | 0.11 | 75%^‡^
Stress Magnetic Resonance Imaging | Overall | 83% | 86% | 94% | 68% | 5.93 | 0.20 | 71%
Stress Magnetic Resonance Imaging | Suspected CAD | 81% | 87% | 93% | 70% | 6.39 | 0.21 | 67%
Coronary Artery Calcium Scoring | Suspected CAD | 98–99% | 35–40% | 65–68% | 93–95% | 1.51 | 0.04 | 55–56%
Coronary Computed Tomography Angiography (Low radiation dose) § | Suspected CAD | 100% | 89% | 93% | 99% | 9.2 | 0.00 | 58%
Coronary Computed Tomography Angiography (Radiation dose not specified) | Suspected CAD | 98.2% | 81.6% | 90.5% | 99.0% | NR | NR | 59.9% (28–85%)

CAD = coronary artery disease; LR + = positive likelihood ratio; LR - = negative likelihood ratio; angiography; NPV = negative predictive value; NR = not reported; PPV = positive predictive value

* Values for diagnostic test measures are taken from or derived from systematic reviews cited in Appendix H.

† Values reported are for combined groups of patients with known CAD and patients with suspected (but not confirmed) CAD.

‡ Mean prevalence only available or calculable for one of the two included reviews.

§ All included studies used prospective electrocardiography gating for CT; uses much lower radiation doses than other techniques.

### Radiation Exposure in Noninvasive Cardiac Testing

Medical imaging is the largest controllable source of radiation exposure to the American public38 and scrutiny of cardiac imaging procedures has increased based on concerns related to greater utilization and lack of adherence to quality control procedures.39 In clinical decisionmaking, the levels of exposure for a given test need to be put in the context of other radiation-utilizing tests that may be part of the clinical pathway, as the possible cumulative effects of repeated radiation exposure are of concern. Potential benefits and risks, including any related to not performing the test, should be carefully considered before ordering tests that will expose patients to ionizing radiation. Final determination of net benefit for a given clinical scenario reflects the values and judgments of the individuals making the decisions.

Current guidance from regulatory bodies is that no threshold exits and that exposure should be kept as low as reasonably achievable (ALARA). ALARA takes into consideration the importance of assessing the “benefit to risk ratio” to balance the importance of information needed from a procedure with the potential risks related to radiation exposure.

ACCF/AHA Guidelines recommend following ALARA in all patient populations and provide recommendations for specific cardiac testing modalities that involve ionizing radiation and note that care should be taken when exposing low-risk patients, particularly young patients, to ionizing radiation.8 They further note that all noninvasive stress testing carries some risk, even if ionizing radiation is not involved. The American College of Radiology reports that ICA is not usually appropriate for diagnosing CAD in patients with low probability.40 SPECT, CCTA, echocardiography, and MRI are all considered more appropriate than ICA for low CAD probability. Of these modalities, the ACR considers CCTA with various contrast and dose techniques to be the most appropriate – receiving the rating of “usually appropriate”.

To date, no large-scale epidemiologic studies evaluating cancer risk associated with cardiac imaging procedures involving ionizing radiation have been published, and there is uncertainty and controversy with regard to the actual risk of low-dose radiation from cardiac testing. For context, estimates of typical effective dose for environmental and medical sources of radiation are outlined in Table 4. Some radiation exposure occurs naturally and during activities of daily living. As seen in Table 4, estimated radiation dose for various noninvasive tests for CAD vary by test. The effective doses for imaging techniques from studies included in this report range from <1 mSv to 16 mSv. The CT radiation dose is influenced by a number of factors including prospective versus retrospective gating, use of multidectors rows, type of processing, and patient body morphometrics. Use of prospective gating significantly reduces the effective dose while obtaining a higher quality of image compared with retrospective gating.41 Further, using prospective gating with a tube potential of <100 kVp requires a lower effective dose than prospective gating used with a tube potential ≥100 kVp.42 Other imaging parameters such as contrast media used and slice number affect the effective dose of CCTA, which is why effective dose ranges widely for this imaging technique. The values in the following table are based on literature estimates and are subject to change dependent on the imaging parameters utilized.

Table 4 Overview of radiation exposure ranges^*^

Radiation Exposure Type | | | Total Effective Dose (mSv)
Environmental Exposures | Round-trip flight, New York – Seattle | | 0.06
Environmental Exposures | Naturally occurring | | 3/year
Environmental Exposures | July 1971 lunar landing | | 5
Environmental Exposures | Nuclear worker | | 20
Diagnostic and Procedural Exposures | Echocardiography | | 0
Diagnostic and Procedural Exposures | CMRI | | 0
Diagnostic and Procedural Exposures | ECG | | 0
Diagnostic and Procedural Exposures | Dental CT | | 0.2
Diagnostic and Procedural Exposures | Mammogram | | 0.4
Diagnostic and Procedural Exposures | CACS | Range found in studies in this report | 0.69–0.8
Diagnostic and Procedural Exposures | CACS | Range reported in Einstein 2014 | 1–5
Diagnostic and Procedural Exposures | ICA | Range reported by Einstein 2014 | 2–20
Diagnostic and Procedural Exposures | ICA | Range reported by ACR | 1–10 (with or without ventriculography)
Diagnostic and Procedural Exposures | CCTA | Range found in studies in this report | 3.8–15.1
Diagnostic and Procedural Exposures | CCTA | Range reported in Einstein 2007 and 2014 | <0.5–30
Diagnostic and Procedural Exposures | CCTA | Range reported by ACR | 1–30 (using various contrast and dose techniques)
Diagnostic and Procedural Exposures | CCTA | Range reported by Cerqueira 2010 | 5–10
Diagnostic and Procedural Exposures | Fluoroscopy for PCI | Range reported by Einstein 2014 | 5–57
Diagnostic and Procedural Exposures | PET | Range found in studies in this report | 6.0
Diagnostic and Procedural Exposures | PET | Range reported in Einstein 2014 | 2 (^13^N ammonia); 4 (^82^Rb); 7 (^18^F FDG – not currently FDA approved)
Diagnostic and Procedural Exposures | SPECT | Range found in studies in this report | 10.5–14
Diagnostic and Procedural Exposures | SPECT | Ranges reported in Einstein 2014 | 2.3–14 (^99m^Tc Tetrofosmin); 2.7–18 (^99m^Tc Sestamibi); 15 (^201^Tl); 22 (^201^Tl/^99m^Tc Tetrofosmin dual-isotope); 23 (^201^Tl/^99m^Tc Sestamibi dual-isotope)
Diagnostic and Procedural Exposures | SPECT | Range reported by ACR | 10–30
Diagnostic and Procedural Exposures | SPECT | Reported by Halliburton 2011 | 11 (^99m^Tc)
Diagnostic and Procedural Exposures | Coronary radiofrequency ablation | | 15
Diagnostic and Procedural Exposures | Pelvic vein embolization | | 60

CACS = coronary artery calcium scoring; CCTA = coronary computed tomography angiography; CMR = cardiac magnetic resonance imaging; ECG = electrocardiogram; ECHO = echocardiography; ICA = invasive coronary angiography; mSv = milliSeiverts; PCI = percutaneous coronary intervention; PET = positron emission tomography; SPECT = single-photon emission tomography

* The overview was compiled using data from several publications.38-40,43-46

### Treatment of Stable Coronary Artery Disease

The goal of testing is to identify people who would benefit from treatment. Where efficacious treatment is available and test costs and adverse events are comparable, test sensitivity may be most important to consider. In situations in which there is little difference in treatment outcomes, avoiding false positives is important and thus specificity may be more important. The focus of this report is on stable, symptomatic patients without prior CAD presenting for an initial test to determine the presence of CAD. There are a number of treatment options for this population. The extent to which a test leads to the appropriate treatment is reflected in the impact on clinical outcomes. Because one of the outcomes of interest for this report is whether noninvasive tests differ in terms of referral for treatment (e.g., revascularization), a brief background on treatment options is provided here.

Treatment of stable CAD is initially guided by the patient's post-test risk stratification, symptoms, and non-CAD comorbidities.8,47,48 Based on the predicted annual cardiac mortality rate, recent clinical guidelines provide thresholds of low risk (≤1% per year), intermediate risk (1%–3% per year), and high risk (≥3% per year).8 As shown in Figure 2, patients considered to be at low or intermediate risk of cardiac mortality should generally be treated with medical therapy alone, while those found to be at high risk should receive both medical therapy and revascularization.

Figure 2 Initial treatment pathways for patients diagnosed with CAD

CAD = coronary artery disease

This figure is a flow diagram that provides an overview of the initial treatment pathways for patients diagnosed with stable CAD. Treatment is initially guided by the patient's posttest risk stratification. In general, patients considered to be a low or intermediate risk should be treated with optimal medical which consists of antianginal, antiplatelet, and lipid-lowering drugs as well as lifestyle changes, while those found to be at high risk should receive both optimal medial therapy and revascularization (either percutaneous coronary intervention or coronary artery bypass graft).

#### Medical Therapy

Optimal (or guideline-directed) medical therapy is optimized on a per-patient basis depending on patient characteristics and guideline recommendations. Medical therapy includes lifestyle modifications (physical activity, smoking cessations, weight management, and dietary changes), treatment of secondary conditions such as diabetes and hypertension, risk modification with antiplatelet drugs, management of lipid levels, and treatment of angina symptoms if present.

Lifestyle interventions including primary risk reduction strategies such as exercise and increased physical activity, smoking cessation, and weight management are associated with lower rates of cardiovascular outcomes and can improve outcome following a nonfatal event. Both antiplatelet drugs (primarily aspirin) and lipid-lowering drugs (e.g., statins) are used to reduce the risk of thrombotic coronary events through stabilization of the coronary plaque to prevent rupture and thrombosis. Angina is treated with a variety of drugs that reduce myocardial oxygen demand and therefore reduce anginal events including beta-blockers, calcium channel blockers, nitrates, and ranolazine. Beta-blockers are typically recommended as first-line treatment because of evidence that they reduce the risk of mortality post-MI and in those with hypertension. In low- to intermediate-risk patients treated only with medical therapy, the benefits of initial treatments identified in Figure 2 are outlined in Table 5.

Table 5 Effects of medical therapy for stable coronary artery disease

Intervention | Purpose of Treatment | Coronary Event Benefits | Potential Harms
Antiplatelet; Aspirin | Reduce risk of clot development | 33% reduction in serious vascular event such as nonfatal MI, nonfatal stroke, or vascular death.49 | Risk of a major extracranial bleed with aspirin (<75 to 325 mg): odds ratios 1.4 to 1.7; absolute event rates 1.8 to 2.5%.49
Lipid-lowering; Statins | Reduce risk of cholesterol-related effects | 18% reduction in coronary death rate, 24% reduction in the composite of nonfatal MI or coronary death, nonfatal or fatal stroke and coronary or noncoronary revascularization.50 22% reduction in risk of CAD death, nonfatal MI, resuscitation after cardiac arrest, or fatal or nonfatal stroke with high dose vs. standard dose statin (i.e. atorvastatin 10 mg vs. 80 mg).51 | Potential myalgias, rhabdomyolysis, elevated liver enzymes.
Beta-blockers | Reduce angina symptoms | At least 50% reduction in the frequency of angina attacks.52 No impact on cardiovascular outcomes except when used post-MI. | Potential reduced heart rate with exercise, low blood pressure, lethargy.
Calcium Channel Blockers | Reduce angina symptoms | Both dihydropyridines and nondihydropyridine calcium channel blockers reduce the frequency of angina attacks by at least 50%.53 Benefit on cardiovascular outcomes has not been shown. | Peripheral edema, flushing, headaches Verapamil: constipation short-acting nifedipine: reflex tachycardia. Verapamil and diltiazem: reduce cardiac contractility and slow cardiac conduction.
Nitrates | Reduce angina symptoms | Immediate release preparations used for treatment of acute angina. Longer-acting forms improve exercise tolerance and reduce degree of ST segment depression during exercise, but tolerance develops quickly. Intermittent dosing may help. No benefit in the frequency of angina attacks has been found.54 | Flushing, headache hypotension. Development of tolerance. Multiple contraindications exist.
Ranolazine | Reduce angina symptoms | 22% reduction in recurrent ischemia, 33% reduction in worsening angina, results in greater exercise duration (514 vs. 482 seconds).55 | Dose-dependent increase in the QT interval; multiple contraindications and drug interactions exist.

CAD = coronary artery disease; MI = myocardial infarction

#### Revascularization

Revascularization methods include coronary artery bypass graft (CABG) surgery and percutaneous coronary interventions (PCI). The determination of which revascularization approach is used depends in part on patient presentation and characteristics, primarily severity of CAD (e.g., number of vessels involved, degree of stenosis, and SYNTAX [Synergy Between PCI With Taxus and Cardiac Surgery] score), but other factors such as age, diagnosis of diabetes, peripheral vascular disease or heart failure, and smoking status also play a role. The SYNTAX score is an assessment of overall coronary lesion complexity, with higher scores representing more complex coronary disease (low scores is defined as ≤22, an intermediate score as 23–32, and a high score ≤33).

PCI is an X-ray guided procedure that involves threading a catheter through a major artery to the site of the damaged vessel and inflating an attached balloon (or other device) to open the affected vessel. A stent may be placed at the damaged site to keep the vessel open. PCI methods have progressed with time, beginning with balloon angioplasty, then bare metal stent placement, and more recently drug eluting stent placement. The drugs in the drug eluting stents (e.g., sirolimus, paclitaxel, zotaralimus, everolimus, and biolimus) inhibit vascular smooth muscle cell proliferation and reduce stent thrombosis and restenosis. To date, relative to medical therapy alone, PCI has not been shown to significantly improve all-cause death, cardiac death or MI, or nonfatal MI in any individual trial, or in meta-analyses of trials when limited to those that exclude patients with recent ACS,56-58 and may increase the risk of MI in the short term.59-62 In a recent meta-analysis of eight trials (7229 patients) comparing medical therapy alone with coronary stent placement plus medical therapy in patients with stable CAD (including post-MI), rates of death, nonfatal MI, unplanned revascularization and persistent angina were not found statistically different through a mean of 4.3 years followup.63 However, PCI has been shown to reduce symptoms and incidence of angina. In a study with 10-year followup, 59 percent of patients who underwent PCI were free of angina compared with 43 percent of those treated with medical therapy.64

CABG, or heart bypass surgery, involves grafting of arteries (internal mammary) and/or veins (e.g., saphenous vein) in order to allow blood flow to bypass the damaged vessel(s). This procedure has been shown to improve outcomes in patients with left main coronary artery disease when compared with medical therapy alone. In the most recent trial, 10-year survival rates were similar for CABG versus medical therapy, but rates of MI, repeat revascularization, and a composite endpoint (overall mortality, Q-wave MI, or refractory angina that required revascularization) were significantly worse with medical therapy.64

CABG versus PCI. A recent systematic review that included results from 13 RCTs and 5 meta-analyses evaluated the relative effects of the revascularization options in patients with unprotected left main disease (ULMD), multivessel CAD, diabetes mellitus, and left ventricular dysfunction (LVD).65 The review concluded that in patients with more complex CAD, CABG results in a lower risk of mortality and a composite outcome (all-cause mortality, MI, stroke, or repeat revascularization) versus PCI with drug eluting stents. Further, PCI resulted in higher rates of revascularization. However, the risk of stroke is higher after CABG than after PCI. Consistent with other reports, patients with diabetes have a lower risk of the composite endpoint following CABG versus PCI. Another meta-analysis of individual patient-level data from 10 CAD trials compared CAGB PCI (with balloon angioplasty or bare-metal stents) or CABG and found that the 5-year mortality rate was slightly lower in patients with stable symptoms as well as in those with no history of MI.66

## Scope and Key Questions

The objective of this review is to assess the effectiveness of noninvasive technologies for the diagnosis of CAD or dysfunction that results in symptoms attributable to myocardial ischemia in patients who present with signs or symptoms suggestive of CAD, whose condition is considered to be stable, and who have no known history of CAD. The intended focus is on clinical outcomes and clinical pathways following the first diagnostic test performed as result of initial risk assessment, which includes clinical presentation and physical exam, family history of CAD, and findings on resting ECG. Further, this report focuses on established tests for diagnosing CAD. Harms related to both the initial test and subsequent testing are evaluated. Information on traditional measures of accuracy (e.g., sensitivity and specificity) of noninvasive tests versus the historically accepted gold standard of ICA is presented for context. The report focuses on patients with stable symptoms of suspected CAD; patients with definite ACS were excluded or did not comprise greater than 20 percent of study populations.

### Key Questions

In stable, symptomatic patients with suspected CAD who do not have previously diagnosed CAD and who have had a resting ECG:

1. For patients considered to be at very low or low risk for CAD, what is the comparative effectiveness of anatomic tests (compared with each other, usual care, or no testing):
  a. For improving primary clinical health outcomes (e.g., quality of life, avoidingMI)? In the absence of comparative studies linking testing with outcomes, do the tests predict future clinical events (predictive accuracy)?
  b. What are the adverse effects, consequences, or harms of testing?
  c. How do noninvasive tests differ in terms of clinical management based on test results, including referral for coronary angiography or additional noninvasive testing?
  d. What harms are associated with additional testing following anatomic tests?
  e. Is there differential effectiveness or harm based on patient characteristics (e.g., sex, age, comorbidities) or the patient's ability to exercise?
2. For patients considered to be at very low or low risk for CAD, what is the comparative effectiveness of functional tests (compared with each other, usual care, or no testing):
  a. For improving primary clinical health outcomes (e.g., quality of life, avoidingMI)? In the absence of comparative studies linking testing with outcomes, do the tests predict future clinical events (predictive accuracy)?
  b. What are the adverse effects, consequences, or harms of testing?
  c. How do noninvasive tests differ in terms of clinical management based on test results, including referral for coronary angiography or additional noninvasive testing?
  d. What harms are associated with additional testing following anatomic tests?
  e. Is there differential effectiveness or harm based on patient characteristics (e.g., sex, age, comorbidities) or the patient's ability to exercise?
3. For patients considered to be at intermediate to high risk for CAD, what is the comparative effectiveness of anatomic tests (compared with each other usual care, or no testing):
  a. For improving primary clinical health outcomes (e.g., quality of life, avoidingMI)? In the absence of comparative studies linking testing with outcomes, do the tests predict future clinical events (predictive accuracy)?
  b. What are the adverse effects, consequences, or harms of testing?
  c. How do noninvasive tests differ in terms of clinical management based on test results, including referral for coronary angiography or additional noninvasive testing?
  d. What harms are associated with additional testing following anatomic tests?
  e. Is there differential effectiveness or harm based on patient characteristics (e.g., sex, age, comorbidities) or the patient's ability to exercise?
4. For patients considered to be at intermediate to high risk for CAD, what is the comparative effectiveness of functional tests (compared with each other, usual care, or no testing):
  a. For improving primary clinical health outcomes (e.g., quality of life, avoiding MI)? In the absence of comparative studies linking testing with outcomes, do the tests predict future clinical events (predictive accuracy)?
  b. What are the adverse effects, consequences, or harms of testing?
  c. How do noninvasive tests differ in terms of clinical management based on test results, including referral for coronary angiography or additional noninvasive testing?
  d. What harms are associated with additional testing following anatomic tests?
  e. Is there differential effectiveness or harm based on patient characteristics (e.g., sex, age, comorbidities) or the patient's ability to exercise?
5. What is the comparative effectiveness of anatomic tests versus functional tests in those who are at very low or low risk for CAD?
  a. For improving primary clinical health outcomes (e.g., quality of life, avoiding MI)?
  b. What are the adverse effects, consequences, or harms of testing?
  c. How do noninvasive tests differ in terms of clinical management based on test results, including referral for coronary angiography or additional noninvasive testing?
  d. What harms are associated with additional testing following anatomic tests?
  e. Is there differential effectiveness or harm based on patient characteristics (e.g., sex, age, comorbidities) or the patient's ability to exercise?
6. What is the comparative effectiveness of anatomic tests versus functional tests in those who are at intermediate to high risk for CAD?
  a. For improving primary clinical health outcomes (e.g., quality of life, avoiding MI)?
  b. What are the adverse effects, consequences, or harms of testing?
  c. How do noninvasive tests differ in terms of clinical management based on test results, including referral for coronary angiography or additional noninvasive testing?
  d. What harms are associated with additional testing following anatomic tests?
  e. Is there differential effectiveness or harm based on patient characteristics (e.g., sex, age, comorbidities) or the patient's ability to exercise?

### Analytic Framework

The analytical framework for the systematic review is presented in Figure 3.

Figure 3 Analytic framework for noninvasive testing for coronary artery disease

BP = blood pressure; CABG = coronary artery bypass graft; CAD = coronary artery disease; DM = diabetes mellitus; KQ = Key Question; PCI = percutaneous coronary intervention

* People at very low or low risk are evaluated separately from those at intermediate to high risk when possible.

† KQ 1–6e: Potential modifiers related to differential efficacy and/or safety include patient factors (e.g., age, sex), comorbidities, and ability to exercise.

This figure, referred to as the analytical framework, depicts the Key Questions addressed in this review. In general, the figure illustrates the diagnostic and treatment course and the outcomes for each for a person presenting with symptoms of coronary artery disease (CAD) at either very low, low, or intermediate to high risk for CAD. For example, a patient (far left of diagram) who presents with symptoms suspicious for CAD may receive anatomic or functional testing. The testing may lead to a diagnosis of CAD or further risk stratification,which in turn impacts intermediate outcomes such as the need for additional testing or management options and ultimately the primary health outcomes (far right of the diagram). Harms that may result from either the initial test or subsequent testing are also represented (bottom of diagram) and may include procedural harms as well as the consequences and risks associated with diagnostic testing. The solid lines marked with Key Question numbers are those that this review will evaluate in a comparative way (diagnostic test versus diagnostic test). Key Questions 1-6e (differential efficacy and/or safety) are represented by a footnote (under diagram). The faded text represents the evidence of a relationship between intermediate outcomes and primary health outcomes and adverse events and is beyond the scope of this review.