# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Donald E. Casey, Jr., M.D., M.P.H., M.B.A.^*^
  * Provided input on Draft Report.
  Principal and Founder of IPO4Health
  Managing Director, Alvarez & Marsal Health Industry Group
  Adjunct Faculty, Thomas Jefferson College of Population Health
  Chicago, IL
- Nakela L. Cook, M.D., M.P.H., FACC^*^
  Chief Medical Officer
  Division of Cardiovascular Sciences
  National Heart, Lung, and Blood Institute
  Boston, MA
- Andrew J. Einstein, M.D., Ph.D.^*^
  Associate Professor of Medicine (in Radiology)
  Victoria and Esther Aboodi Cardiology Researcher
  Co-Director of Cardiac CT and MRI Director of Cardiac CT Research
  Columbia University Medical Center and New York-Presbyterian Hospital
  New York, NY
- Stephan D. Fihn, M.D., M.P.H., FACP^*^
  Professor, Department of Medicine
  University of Washington
  Director, Office of Analytics and Business Intelligence
  U.S. Department of Veterans Affairs
  Seattle, WA
- Thomas Gerber, M.D., Ph.D., FAHA, FACC^*^
  Cardiologist, Professor of Medicine and Radiology
  Mayo Clinic
  Rochester, MN
- Christopher M. Kramer, M.D.^*^
  Ruth C. Heede Professor of Cardiology
  Professor of Radiology
  Director, Cardiovascular Imaging Center
  University of Virginia Health System
  Charlottesville, VA
- Athena Poppas, M.D., FACC, FASE^*^
  Associate Professor of Medicine, Brown University
  Cardiologist, Director of Cardiovascular Imaging
  Rhode Island, Miriam and Newport Hospitals
  Providence, RI
- E. Kent Yucel, M.D.^*^
  Chair and Professor of Radiology
  Tufts University School of Medicine
  Boston, MA