# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- David Atkins, M.D., M.P.H.
  Director, Health Services Research & Development
  U.S. Department of Veterans Affairs
  Washington, DC
- Marcello di Carli, M.D.
  Assistant Professor of Radiology and Medicine
  Chief of Nuclear Medicine
  Brigham and Women's Hospital
  Harvard Medical School
  Boston, MA
- Pamela Douglas, M.D., M.A.C.C., FASE
  Professor of Medicine, Cardiology
  Director, Imaging Program
  Duke Clinical Research Institute
  Durham, NC
- Stephan D. Fihn, M.D., M.P.H., FACP
  Professor, Department of Medicine
  University of Washington
  Director, Office of Analytics and Business Intelligence
  U.S. Department of Veterans Affairs
  Seattle, WA
- Bernard J. Gersh, M.B., Ch.B., D.Phil.
  Professor of Medicine, Cardiovascular Diseases
  Mayo Clinic
  Rochester, MN
- Peter W. Groeneveld, M.D., M.S.
  Associate Professor of Medicine
  Perelman School of Medicine at University of Pennsylvania
  Philadelphia, PA
- Judith S. Hochman, M.D.
  Professor of Cardiology
  Senior Associate Dean for Clinical Sciences
  New York University Langone Medical Center
  New York, NY
- Joseph Hutter, M.D., M.S.
  Medical Officer
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Christopher M. Kramer, M.D.
  Ruth C. Heede Professor of Cardiology
  Professor of Radiology
  Director, Cardiovascular Imaging Center
  University of Virginia Health System
  Charlottesville, VA
- Leslee Shaw, Ph.D., FACC, FASNC, FAHA
  Professor of Medicine, Division of Cardiology
  Emory University School of Medicine
  Atlanta, GA
- Raman Subha, M.D.
  Professor of Cardiovascular Medicine, Biomedical Informatics, and Radiology
  Ohio State University Wexner Medical Center
  Columbus, OH