# Investigator Affiliations

- Andrea C. Skelly, Ph.D., M.P.H.
  Spectrum Research, Inc.
  Tacoma, WA
- Robin Hashimoto, Ph.D.
  Spectrum Research, Inc.
  Tacoma, WA
- David I. Buckley, M.D., M.P.H
  Oregon Health & Science University
  Portland, OR
- Erika D. Brodt, B.S.
  Spectrum Research, Inc.
  Tacoma, WA
- North Noelck, M.D., Ph.D.
  Oregon Health & Science University
  Portland, OR
- Annette M. Totten, Ph.D.
  Oregon Health & Science University
  Portland, OR
- Jonathan R. Lindner, M.D.
  Oregon Health & Science University
  Portland, OR
- Rongwei Fu, Ph.D.
  Oregon Health & Science University
  Portland, OR
- Marian McDonagh, Pharm.D.
  Oregon Health & Science University
  Portland, OR